# Acronyms and Abbreviations

AAA: American Academy of Audiology

AAHP: American Association of Health Plans

ABX: antimicrobial

AHCPR: Agency for Health Care Policy and Research

AHRQ: Agency for Healthcare Research and Quality

AMP: ampicillin

AMX: amoxicillin

AOM: acute otitis media

AOME: acute otitis media with effusion

APA: Ambulatory Pediatric Association

BID: two times a day

CBA: cost-benefit analysis

CEA: cost-effectiveness analysis

CFC: cefaclor

CFX: cefixime

CI: confidence interval

CINAHL: Cumulative Index to Nursing and Allied Health Literature

CLV: clavulanate

DARE: Database of Abstracts of Reviews of Effectiveness

DZ: disease

EES: erythromycin ethylsuccinate

ENT: ear, nose, and throat

EPI: episode

ER: emergency room

ERY: erythromycin

FACCT: Foundation for Accountability

GI: gastrointestinal

HMO: health maintenance organization

HZ: history

ICE: incremental cost effectiveness

IPA: International Pharmaceutical Abstracts

ME: middle ear

MEE: middle ear effusion

NAMCS: National Ambulatory Medical Care Survey

NAPNAP: National Association of Pediatric Nurse Associates and Practitioners

NHAMC: National Hospital Ambulatory Medical Care Survey

NHIS: National Health Interview Survey

NNT: number needed to treat

OM: otitis media

OR: odds ratio

PCN: penicillin

PE: pressure equalization

PMEE: persistent middle ear effusion

PPO: preferred provider organization

QALY: quality-adjusted life-years

QID: four times a day

RCT: randomized controlled trial

RR: relative risk

RX: prescription

SENTAC: Society for Ear, Nose, and Throat Advances in Children

SSX: sulfisoxazole

TID: three times a day

TMP-SMX: trimethoprim-sulfamethoxazole

TX: treatment

UI: unique identification

URI: upper respiratory infection