# Bibliography

Abrol B. The diagnosis and management of acute otitis media in infants. Indian Pediatr. 1973;10:141-5. [pmid: 4719234].
Adam D. [Therapy of bacterial infections within the scope of ENT in children]. Z Allgemeinmedizin. 1979;55:1012-8.
Adam D. Five-day therapy with cefpodoxime versus ten-day treatment with cefaclor in infants with acute otitis media. Infection. 1995;23:398-400.
Adam D. Modern cephalosporins as therapeutics for otitis media. Infect Dis Clin Practice. 1998;7:S96-8.
Adams PF, Benson V. Current estimates from the National Health Interview Survey, 1990. National Center for Health Statistics. Vital Health Stat 10 (181). Hyattsville, MD: U.S. Department of Health and Human Services, 1991.
Adams PF, Benson V. Current estimates from the National Health Interview Survey, 1994. National Center for Health Statistics. Vital Health Stat 10 (193). Hyattsville, MD: U.S. Department of Health and Human Services, 1995.
Addis DJ. Cyclacillin in the treatment of acute otitis media and acute streptococcal pharyngitis. Adv Ther. 1984;1:45-9.
Adler M, McDonald P, Keyserling C, et al Comparative safety and efficacy of cefdinir (CDR) and amoxicillin/clavulanate (A/C) in the treatment of acute suppurative otitis media in children Abstracts of the interscience conference on antimicrobial agents and chemotherapy 1996 36(0).
Adler M, McDonald PJ, Trostmann U, et al. Cefdinir versus amoxicillin/clavulanic acid in the treatment of suppurative acute otitis media in children. Eur J Clin Microb Infect Dis. 1997;16:214-9.
Agaeva N, Sultanova SM. Acute otitis media complicated by meningitis. Vestn Otorinolaringol. 1979;41:8-12.
Alban J. Epicillin in the treatment of pharyngitis and otitis media. Curr Ther Res Clin Exp. 1974;16:24-6. [pmid: 4203844].
Alho OP. How common is recurrent acute otitis media?. Acta Otolaryngol suppl. 1997;529:8-10. [pmid: 9288255].
Alho OP, Laara E, Oja H. What is the natural history of recurrent acute otitis media in infancy?. J Fam Pract. 1996;43:258-64. [pmid: 8797753].
Alsarraf R, Jung CJ, Perkins J, et al Otitis media health status evaluation: a pilot study for the investigation of cost-effective outcomes of recurrent acute otitis media treatment Ann Otol Rhinol Laryngol 1998 107(2):120 8 9486906
Amadasun JE. The cost effective medical treatment of suppurative otitis media in a Nigerian environment. W Afr J Med. 1997;16:85-7.
Andrade MA, Hoberman A, Glustein J, et al. Acute otitis media in children with bronchiolitis. Pediatrics. 1998;101:617-9. [pmid: 9521943].
Anonymous. Average hours and earnings of production or nonsupervisory workers1 on private nonfarm payrolls by major industry, 1964 to date. Employment. 1999;46.
Anonymous. Phenethicillin and penicillin V in the treatment of acute otitis media in children: a comparative trial from general practice. Lancet. 1962;1:947-9.
Anonymous. Local treatment with a corticosteroid-antibiotic preparation in infections of the ear. Practitioner. 1970;205:691-5. [pmid: 4923896].
Anonymous. The activity of doxycycline with respect to infection in diorhinolaryngology. Rev Laryngol Otol Rhinol. 1984;105:137-42.
Anonymous. Safe therapy with cefpodoxime in acute otitis media. Fortschr Med Suppl. 1994;111:3-4.
Anonymous. Effects of cefixime or co-amoxiclav treatment on nasopharyngeal carriage of Streptococcus pneumoniae and Haemophilus influenzae in children with acute otitis media. J Antimicrob Chemother. 1998;41:253-58. [pmid: 9533468].
Antonelli A, Cimino A, Di Girolamo A, et al. [The treatment of ENT phlogosis: seaprose S vs. nimesulide.]. Acta Otorhinolaryngol Ital. 1993;13:1-16.
Appelman CLM, Bossen PC, Dunk JHM, et al. Acute otitis media. Huisarts en Wetenschap. 1990;33:242-5.
Appelman CL, Claessen JQ, Touw-Otten FW, et al. Co-amoxiclav in recurrent acute otitis media: placebo controlled study. BMJ. 1991;303:1450-2. [pmid: 1773154]. [pmcid: 1671677].
Appelman CL, Claessen JQ, Touw-Otten FW, et al. Severity of inflammation of tympanic membrane as predictor of clinical course of recurrent acute otitis media. BMJ. 1993;306.
Arguedas A, Loaiza C, Herrera M, et al. Comparative trial of 3-day azithromycin versus 10-day amoxycillin/clavulanate potassium in the treatment of children with acute otitis media. Int J Antimicrob Agents. 1996;6:233-8. [pmid: 18611713].
Arguedas A, Loaiza C, Rodriguez F, et al. Comparative trial of 3 days of azithromycin versus 10 days of clarithromycin in the treatment of children with acute otitis media with effusion. J Chemother. 1997;9:44-50. [pmid: 9106017].
Arguedas AG, Zaleska M, Stutman HR, et al. Comparative trial of cefprozil vs. amoxicillin clavulanate potassium in the treatment of children with acute otitis media with effusion. Pediatr Infect Dis J. 1991;10:375-80. [pmid: 1906160].
Arnhold R. Acute otitis media-newer attitudes toward treatment. Clin Pediatr (Phila). 1967;6. [pmcid: 358331].
Arola M, Ruuskanen O, Ziegler T, et al. Clinical role of respiratory virus infection in acute otitis media. Pediatrics. 1990;86:848-55. [pmid: 2174535].
Arola M, Ziegler T, Ruuskanen O. Respiratory virus infection as a cause of prolonged symptoms in acute otitis media. J Pediatrics. 1990;116:697-701.
Aronovitz GH Middle ear infections in pediatric patients: treatment with amoxicillin J Infect Dis 1974suppl129:S185 6
Aronovitz GH. Treatment of otitis media with cefuroxime axetil. South Med J. 1988;81:978-80. [pmid: 3043692].
Aronovitz G. A multicenter, open label trial of azithromycin vs. amoxicillin/clavulanate for the management of acute otitis media in children. Pediatr Infect Dis J. 1996;15:S15-9. [pmid: 8878241].
Aronovitz GH, Doyle CA, Durham SJ, et al. Cefprozil vs. amoxicillin/clavulanate in the treatment of acute otitis media. Infect Med. 1992;9:19-32.
Asmar BI, Dajani AS, Del Beccaro MA, et al. Comparison of cefpodoxime proxetil and cefixime in the treatment of acute otitis media in infants and children. Otitis Study Group. Pediatrics. 1994;94:847-52. [pmid: 7971000].
Aspin MM, Hoberman A, McCarty J, et al. Comparative study of the safety and efficacy of clarithromycin and amoxicillin-clavulanate in the treatment of acute otitis media in children. J Pediatr. 1994;125:136-41. [pmid: 8021763].
Astruc J [Efficacy and tolerance of a new formulation of amoxicillin 100 mg - clavulanic acid 12.5 mg in acute otitis media in infants.] Ann Pediatr (Paris) 1992 39(2):142 8 358317 1580528
Aubert P. [Acute and seromucous otitis in the young child]. Revue de l Infirmiere. 1988;38:17-9.
Baba S, Ito H, Tsukiyama M, et al. [Clinical evaluation of long-acting preparation of cephalexin (S-6436) in the treatment of acute tonsillitis and acute otitis media-a double blind study (author's transl)]. Kansenshogaku Zasshi - J Jpn Assoc Infect Dis. 1977;51:286-302.
Baba S, Hondo J, Wada K, et al. Evaluation of cefroxadine (CGP-9000) in acute tonsillitis, acute suppurative otitis media and acute exacerbation of chronic otitis media. A comparative double blind study with cephalexin. Chemotherapy. 1980;28:590-618.
Baba S. A comparative double-blind evaluation of AM-715 with amino benzyl penicillin in acute suppurative otitis media and acute exacerbation of chronic suppurative otitis media. Practica Otologica Kyoto. 1982;75:1835-58.
Baba S. Clinical studies on augmentin in the treatment of otorhinolaryngological infections augmentin. Proceedings of an international symposium, Montreux, Switzerland. 1982:149-55.
Baba S, Ito H, Kinoshita H, et al. [Comparative study on cefmetazole and cefazolin in the treatment of suppurative otitis media]. Jpn J Antibiot. 1982;35:1523-52. [pmid: 6752467].
Baba S, Murai K, Kinoshita H, et al. [Double-blind comparative trial of cefroxadine and cephalexin in the treatment of acute suppurative otitis media and acute exacerbation of chronic suppurative otitis media]. Jpn J Antibiot. 1983;36:2595-634. [pmid: 6361325].
Baba S, Murai K, Kinoshita H, et al. Evaluation of BRL25000 (clavulanic acid-amoxicillin) in acute purulent otitis media and acute exacerbation of chronic purulent otitis media. A comparative double blind study with amoxicillin. Chemotherapy (TOKYO). 1983;31:97-112. [pmcid: 314422].
Baba S, Wada K, Maseki T, et al. [Therapeutic evaluation of an ampicillin suppository (KS-R1) used against acute suppurative otitis media in children: a comparison with an oral preparation]. Jpn J Antibiot. 1983;36:1973-94. [pmid: 6361321].
Baba S, Kinoshita H, Mori Y, et al. A comparative double blind study of AT-2266 with pipemidic acid in the treatment of suppurative otitis media. Chemotherapy. 1984.
Baba S, Kinoshita H, Mori Y, et al. Evaluation of clinical effectiveness and safety of lenampicillin in acute suppurative otitis media and acute exacerbation of chronic suppurative otitis media in comparison with talampicillin by double-blind method. Otologia Fukuoka. 1985;31:790-824.
Baba S, Kinoshita H, Sasaki T, et al. A comparative double-blind study of norfloxacin and pipemidic-acid in suppurative otitis media. Otologia Fukuoka. 1986;32:843-67.
Baba S, Kinoshita H, Mori Y, et al. [A parallel comparative double blind study of cefixime with cefaclor in the treatment of acute suppurative otitis media in children]. Jpn J Antibiot. 1987;40:1-24. [pmid: 3295321].
Baba S, Shimada J, Soyano K, et al. Clinical evaluation of cefuroxime axetil in suppurative otitis media acute infections and acute exacerbation of chronic infections. A double-blind comparison with cefaclor. Otologia Fukuoka. 1987;33:725-47.
Baba S, Mori Y, Suzuk K, et al. Evaluation of Cs-807 in suppurative otitis media. A comparative double blind study with cefaclor. Otologia Fukuoka. 1988;34:1274-96.
Baba S, Kasazima T, Takasaka T, et al. Clinical evaluation of cefotiam hexetil in suppurative otitis media acute infection and acute exacerbation of chronic infection. A double blind comparative study with cefaclor. Otologia Fukuoka. 1989;35:82-102.
Baba S, Soyano K, Mori N, et al. Comparative study of roxithromycin ru-28965 and midecamycin acetate in the treatment of suppurative otitis media. Otologia Fukuoka. 1989;35:314-40.
Baba S, Mori Y, Suzuki K, et al. [Evaluation of the efficacy of ceftriaxone in acute suppurative otitis media and acute exacerbation of chronic suppurative otitis media. A comparative study with cefotiam as the control]. Jpn J Antibiot. 1989;42:212-47. [pmid: 2523493].
Baba S, Soyano K, Takasaka T, et al. Evaluation of TE-031 in treatment of suppurative otitis media. Results of a double-blind comparative clinical study with josamycin. Otologia Fukuoka. 1989;35:113-33.
Baba S. Clinical studies of sparfloxacin in the field of otorhinolaryngology. Drugs. 1993;46:329-30.
Babonis T, Weir MR, Kelly PC, et al. Progression of tympanometry and acoustic reflectometry. Findings in children with acute otitis media. Clin Pediatr. 1994;33:593-600.
Backhouse CI, Woods P. Trimethoprim and amoxycillin in acute otitis media. Practitioner. 1985;229:51-4. [pmid: 3887355].
Bain DJ. Acute otitis media in general practice. Practitioner. 1981;225:1568-75. [pmid: 6174965].
Bain DJ. Can the clinical course of acute otitis media be modified by systemic decongestant or antihistamine treatment?. Br Med J (Clin Res Ed.). 1983;287:654-6.
Bain J, Murphy E, Ross F. Acute otitis media: clinical course among children who received a short course of high dose antibiotic. Br Med J (Clin Res Ed.). 1985;291:1243-6.
Bain J. Childhood otalgia: acute otitis media. 2. Justification for antibiotic use in general practice. BMJ. 1990;300:1006-7. [pmid: 2344488]. [pmcid: 1662711].
Banz K, Schwicker D, Thomas AM. Economic evaluation of immunoprophylaxis in children with recurrent ear, nose, and throat infections. Pharmacoeconomics. 1994;6:464-77. [pmid: 10155274].
Baquero-Artigao F, Del Castillo F, Garcia-Perea A. Antimicrobial resistance of Streptococcus pneumoniae from acute otitis media in Spain: Influence of recent antibiotic therapy. In: Abstracts of the 37th interscience conference on antimicrobial agents & chemotherapy, 1997:346.
Baranski-Filho MC, Da Silva Durao A, Moura E, et al. Sodium and benzathine ampicillin in acute otitis media. Multicenter study. Folha Med. 1983;87:235-7.
Barnett ED, Klein JO, Hawkins KA, et al. Comparison of spectral gradient acoustic reflectometry and other diagnostic techniques for detection of middle ear effusion in children with middle ear disease. Pediatr Infect Dis J. 1998;17:556-9. [pmid: 9655560].
Barnett ED, Klein JO, Teele DW, et al. Single dose ceftriaxone for acute otitis media. In: Abstracts of the 34th interscience conference on antimicrobial agents & chemotherapy, 1994:219.
Barnett ED, Levatin JL, Klein OJ, et al. Challenges of evaluating homeopathic treatment of acute otitis media. In: Lim DJ and Bluestone CD, directors. Abstracts of the 7^th^ international symposium on recent advances in otitis media, 1999:110.
Barnett ED, Teele DW, Klein JO, et al Comparison of ceftriaxone and trimethoprim-sulfamethoxazole for acute otitis media. Greater Boston Otitis Media Study Group Pediatrics 1997 99(1):23 8 8989332
Barry A, Garaud J, Hare R, et al. Correlation of clinical outcome with microbiological susceptibilities (S) to ceftibuten (Cftb) and cefactor (Ccl). Abstracts of the 36th interscience conference on antimicrobial agents & chemotherapy, 1996:97.
Barry B, Gehanno P, Blumen M, et al. Clinical outcome of acute otitis media caused by pneumococci with decreased susceptibility to penicillin. Scand J Infect Dis. 1994;26:446-52. [pmid: 7984977].
Bartolozzi G, Sacchetti A, Scarane P, et al. Natural history of otitis media with effusion in children under six years of age. Adv Otorhinolaryngol. 1992;47:281-3. [pmid: 1456148].
Barulina NV, Sharafutdinova TA. Characteristics of the course and treatment of acute otitis media in infants and toddlers. Vestn Otorinolaringol. 1991;2:58-9. [pmid: 2048257].
Bass JW, Cashman TM, Frostad AL, et al Antimicrobials in the treatment of acute otitis media. A second clinical trial Am J Dis Child 1973 125(3):397 402 4632555
Bass JW, Cohen SH, Corless JD, et al Ampicillin compared to other antimicrobials in acute otitis media JAMA 1967 202(8):697 702 4964192
Bass JW, Cohen SH, Corless JD, et al. Ampicillin trihydrate in the treatment of acute otitis media in children. Ann N Y Acad Sci. 1967;145:379-86. [pmid: 4397882].
Bass LW, Wolfson JH, Breck JM, et al. Cefaclor compared to augmentin for acute otitis media. Ann Otol Rhinol Laryngol 1983;96.
Bauchner H, Adams W, Barnett E, Klein J Therapy for acute otitis media. Preference of parents for oral or parenteral antibiotic Arch Pediatr Adolesc Med 1996 150(4):396 9 8634735
Bazet MC, Blanc F, Chumdermpadetsuk S, et al. Roxithromycin in the treatment of paediatric infections. Br J Clin Pract. 1988;42:117-8.
Beatson JM, Marsh BT, Talbot DJ. A clinical comparison of pivmecillinam plus pivampicillin (Miraxid) and a triple tetracycline combination (Deteclo) in respiratory infections treated in general practice. J Int Med Res. 1985;13:197-202. [pmid: 3930309].
Begg C, Cho M, Eastwood S, et al. Improving the quality of reporting of randomized controlled trials: the CONSORT statement. JAMA. 1996;276:637-9. [pmid: 8773637].
Begue P, Broussin B, Quinet B, et al. [Acute otitis media in children: A randomized and open clinical trial of the efficacy of 2 major antibiotics (erythromycin ethylsuccinate/acetyl sulfafurazole vs amoxicillin/clavulanic acid)]. Ann Pediatr (Paris). 1990;37:127-30. [pmcid: 358317]. [pmid: 2181915].
Begue P, Lacroix J. Cefuroxime axetil and respiratory tract infection: Results of a multicenter trial conducted in pediatric offices. Medecine et Maladies Infectieuses. 1991;21:75-8.
Begue P, Boulesteix J, Dubreuil C, et al. Cefixime versus amoxicillin-clavulanate for the treatment of acute otitis media in children. Medecine Et Maladies Infectieuses. 1996;26:125-32.
Begue P, Boulesteix J, Dubreuil C, et al. Cefixime versus amoxicillin-clavulanic acid combination in treating acute otitis media in children: Evaluation of clinical efficacy and tolerance. Arch Pediatr 1996;3.
Behre U, Burow HM, Quinn P, et al. Efficacy of twice-daily dosing of amoxycillin/clavulanate in acute otitis media in children. Infection. 1997;25:163-6. [pmid: 9181384].
Beiger M, Gilabert B, Ducos A, et al. [Suppurative otitis in children's outpatient clinic]. Rev Chil Pediatr. 1971;42:125-32. [pmid: 5088123].
Bellioni P, Di Luzio Paparatti U, Salvinella F, et al. Miocamycin for the management of ORL infections. Eur Rev Med Pharmacol Sci. 1987;9:293-8.
Bellomo D, Di Nicola R [Antibiotic therapy and inflammatory pathology of the middle ear] Arch Ital Laringol 1965 73(Suppl):89 104
Benson V, Marano MA. Current estimates from the National Health Interview Survey, 1993. National Center for Health Statistics. Vital Health Stat 10 (190). Hyattsville, MD: U.S. Department of Health and Human Services, 1994.
Benson V, Marano MA. Current estimates from the National Health Interview Survey, 1995. National Center for Health Statistics. Vital Health Stat 10 (199). Hyattsville, MD: U.S. Department of Health and Human Services, 1998.
Bergeron MG, Ahronheim G, Richard JE, et al. Comparative efficacies of erythromycin-sulfisoxazole and cefaclor in acute otitis media: A double blind randomized trial. Pediatr Infect Dis J. 1987;6:654-60. [pmid: 3302918].
Bergholz L, Hallander H, Rudberg R. Treatment of acute otitis media with azidocillin administered twice daily. Scand J Infect Dis. 1973;5:203-8. [pmid: 4588302].
Bergholz L, Rudberg R. [Treatment of otitis media acuta]. Lakartidningen. 1972;69:3922-8. [pmid: 4403509].
Bergholz L, Rudberg R. [Acute otitis media-myringotomy or not?]. Lakartidningen. 1973;70:3043-4. [pmid: 4133415].
Bergstrom BK, Bertilson SO, Movin G. Clinical evaluation of rectally administered ampicillin in acute otitis media. J Int Med Res. 1988;16:376-85. [pmid: 3197915].
Berman S, Byrns PJ, Bondy J, et al. Otitis media-related antibiotic prescribing patterns, outcomes, and expenditures in a pediatric medicaid population. Pediatrics. 1997;100:585-92. [pmid: 9310510].
Berman S, Lauer BA. A controlled trial of cefaclor versus amoxicillin for treatment of acute otitis media in early infancy. Pediatr Infect Dis J. 1983;2:30-3.
Berman S, Roark R. Factors influencing outcome in children treated with antibiotics for acute otitis media. Pediatr Infect Dis J. 1993;12:20-4. [pmid: 8417420].
Berman S, Roark R, Luckey D. Theoretical cost-effectiveness of management options for children with persisting middle ear infusions. Pediatrics. 1994;93:353-63. [pmid: 8115191].
Bhambhani K, Asmar B, Kobos DM. Cefaclor twice-a-day vs. 3-times-a-day vs. amoxicillin in the treatment of acute otitis media. Joint meeting of the American Pediatric Society and the Society For Pediatric Research; 1985 May 6-9; Washington, D.C.. Pediatric Research 19 (4 part 2);1985; p. 237a.s.
Bhambhani K, Foulds DM, Swamy KN. Acute otitis media in children: Are decongestants or antihistamines necessary?. Ann Emerg Med. 1983;12:13-6. [pmid: 6185020].
Biles RW, Buffler PA, O'Donell AA. Epidemiology of otitis media: A community study. Am J Public Health. 1980;70:593-8. [pmid: 7377434]. [pmcid: 1619433].
Biolcati AH. An open comparative study of the efficacy and safety of sultamicillin versus cefaclor in the treatment of acute otitis media in children. J Int Med Res. 1992;20:A31-43.
Birrell JF. Otitis media. BMJ. 1976;1:443-5. [pmid: 1252785]. [pmcid: 1638938].
Bisonni RS, Lawler FH, Pierce L. Recurrent otitis media: A cost-utility analysis of simulated treatment using tympanostomy tubes vs antibiotic prophylaxis. Fam Pract Res J. 1991;11:371-8. [pmid: 1767684].
Blahova O, Drastik J. [Antibiotics for recurrent acute otitis media in infants under two (author's transl)]. Z Laryngol Rhinol Otol. 1973;52:802-7. [pmid: 4149361].
Bland RD. Otitis media in the first six weeks of life: Diagnosis, bacteriology, and management. Pediatrics. 1972;49:187-97. [pmid: 4551016].
Block SL, Hedrick J, Sperling M, et al. A comparison of two different doses of augmentin in the treatment of otitis media (OM) in children. In: Program & abstracts of the 33rd interscience conference on antimicrobial agents & chemotherapy, 1993:155.
Block SL, Hedrick JA, Tyler R, et al. Penicillin-resistant pneumococcal acute otitis media: Recently-treated vs. untreated otitis. Pediatr Res 1994;37.
Blomqvist M, Hedstrom SA. The clinical efficacy and safety of bacampicillin twice daily in comparative studies. J Int Med Res. 1987;15:32-43. [pmid: 3545941].
Bluestone CD Role of sulbactam-ampicillin and sultamicillin in the treatment of bacterial infections of the upper respiratory tract of children Symposium on sulbactam: Worldwide clinical experience held at the XV International Congress Of Chemotherapy 1989 Suppl97(5):35 40
Bluestone CD. Surgery for otitis media: Results of randomized clinical trial as related to clinical practice. Adv Otorhinolaryngol. 1992:319-24.
Bluestone CD, Beery QC, Michaels RH, et al. Cefaclor compared with amoxycillin acute otitis media with effusion: A preliminary report. Postgrad Med J. 1979;55:42-9.
Bluestone CD, Klein JO. Management of otitis media in infants and children. Philadelphia: W. B. Saunders Company, 1995.
Bluestone CD and Klein JO. Otitis media, atelectasis, and eustachian tube dysfunction. In: Bluestone CD, Stool SE, Kenna M, eds. Pediatric otolaryngology. Philadelphia: W. B. Saunders Company, 1996.
Blumer JL. Cefixime. Drug Ther. 1989;19:60-84.
Blumer JL, Bertino JS Jr, Husak MP Comparison of cefaclor and trimethoprim-sulfamethoxazole in the treatment of acute otitis media Pediatr Infect Dis 1984 3(1):25 9 6366771
Blumer JL, Forti WP, Summerhouse TL. Comparison of the efficacy and tolerability of once-daily ceftibuten and twice-daily cefprozil in the treatment of children with acute otitis media. Clin Ther. 1996;18:811-20. [pmid: 8930425].
Blumer JL, McLinn SE, Deabate CA, et al. Multinational multicenter controlled trial comparing ceftibuten with cefaclor for the treatment of acute otitis media. Members of the Ceftibuten Otitis Media International Study Group. Pediatr Infect Dis J. 1995;14:S115-20. [pmid: 7567311].
Boccazzi A, Borzani M, Scotti L. [Amoxicillin-clavulanic acid combination in bacterial infections of the upper respiratory tract in childhood. Controlled clinical study.]. Pediatr Med Chir. 1988;10:395-400. [pmid: 3068633].
Bollag U, Bollag-Albrecht E Recommendations derived from practice audit for the treatment of acute otitis media Lancet 1991 338(Jul 13):96 9 1676479
Bonato F, Pesavento G, Ecari U, et al. Use of cefoperazone sodium in treatment of ENT infections. G Mal Infett Parassit. 1987;39:325-9.
Borderon JC, Ramponi N, Ployet MJ, et al. A clinical trial of amoxicillin + clavulanic acid in pediatric patients. Ann Pediatr (Paris). 1985;32:895-9. [pmcid: 358317]. [pmid: 4091446].
Bottenfield GW, Burch DJ, Hedrick JA, et al Safety and tolerability of a new formulation (90 mg/kg/day divided every 12 h) of amoxicillin/clavulanate (Augmentin) in the empiric treatment of pediatric acute otitis media caused by drug-resistant Streptococcus pneumoniae Pediatr Infect Dis J 1998 17(10):963 8 9802654
Boulesteix J, Begue P, Dubreuil C, et al. Acute otitis media in children: A study of nasopharyngeal carriage of potential pathogens and therapeutic efficacy of cefixime and amoxicillin-clavulanate. Infection. 1995;23:S79-82. [pmid: 8537137].
Boulesteix J, Dubreuil C, Moutot M, et al Cefpodoxime proxetil five days versus cefixime eight days in the treatment of acute otitis media in children Med Mal Infect 1995 25(3 Bis):534 9
Bourrel J, Capdevielle R, Fournier JC, et al. Co-trimoxazole in suspension for oral administration in infants and children with acute otitis in general practice. Med Interne. 1983;18:210-1.
Branthaver B, Greiner DL, Eichelberger B. Determination of cost-effective treatment of acute otitis media from HMO records. Am J Health Syst Pharm. 1997;54:2736-40. [pmid: 9408521].
Brodie DP, Griggs JV, Cunningham K Comparative study of cefuroxime axetil suspension and amoxycillin syrup in the treatment of acute otitis media in general practice J Int Med Res 1990 18(3):235 9 2113874
Brook I, Gober AE. Microbiologic chara teristics of persistent otitis media. Arch Otolaryngol Head Neck Surg. 1998;124:1350-2. [pmid: 9865757].
Brook I, Yocum P. Bacteriology and beta-lactamase activity in ear aspirates of acute otitis media that failed amoxicillin therapy. Pediatr Infect Dis J. 1995;14:805-8. [pmid: 8559633].
Browning GG. Childhood otalgia: Acute otitis media. 1. Antibiotics not necessary in most cases. BMJ. 1990;300:1005-6. [pmid: 2344487]. [pmcid: 1662707].
Brownlee RC Jr, DeLoache WR, Cowan CC Jr, et al. Otitis media in children. Incidence, treatment, and prognosis in pediatr practice. J Pediatr. 1969;75:636-42. [pmid: 5809840].
Burch D, McCracken G, Moonsammy G, et al. Clinical profile of a new formulation of amoxicillin/clavulanate (A/C) for the treatment of acute otitis media (AOM). Clin Infect Dis. 1997;25.
Burch D, McCracken G, Moonsammy G. Clinical profile of a new formulation of amoxicillin/clavulanate (A/C) for the treatment of acute otitis media (AOM). Pediatrics. 1998;102.
Burke P, Bain J, Robinson D, Dunleavey J Acute red ear in children: controlled trial of non-antibiotic treatment in general practice BMJ 1991 303(6802):558 62 1912887 1670875
Burns WW, Frenkel LD. Ceftriaxone for treatment of otitis media. Pediatr Infect Dis J. 1990;9:226-7.
Bush AM. An evaluation of methacycline hydrochloride (6 methylene oxytetracycline). NZ Med J. 1967;66:240-3.
Bussi R, Marchetti F, Murgia V, et al. Efficacy of first choice antibiotics for upper respiratory tract infections. Ricerca e Pratica 1995:147-57.
Byrns PJ, Bondy J, Glazner JE, et al. Utilization of services for otitis media by children enrolled in Medicaid. Arch Pediatr Adolesc Med. 1997;151:407-13. [pmid: 9111441].
Callahan CW Cost effectiveness of antibiotic therapy for otitis media in a military pediatric clinic Pediatr Infect Dis J 1988 7(9):622 5 3140210
Cameron GG, Pomahac AC, Johnston MT. Comparative efficacy of ampicillin and trimethoprim-sulfamethoxazole in otitis media. Can Med Assoc J. 1975;112:87-8. [pmid: 1093657].
Campelli A, Fioredda F, Ranieri E, et al. Treatment of otitis media. In: Frior R, Pestalozza G, eds. The child and the future: Present and future trends. International Congress Series. New York: Elsevier Science Publishers, 1993:13-6.
Cantekin EI, Mandel EM, Bluestone CD et al Lack of efficacy of a decongestant-antihistamine combination for otitis media with effusion ("secretory" otitis media) in children. Results of a double-blind, randomized trial N Engl J Med 1983 308(6):297 301 6337322
Careddu P, Bellosta C, Tonelli P, et al. Efficacy and tolerability of brodimoprim in pediatric infections. J Chemother. 1993;5:543-5. [pmid: 8195853].
Carlin SA, Marchant CD, Shurin PA, et al. Early recurrences of otitis media: Reinfection or relapse? [published erratum appears in J Pediatr 1987 Apr;110(4):668]. J Pediatr. 1987;110:20-5. [pmid: 3540247].
Carlin SA, Marchant CD, Shurin PA, et al. Host factors and early therapeutic response in acute otitis media. J Pediatr. 1991;118:178-83. [pmid: 1899699].
Carlin SA, Shurin PA, Marchant CD, et al Nine year experience with antibiotic treatments ATB Rx of otitis media (OM) factors in treatment failure Joint meeting of the American Pediatric Society and the Society For Pediatric Research; Pediatr Res 1989 25(4part2):
Carr WG. Clindamycin palmitate hydrochloride: A clinical trial in a pediatric office practice. Curr Ther Res Clin Exp. 1973;15:630-40. [pmid: 4201546].
Carvalho ES, Campos SO, Pignatari SN, et al. Efficacy and safety of cefprozil versus cefaclor in the treatment of acute otitis media in pediatric patients. J Pediatr. 1998;74:461-6.
Casselbrant ML, Brostoff LM, Cantekin EI, et al. Otitis media with effusion in preschool children. Laryngoscope. 1985;95:428-36. [pmid: 4039020].
Casselbrant ML, Brostoff LM, Cantekin EI, et al Incidence, prevalence, and natural history of otitis media in children in Pittsburgh Ann Otol Rhinol Laryngol 1990 149(Suppl):28 9
Casselbrant ML, Kaleida PH, Rockette HE, et al Efficacy of antimicrobial prophylaxis and of tympanostomy tube insertion for prevention of recurrent acute otitis media: results of a randomized clinical trial Pediatr Infect Dis J 1992 11(4):278 86 1565551
Catalano GB, Serra A, La Mantia I. Use of amoxycillin and clavulanic acid combination in the infections of the otorhinolaryngological area. Riv Ital Otorinolaringol Audiologia e Foniatria. 1988;8:359-65.
Catania S, Mascellino MT, Fornasiero M, et al. Miokamycin for upper respiratory tract infections. Eur Rev Med Pharmacol Sci. 1987;9:323-5.
Celik O, Gok U, Yalcin S, et al. Comparison of the clinical efficacy of azithromycin and cefuroxime axetile in the treatment of patients with acute otitis media. Mikrobiyol Bul. 1997;31:253-61.
Chalmers I, Adams M, Dickersin K, et al A cohort study of summary reports of controlled trials JAMA 1990 Mar 9 263(10):1401 5
Chamberlain JM, Boenning DA, Waisman Y, et al Single-dose ceftriaxone versus 10 days of cefaclor for otitis media Clin Pediatr 1994 33(11):642 6
Chan KH, Bluestone CD, Tan LS, et al. Comparative study of sultamicillin and amoxicillin-clavulanate: Treatment of acute otitis media. Pediatr Infect Dis J. 1993;12:24-8. [pmid: 8417421].
Chaput de Saintonge DM, Levine DF, Savage IT, et al. Trial of three-day and ten-day courses of amoxycillin in otitis media. BMJ. 1982;284:1078-81. [pmid: 6802412]. [pmcid: 1497899].
Charles D, Bluestone MD. [Epidemiology, bacteriology and clinical experience with cefixime in the treatment of acute infantile otitis media.]. An Esp Pediatr. 1991;35:101-4.
Chernyi VV. Experience in the treatment of young children with an unfavorable curse of acute purulent otitis media. Vestn Otorinolaringol. 1986;1.
Chibante A, Burdeksa A, Kissling M. Efficacy and tolerability of cefetamet pivoxil in toddlers with respiratory tract infections. Drug Invest. 1992;4:252-7.
Chibante A, Peixoto E, Lejeune R, et al. Clinical efficacy and safety of cefetamet pivoxil in toddlers. Int J Antimicrob Agents. 1994;4:203-10. [pmid: 18611612].
Chiche D. Cefuroxime axetil (Zinnat). Concours Med. 1990;112:3008-10.
Chilton LA, Skipper BE. Antihistamines and alpha-adrenergic agents in treatment of otitis media. South Med J. 1979;72:953-5. [pmid: 382379].
Chomarat M, Dubreuil C. [Treatment of acute otitis media: Comparative study of efficacy of cefatrizine and amoxicillin-clavulanic acid.]. Pathol Biol. 1991;39:555-7. [pmid: 1881694].
Chonmaitree T, Owen MJ, Patel JA, et al. Effect of viral respiratory tract infection on outcome of acute otitis media. J Pediatr. 1992;120:856-62. [pmid: 1534364].
Chow AW, Hall CB, Klein JO, et al Evaluation of new anti-infective drugs for the treatment of respiratory tract infections Clin Infect Dis 1992 15(suppl 1):S62 88 1477253
Christensen CH, Hartmann E. Treatment of sinusitis and otitis media with pivampicillin. Pharmatherapeutica. 1980;2:469-74. [pmid: 7208541].
Cicchetti V, Luvara A, Martino AM, et al. [Comparative clinical study with rifampicin and other antibiotics in the treatment of acute otitis in children.]. Minerva Pediatr. 1971;23:1684-8. [pmid: 5132352].
Cioce C, Pestalozza G. Azithromycin in the treatment of acute otitis media in children: Comparative trial with amoxicillin plus clavulanic acid. In: Frior R, Pestalozza G, editors. The child and the environment: Present and future needs. New York: Elsevier Science Publishers, 1993:141-4.
Claassen AJ, Hough AP. A microbiological study of acute otitis media in Bloemfontein. S Afr Med J. 1987;71:15-6. [pmid: 3798284].
Claessen JQ, Appelman CL, Touw-Otten FW, et al. Persistence of middle ear dysfunction after recurrent acute otitis media. Clin Otolaryngol. 1994;19:35-40. [pmid: 8174299].
Clemente M, Morera C. Open assay with soltrim in otitis media. Rev Clin Esp. 1983;168:409-10. [pmid: 6603635].
Clements DA, Langdon L, Bland C, et al. Influenza A vaccine decreases the incidence of otitis media in 6- to 30-month-old children in day care. Arch Pediatr Adolesc Med. 1995;149:1113-7. [pmid: 7550814].
Coffey JD Jr, Martin AD, Booth HN. Neisseria catarrhalis in exudate otitis media. Arch Otolaryngol. 1967;86:403-6. [pmid: 6041112].
Cohen R, Bingen E, Varon E, et al. Change in nasopharyngeal carriage of Streptococcus pneumoniae resulting from antibiotic therapy for acute otitis media in children. Pediatr Infect Dis J. 1997;16:555-60. [pmid: 9194104].
Cohen R, de La Rocque F, Boucherat M, et al. Randomized open study of Pediazole (R) versus cefaclor in children with acute otitis media. Ann Pediatr. 1991;38:115-9.
Cohen R, de La Rocque F, Boucherat M, et al. Cefpodoxime proxetil vx cefixime for painful febrile acute otitis media in children. Med Mal Infect. 1994;24:844-51.
Cohen R, de la Rocque F, Boucherat M, et al. Treatment failure in otitis media: an analysis. J Chemother. 1994;6:17-22. discussion 23-4. [pmid: 7861210].
Cohen R, de La Rocque F, Boucherat M, et al Randomized trial comparing 5-day cefpodoxime proxetil and 8-day amoxicillin-clavulanate treatment of acute otitis media in children Med Mal Infect 1997 27(5):596 602
Cohen R, de La Rocque F, Bouhanna A, et al. [Randomized study of cefatrizine versus cefaclor in conjunctivitis otitis syndrome.]. Pathol Biol. 1990;38:517-20. [pmid: 2200994].
Cohen R, Lebeaut A, Narcy P. Treatment of acute otitis media by an oral pediatric suspension of amoxicillin-clavulanic acid. Ann Pediatr (Paris). 1989;36:49-54. [pmcid: 358317]. [pmid: 2648939].
Cohen R, Levy C, Boucherat M, et al. Five vs. ten days of therapy for acute otitis media (AOM) in young children. Abstracts of the 37th interscience conference on antimicrobial agents and chemotherapy. 1997:370.
Cohen R, Levy C, Boucherat M, et al A multicenter, randomized, double-blind trial of 5 versus 10 days of antibiotic therapy for acute otitis media in young children J Pediatr 1998 133(5):634 9 9821420
Cohen R, Navel M, Grumberg J, et al. Single dose ceftriaxone (CRO) for acute otitis media in area with high resistance to Streptococcus pneumoniae. Abstracts of the 37th Interscience Conference on Antimicrobial Agents & Chemotherapy. 1997:370.
Coles SJ, Addlestone MB, Kamdar MK, et al. A comparative study of clarithromycin and amoxycillin suspensions in the treatment of pediatric patients with acute otitis media. Infection. 1993;21:272-8. [pmid: 8225637].
Coles SJ, Macklin JL, Addlestone MB, et al. Clarithromycin versus amoxicillin suspensions in the treatment of acute otitis media in children. In: New HC, Young LS, Zinner SH Acar JF, eds. Infectious disease and therapy: New macrolides. New York: Marcel Dekker, Inc. 1995:451-5.
Cooper J, Inman JS, Dawson AF. A comparison between co-trimoxazole and amoxycillin in the treatment of acute otitis media in general practice. Practitioner. 1976;217:804-9. [pmid: 11457].
Craig WA, Gerber AU. Worldwide experience with bacampicillin administered twice a day. Rev Infect Dis. 1981;3:171-7. [pmid: 7012998].
Cremonesi G, Tarantino V, Stura M, et al. Comparison of cefatrizine and erythromycin for pediatric ear, nose, and throat infections. Clin Ther. 1987;9:263-6. [pmid: 3300988].
Croteau N, Hai-Vu, Pless IB, Infante-Rivard C. Trends in medical visits and surgery for otitis media among children. Am J Dis Child. 1990;144:535-8. [pmid: 2330920].
Cruz Filho NA, Bastos HM, Reis SD. Ampicillin in Acute Otitis Media. Folha Med. 1989;99:169-74.
Culpepper L, Froom J Routine Antimicrobial treatment of acute otitis media: Is it necessary? JAMA 1997 278(20):1643 5 9388073
Culpepper L, Froom J, Bartelds AI, et al. Acute otitis media in adults: A report from the International Primary Care Network [published erratum appears in J Am Board Fam Pract 1993 Nov-Dec; 6(6):616.]. J Am Board Fam Pract. 1993;6:333-9. [pmid: 8352035].
Culpepper L, Long D, and Sisk J. Appendix E. Report of the AHCPR otitis media guideline panel committee for scientific assessment of Pittsburgh Otitis Media Research Center (OMRC) and Cantekin Publications. In: Stool SE, Berg AO, Berman S, et al. Otitis media with effusion in young children. Clinical practice guideline, Number 12. Rockville MD: U.S. Department of Health and Human Services, Agency for Health Care Policy and Research, Public Health Service, 1994 AHCPR Publication No. 94-0622.
Cunha BA. Oral cephalosporins for common infections. Emerg Med. 1990;22:89-92, 97-8.
Dabernat H, Geslin P, Megraud F, et al. Study of nasopharyngeal (NP) carriage and effects of two antibiotics on potential pathogens in children with acute otitis media (AOM). Abstracts of the 35th interscience conference on antimicrobial agents and chemotherapy; 1995;40.
Dabernat H, Geslin P, Megraud F, et al. Effects of cefixime or co-amoxiclav treatment on nasopharyngeal carriage of Streptococcus pneumoniae and Haemophilus influenzae in children with acute otitis media. J Antimicrob Chemother. 1998;41:253-8. [pmid: 9533468].
Dadswell JV. Bacteriological findings in acute otitis media. Lancet. 1967;1:243-5. [pmid: 4163147].
Dagan R, Abtamson O, Leibovitz E, et al. Eradication of organisms from middle ear fluid (MEF) in childhood acute otitis media (AOM): Comparison between cefuroxime axetil (CXM) and cefaclor (CECL) suspensions. Abstracts of the 36th interscience conference on antimicrobial agents and chemotherapy; 1996:254.
Dagan R, Abramson O, Leibovitz E, et al. Impaired bacteriologic response to oral cephalosporins in acute otitis media caused by pneumococci with intermediate resistance to penicillin. Pediatr Infect Dis J. 1996;15:980-5. [pmid: 8933545].
Dagan R, Abramson O, Leibovitz E, et al. Bacteriologic response to oral cephalosporins: Are established susceptibility breakpoints appropriate in the case of acute otitis media?. J Infect Dis. 1997;176:1253-9. [pmid: 9359726].
Dagan R, Leibovitz E, Greenberg D, et al. Dynamics of pneumococcal nasopharyngeal colonization during the first days of antibiotic treatment in pediatric patients. Pediatr Infect Dis J. 1998;17:880-5. [pmid: 9802628].
Dagan R, Leibovitz E, Greenberg D, et al. Early eradication of pathogens from middle ear fluid during antibiotic treatment of acute otitis media is associated with improved clinical outcome. Pediatr Infect Dis J. 1998;17:776-82. [pmid: 9779760].
Dagan R, Leibovitz E, Jacobs M, et al. Bacteriologic response to acute otitis media (AOM) caused by Haemophilus influenzae (HI) treated with azithromycin (AZ). Abstracts of the 37th interscience conference on antimicrobial agents and chemotherapy. 1997:345.
Damoiseaux RAMJ, van Balen RAM, Hoes AW, et al. Antibiotic treatment of acute otitis media in children under two years of age: evidence based?. Br J Clin Pract. 1998;48:1861-4.
Daniel RR Comparison of azithromycin and co-amoxiclav in the treatment of otitis media in children J Antimicrob Chemother 1993 31(Suppl E):65 71 8396099
Daschner F, Behre U. Twice daily is enough with cefaclor. Mod Med. 1981;9:665-7.
Day JC. U. S. Bureau of the Census, Current Population Reports. Washington, D.C.: U.S. Government Printing Office, 1996, No. P25-1130.
De Campora E, Camaioni A, Leonardi M, et al. Comparative efficacy and safety of roxithromycin and clarithromycin in upper respiratory tract infections. Diagn-Microbiol-Infect-Dis. 1992;15:119S-22. [pmid: 1535578].
De Jose MI, De Miguel MJG, Aristegui J, et al. International multicenter study comparing azithromycin and amoxicillin- clavulinemic acid in the treatment of pediatric acute otitis media. Acta. 1998;56:350-5.
Deguchi K, Yokota N, Tanaka S, et al. [A clinical bacteriological efficacy study on a fosfomycin otic solution.]. Jpn J Antibiot. 1986;39:2344-54. [pmid: 3099028].
Deguine C, Pulec JL. Acute suppurative otitis media. Ear Nose Throat J. 1993;72.
Del Castillo F, Baquero-Artigao F, Garcia-Perea A. Influence of recent antibiotic therapy on antimicrobial resistance of Streptococcus pneumoniae in children with acute otitis media in Spain. Pediatr Infect Dis J. 1998;17:94-7. [pmid: 9493802].
Del Castillo F, Corretger JM, Medina J, et al. Acute otitis media in childhood: A study of 20,532 cases. Infection. 1995;23:S70-3. [pmid: 8537135].
Del Mar C, Glasziou P, Hayem M. Are antibiotics indicated as initial treatment for children with acute otitis media? A meta-analysis. BMJ. 1997 May 24;314:1526-9.
DerSimonian R. and Laird N. Meta-analysis in clinical trial. Control Clin Trials. 1986;7:177-88. [pmid: 3802833].
Detsky AS, Naglie JG. A clinician's guide to cost-effectiveness analysis. Ann Intern Med. 1990;113:147-54. [pmid: 2113784].
Di Muro R. Clarithromycin in the treatment of acute otitis media with effusion. Clinical experiences and results. Otorinolaringologia. 1992;42:393-6.
Diachuk VV. [Clinical evaluation of the microflora in acute otitis media and otoantritis in nursing infants]. Zh Ushn Nos Gorl Bolez. 1977:45-9.
Diamant M, Diamant B. Abuse and timing of use of antibiotics in acute otitis media. Arch Otolaryngol. 1974;100:226-32. [pmid: 4850379].
Dominguez Rovira S, Mainou Cid C, Claros Blanch A, et al. [Clinical and microbiological study of otitis media in infants.]. An Esp Pediatr. 1996;44:341-4. [pmid: 8849084].
Dosdegani R, Bignoli L, Bombelli G, et al. Cefatrizine in the treatment of ENT infective diseases. Rivista Italiana di Otorinolaringologia Audiologia e Foniatria. 1988;8:193-6.
Douglass CC. Nitrofurazone in the treatment of bacterial ear infections: Re-evaluation after twenty years. Laryngoscope. 1970;80:400-8. [pmid: 5436960].
Dowell SF, Butler JC, Giebink GS, et al. Acute otitis media: Management and surveillance in an era of pneumococcal resistance -- a report from the drug-resistant Streptococcus pneumoniae Therapeutic Working Group. Pediatr Infect Dis J. 1999;18:1-9. [pmid: 9951971].
Dowell SF, Marcy SM, Phillips WR, et al Principles of judicious use of antimicrobial agents for pediatric upper respiratory tract infections Pediatr 1998 101(1, suppl):163 5
Dragneva MK. [Preceding antibiotic therapy and inflammation of the middle ear in infants]. Zhu Ushn Noso Gorl Bolez 1977:77-81.
Dragneva MK, Stovbun FI, Shevrygin BV. [Role of infection in the development of middle ear inflammation in nursing infants 1st treated with antibiotics. ] Vestn Otorinolaringol 1981:31-4.
Dugdale AE, Canty A, Lewis AN, et al. The natural history of chronic middle ear disease in Australian Aboriginals: A cross-sectional study. Med J Aust. 1978;1:6-8.
Dupuis G, Ebbo D, Evennou A, et al [Efficacy and tolerability of cefuroxime-axetil in infections of the upper respiratory tract: Comparative study with cefadroxil.] Rev Laryngol Otol Rhinol 1989 110(1):123 6
Dusdieker LB, Murph JR, Booth BM, et al Once-a-day antibiotic dosing in children with acute suppurative otitis media. Twenty Sixth annual meeting of the ambulatory pediatric association Am J Dis Child 1986 140(40):
Egerton JR. An evaluation of cyclacillin in the treatment of upper respiratory tract infections, otitis media, skin and soft tissue infections. Adv Ther. 1985;2:49-52.
Elies W. Local chemotherapy of selected bacterial infections of the ear. J Antimicrob Chemother. 1990;26:303-5. [pmid: 2228822].
Engelhard D, Cohen D, Strauss N, et al. Randomised study of myringotomy, amoxycillin/clavulanate, or both for acute otitis media in infants. Lancet. 1989;2:141-3. [pmid: 2567903].
Eto A, Kawamura S, Ichikawa G, et al. Clinical study on S-1108 in the field of otorhinolaryngology. Chemotherapy. 1993;41:931-5.
Evangelista P, Valigi F. Evaluation of the clinical efficacy and tolerability of lincomycin in the treatment of bacterial infections in the upper respiratory ways and middle ear. Otolaringologia. 1984;34:167-9.
Fabiani M, Baretti F. Methoxybutropate vs feprazone in acute and subacute upper respiratory diseases. Otolaringologia. 1990;40:233-9.
Faden H, Duffy L, Wasielewski R, et al. Natural history of otitis media (OM) in young children. Pediatr Res 1996;39.
Fauskin G. Acute otitis media in early infancy. Recurrence and prophylaxis. Acta Paediatr Scand. 1991;80:418-22. [pmid: 2058390].
Feder HM Jr. Comparative tolerability of ampicillin, amoxicillin, and trimethoprim-sulfamethoxazole suspensions in children with otitis media. Antimicrob Agents Chemothe. 1982;21:426-7.
Federspil P, Bach R. [Antibiotic therapy of infections involving throat, nose and ears]. Z Allgemeinmed. 1980;56:2331-48.
Federspil P, Koch J. Double-blind comparative trial of trimethoprim/sulfamethopyrazine once daily vs erythromycin 4 X daily in patients with ENT infections. Int J Clin Pharmacol Ther Toxicol. 1983;21:535-9. [pmid: 6358058].
Feigin RD, Keeney RE, Nusrala J, et al. Efficacy of clindamycin therapy for otitis media. Arch Otolaryngol. 1973;98:27-31. [pmid: 4145912].
Feigin RD, Shackelford PG, Campbell J, et al. Assessment of the role of Staphylococcus epidermidis as a cause of otitis media. Pediatrics. 1973;52:569-76. [pmid: 4742252].
Feinauer LR Jr, Lynch CL, Matsen J, et al Cefaclor in supportive otitis media. 40th annual national meeting of the American Federation for Clinical Research Clin Res 1983 31(2):
Feinauer LR, Jr, Matsen JM Comparative study of amoxicillin with cefaclor in suppurative otitis media. Annual Meeting of the Western Society for Pediatric Research Clin Res 1982 30(1):
Feldman S, Doolittle M, Lott L, et al. Similar hematologic changes in children receiving trimethoprim-sulfamethoxazole or amoxicillin for otitis media. J Pediatr. 1985;106:995-1000. [pmid: 3889261].
Feldman W, Momy J, Dulberg C. Trimethoprim-sulfamethoxazole v. amoxicillin in the treatment of acute otitis media. CMAJ. 1988;139:961-4. [pmid: 3052769]. [pmcid: 1268389].
Feldman W, Richardson H, Rennie B, et al. A trial comparing cefaclor with co-trimoxazole in the treatment of acute otitis media. Arch Dis Child. 1982;57:594-6. [pmid: 7051985].
Feldman W, Sutcliffe T, Dulberg C Twice-daily antibiotics in the treatment of acute otitis media: trimethoprim-sulfamethoxazole versus amoxicillin-clavulanate CMAJ 1990 142(2):115 8 2403833 1451732
Ferber T. Cefetamet pivoxil - an oral cephalosporin of the third generation. Ars Medici. 1993;83:858-61.
Fernandez MacLoughlin GJ. Clinical assessment of activity of the propionate of erythromycin in acute otorhinolaryngologic infections in children. Prensa Medica Argentina. 1982;69:833-5.
Fernandez MacLoughlin GJ, Gomez Barreto DG, De la Torre C, et al. Cefpodoxime proxetil suspension compared with cefaclor suspension for treatment of acute otitis media in paediatric patients. J Antimicrob Chemother. 1996;37:565-73. [pmid: 9182113].
Ficnar B, Huzjak N, Oreskovic K, et al. Azithromycin: 3-day versus 5-day course in the treatment of respiratory tract infections in children. J Chemother. 1997;9:38-43.
Fior R, Zocconi E, Tamburini P, et al. The association amoxicillin clavulanic acid in the management of bacterial infections of the middle ear and paranasal sinuses in pediatric age. Rivista Italiana di Otorinolaringologia Audiologia e Foniatria. 1989;9:84-7.
Fletcher RH, Fletcher SW, Wagner EH. Clinical epidemiology -- the essentials. Baltimore: Williams & Wilkins, 1982.
Fliss DM, Krauss M, Gorodischer R, et al. [Cefaclor and trimethoprim-sulfamethoxazole for recurrent otitis media]. Harefuah. 1989;117:361-3. [pmid: 2695415].
Fliss DM, Leiberman A, Dagan R. Medical sequelae and complications of acute otitis media. Pediatr Infect Dis J. 1994;13:S34-40. [pmid: 8159513].
Ford KL, Mason EO, Jr., Kaplan SL, et al. Factors associated with middle ear isolates of Streptococcus pneumoniae resistant to penicillin in a children's hospital. J Pediatr. 1991;119:941-4. [pmid: 1960612].
Forer M, Murtagh J. Acute otitis media. Aust Fam Physician. 1992;21:1667-8. [pmid: 1445004].
Forer M, Murtagh J. Acute otitis media. Aust Fam Physician. 1995;24:2093-7. [pmid: 8579546].
Forquer BD, Linthicum FH, Jr. Middle ear effusion in children: A report of treatment in 500 cases. West J Med. 1982;137:370-4. [pmid: 6184891]. [pmcid: 1274151].
Forsch RT. Short-course antibiotics for acute otitis media. J Fam Pract. 1998;47:173-4. [pmid: 9752364].
Foshee WS. Loracarbef versus amoxicillin-clavulanate in the treatment of acute otitis media with effusion. The 31st interscience conference on antimicrobial agents and chemotherapy, 1991:199.
Foshee WS. Loracarbef (LY163892) versus amoxicillin-clavulanate in the treatment of bacterial acute otitis media with effusion. J Pediatr. 1992;120:980-6. [pmid: 1593361].
Foshee WS, Qvarnberg Y. Comparative United States and European trials of loracarbef in the treatment of acute otitis media. Pediatr Infect Dis J. 1992;11:S12-9. [pmid: 1513607].
Franzetti M, Reali E, Felisati D, et al. Cefaclor compared with amoxicillin in the treatment of acute otitis media of infants and children. Riv Ital Pediatr. 1982;8:297-300.
Freche C, Leveque B, Monnet P. Treatment of upper respiratory tract infections and otitis media with cefaclor and cephalexin: results of a multicenter comparative study. Curr Ther Res. 1981;30:1116-20.
Freijd A, Bygdeman S, Rynnel-Dagoo B. The nasopharyngeal microflora of otitis-prone children, with emphasis on H. influenzae. Acta Otolaryngol. 1984;97:117-26.
Freijd A, Rynnel-Dagoo B. Isolation of nasopharyngeal beta-lactamase producing Haemophilus influenzae, in relation to antibiotic treatment of acute otitis media in infants. Acta Otolaryngol. 1983;95:351-7. [pmid: 6404124].
Fried VM. Ambulatory health care visits by children: principal diagnosis and place of visit. National Center for Health Statistics. Vital Health Stat 13 (137). Hyattsville MD: U.S. Department of Health and Human Services, 1998.
Friedmann I. The pathology of acute and chronic infections of the middle ear cleft. Ann Otol Rhinol Laryngol. 1971;80:391-6. [pmid: 4996151].
Friese KH, Kruse S, Moeller H. Otitis media in children. A comparison of conventional and homeopathic drugs. HNO. 1996;44:462-6. [pmid: 8805013].
Friese KH, Kruse S, Ludtke R, et al. The homoeopathic treatment of otitis media in children-comparisons with conventional therapy. Int J Clin Pharmacol Ther. 1997;35:296-301. [pmid: 9247843].
Friis H. Penicillin versus ampicillin. Ugeskr Laeger. 1987;149:535-8. [pmid: 3824655].
Froehle RM. Ear infection: A retrospective study examining improvement from chiropractic care and analyzing for influencing factors. J Manipulative Physiol Ther. 1996;19:169-77. [pmid: 8728460].
Froom J, Culpepper L, Bridges-Webb C, et al. Effect of patient characteristics and disease manifestations on the outcome of acute otitis media at 2 months. Arch Fam Med. 1993;2:841-6. [pmid: 8111513].
Froom J, Culpepper L, Grob P, et al. Diagnosis and antibiotic treatment of acute otitis media: report from International Primary Care Network. BMJ. 1990;300:582-6. [pmid: 2108756]. [pmcid: 1662354].
Froom J, Culpepper L, Jacobs, M et al Antimicrobials for acute otitis media? A review from the International Primary Care Network." BMJ 1997 315(7100):98 102 9240050
Fry J. Antibiotics in acute tonsillitis and acute otitis media. BMJ. 1958;2:883-6. [pmid: 13572934].
Fry J. Acute otitis media in general practice. Proceedings of the Royal Society of Medicine. 1970;63:741-2. [pmid: 5434232]. [pmcid: 1811490].
Fujimaki Y, Kawamura S, Sugita R, et al. Effect of lincomycin hydrochloride in otorhinolaryngological infections. Evaluation of LCM in anaerobic infections. Pract Otol. 1985;78:1651-62.
Fukami K, Furuta S, Fukuda K, et al. Basic and clinical studies on CS-807 in infections in the otorhinolaryngological field. Chemotherapy. 1988;36:1067-73.
Furman S, Berkowicz L, Dippenaar J, et al. Cefetamet pivoxil vs cefaclor in the treatment of acute otitis media in children. Drugs. 1994;47:21-6.
Furuta S, Yamamoto M, Ohyama M. Clinical effects of MOM tablets on otorhinolaryngological infections. Oto Rhino Laryngology Tokyo. 1980;23.
Furuta S, Fukuda K, Ohhori Y, et al. Basic and clinical studies on cefsulodin for the otorhinolaryngological infections. Jpn J Antibiot. 1982;35:2844-50. [pmid: 7182540].
Furuta S, Yamamoto M, Ohyama M. Clinical effects of MOM tablets on otorhinolaryngological infections. Oto Rhino Laryngology Tokyo. 1980;23.
Fyllingen G, Arnesen AR, Ronnevig J. Phenoxymethylpenicillin two or three times daily in bacterial upper respiratory tract infections: A blinded, randomized and controlled clinical study. Scand J Infect Dis. 1991;23:755-61. [pmid: 1815339].
Galetti G, Martini A, Bergamini G, et al. Efficacy and tolerability of brodimoprim in bacterial otitis media in children. Controlled study versus cefaclor. J Chemother. 1993;5:551-5. [pmid: 8195856].
Galland A, Debray H. Clinical study on augmentin in the treatment of urinary tract infection and otorhinolaryngological infections in children. Chemioterapia 1982;1.
Gan VN, Kusmiesz H, Shelton S, et al. Comparative evaluation of loracarbef and amoxicillin-clavulanate for acute otitis media. Antimicrob Agents Chemother. 1991;35:967-71. [pmcid: 245137]. [pmid: 1854178].
Gananca MM, Caovilla HH, Nunes CTA, et al. Therapeutic effect of benzydamine hydrochloride liquid and diclofenac resinate drops in the acute otitis media in the childhood. Rev Bras Med. 1989;46:22-24.
Gananca MM, Mangabeira Albernaz PL, Ueda HK, et al. Econazole in the treatment of acute or reacutized chronic otitis media. Acta-A WHO. 1984;3:67-9.
Ganiats TG, Schneiderman LJ. Principles of cost-effectiveness research. J Fam Pract. 1988;27:77-84. [pmid: 3134508].
Ganz H. [Complications of the acute otitis media in the antibiotic drug era.]. HNO. 1967;15:174-7. [pmid: 5186935].
Gastpar H, Danner H. The efficacy and tolerance of cefuroxime-axetil. Therapiewoche. 1990;40:2861-7.
Gastpar H, Smit R, Schlenter W. Rapid help for children with acute otitis media. TW Padiatrie. 1995;8:531-4.
Gastpar H, Smit R, Schlenter W. Successful treatment of childhood otitis media with the new cephalosporin cefetamet pivoxil. Therapiewoche. 1995;45:1834-7.
Gates GA. Cost-effectiveness considerations in otitis media treatment. In: Lim D, Bluestone CD, Casselbrant M, Klein J, Ogra P, eds. Proceedings of the sixth international symposium: Recent advances in otitis media, 1996a:1-40.
Gates GA. Cost-effectiveness considerations in otitis media treatment. Otolaryngol Head Neck Surg. 1996b;114:525-30. [pmid: 8643261].
Gebhart DE. Tympanostomy tubes in the otitis prone child. Laryngoscope. 1981;91:849-66. [pmid: 7017311].
Gehanno P, Barry B, Bobin S, et al. Twice daily cefpodoxime proxetil compared with thrice daily amoxicillin/clavulanic acid for treatment of acute otitis media in children. Scand J Infect Dis. 1994;26:577-84. [pmid: 7855555].
Gehanno P, Berche P, Boucot I, et al. Comparative efficacy and safety of cefprozil and amoxycillin/clavulanate in the treatment of acute otitis media in children. J Antimicrob Chemother. 1994;33:1209-18. [pmid: 7928814].
Gehanno P, Berche P, Lambert Zechovsky N, et al. A comparison of cefprozil to amoxicillin clavulanate in the treatment of acute otitis media in children. The 31st interscience conference on antimicrobial agents and chemotherapy, 1991:202.
Gehanno P, Berche P, N'Guyen L, et al. Resolution of clinical failure in acute otitis media confirmed by in vivo bacterial eradication: Efficacy and safety of ceftriaxone injected once daily, for 3 days. Abstracts of the interscience conference on antimicrobial agents the chemotherapy. 1997:372.
Gehanno P, Boucot I, Lenoir G, et al. Impact of penicillin-resistant streptococcus pneumoniae on the efficacy of cefuroxime axetil for the treatment of acute otitis media in children. Abstracts of the 34th interscience conference on antimicrobial aAgents and chemotherapy, 1994:259.
Gehanno P, De Pondt J, Barry B, et al. Cefpodoxime proxetil CPD vs. amoxicillin-clavulanic acid AMC in children suffering from acute otitis media ACM. The 32nd interscience conference on antimicrobial agents and chemotherapy; 1992:391.
Gehanno P, N'Guyen L, Derriennic M, et al. Pathogens isolated during treatment failures in otitis. Pediatr Infect Dis J. 1998;17:885-90. [pmid: 9802629].
Gehanno P, Taillebe M, Denis P, et al. Short-course cefotaxime compared with five-day co-amoxyclav in acute otitis media in children. J Antimicrob Chemother. 1990;26:29-36.
Giebink GS, Batalden PB, Russ JN, Le CT Cefaclor v amoxicillin in treatment of acute otitis media Am J Dis Child 1984 138(3):287 92 6367432
Glass RI, Lew JF, Gangarosa RE, LeBaron CW, Ho M-S. Estimates of the morbidity and mortality from diarrheal diseases in American children. J Pediatr. 1991;118:S27-33. [pmid: 2007954].
Godfrey AAC, Keenan TD, Summerfield M. Trimet v amoxycillin in the treatement of otitis media in children. N Z Med J. 1985;98.
Going JA, Ervin DM. Otitis media: When are tubes and/or adenoidectomy needed?. JSC Med Assoc. 1994;90:483-4.
Gold, MR, Patrick GW, Torrance DL, et al. Identifying and valuing outcomes. In: Gold MR, Siegel GE, Russell LB, Weinstein MC, eds. Cost-effectiveness in health and medicine. New York: Oxford University Press, 1996. p. 82-134.
Goldstein F, Bryskier AB, Appelbaum PC, et al. The etiology of respiratory tract infections and the antibacterial activity of fluoroquinolones and other oral antibacterial agents against respiratory pathogens. Clin Microbiol Infect. 1998;4:2S8-18.
Gomez JR, Gomez G. Comparative trial of erythromycin and tetracycline in common infections found in general practice. Br J Clin Pract. 1968;22:475-7. [pmid: 4880249].
Gonzalez C, Arnold JE, Woody EA, et al. Prevention of recurrent acute otitis media: Chemoprophylaxis versus tympanostomy tubes Laryngoscope. 1986;96:1330-4.
Gonzalez ML (ed). Socioeconomic aspects of medical practice 1996. Chicago: American Medical Association; 1996.
Gooch WM, 3rd, Blair E, Puopolo A, et al. Clinical comparison of cefuroxime axetil suspension and amoxicillin/clavulanate suspension in the treatment of pediatric patients with acute otitis media with effusion. Clin Ther. 1995;17:838-51. [pmid: 8595636].
Gooch WM, 3rd, Blair E, Puopolo A, et al. Effectiveness of five days of therapy with cefuroxime axetil suspension for treatment of acute otitis media. Pediatr Infect Dis J. 1996;15:157-64. [pmid: 8822290].
Gooch WM, 3rd, Gan VN, Corder WT, et al. Clarithromycin and cefaclor suspensions in the treatment of acute otitis media in children. Pediatr Infect Dis J. 1993;12:S128-33. [pmid: 8295814].
Gooch WM, 3rd, Philips A, Rhoades R, et al. Comparison of the efficacy, safety and acceptability of cefixime and amoxicillin/clavulanate in acute otitis media. Pediatr Infect Dis J. 1997;16:S21-4. [pmid: 9041624].
Graham-Zapata LF. Efficacy and safety of cefpodoxime proxetil (8 mg/kg/day) for 5 days vs. amoxicillin/clavulanic acid (40 mg/kg/day) for 8 days in the treatment of acute otitis media in children. Abstracts of the interscience conference on antimicrobial agents and hemotherapy 1997:370.
Gray BM, Converse GM, Dillon HC. Further studies on the natural history of pneumococcal infections in children. Clin Res 1978;26.
Green SDR. Ten years of pediatric experience with ciprofloxacin. Infect Dis Clin Pract. 1998;7:S175-83.
Green SM, Rothrock SG Single-dose intramuscular ceftriaxone for acute otitis media in children Pediatrics 1993 91(1):23 30 8416502
Gudnason T, Sigurdardottir LY, Kristinsson KG, et al. One dose ceftriaxone treatment of otitis media caused by multi-resistant pneumococci. Abstracts of the 36th interscience conference on antimicrobial agents and chemotherapy, 1996:284.
Guggenbichler JP, Titz B, Lysy G. Treatment of acute otitis media: Comparison between cefixime and cefaclor. J Drug Dev Suppl. 1993;6:23-5.
Gutierrez E, Cuervo E. Efficiency and safety of sultamicillin compared with cefaclor in the treatment of acute otitis media in children. Int Pediatr. 1996;11:38-40.
Haggard MP and Smith SC. Impact of otitis media on child quality of life. In: Lim DJ, Bluestone CD, directors. Abstracts of the the 7th international symposium on recent advances in otitis media, 1999a:7.
Haggard MP and Smith SC. Impact of otitis media on child quality of life. In: Rosenfeld RM, Bluestone CD, eds. Evidence-based otitis media. Saint Louis, BC: Decker Inc.; 1999b:375-98.
Haines ST, Kraynak MA. Twice-daily cefaclor therapy. Ann Pharmacother. 1994;28:1353-5. [pmid: 7696725].
Hall MJ, Lawrence L. Ambulatory surgery in the United States, 1995. Advance data from vital and health statistics; no. 296. Hyattsville MD: National Center for Health Statistics. 1997; PHS Publication No. 98-1250 8-0144.
Halsted C, Lepow ML, Balassanian N, et al Otitis media: microbiology and evaluation of therapy Ann NY Acad Sci 1967 145(2):372 8 4397881
Halsted C, Lepow ML, Balassanian N, et al. Otitis media. Clinical observations, microbiology, and evaluation of therapy. Am J Dis Child. 1968;115:542-51. [pmid: 4384577].
Hamed M, Haroon A, Rifaie A, et al. A bacteriological study in cases of acute otitis media in children and adults. J Egypt Public Health Assoc. 1979;54:415-24. [pmid: 399782].
Hanamure Y, Nobori T, Katsuda K, et al. Clinical study of AM-715 in the treatment for infectious diseases of otorhinolaryngology. Pract Otol. 1981;74:163-9.
Hansrod D, Howalder R, Rozar GJ. A clinical and bacteriological evaluation of augmentin: A new broad spectrum antibiotic in general practice. East Afr Med J. 1983;60:778-82. [pmid: 6368188].
Harada Y, Hirakawa K, Tagashira N, et al. Clinical studies of sparfloxacin against suppurative otitis media. Chemotherapy. 1991;39:670-80.
Harada Y, Hirakawa K, Yajin K, et al. A clinical evaluation of cefclidin in the otorhinolaryngological field. Chemotherapy. 1992;40:655-9.
Harada T, Seta N, Matsunaga T, et al. Basic and critical studies on loracarbef in otorhinolaryngological infections. Chemotherapy. 1993;41:467-73.
Haraguchi K, Miyazaki Y, Uchizono A, et al. Basic and clinical studies of loracarbef in infectious diseases in the otolaryngological field. Chemotherapy. 1993;41:474-82.
Harder H, Ohman L, Strand E. Early or late start of treatment in acute otitis media. A comparative study. Acta Otolaryngol Suppl. 1988;449:41-2. [pmid: 3144114].
Harrison CJ, Chartrand SA, Pichichero ME. Microbiologic and clinical aspects of a trial of once daily cefixime compared with twice daily cefaclor for treatment of acute otitis media in infants and children. Pediatr Infect Dis J. 1993;12:62-9. [pmid: 8417428].
Harrison CJ, Hedrick JA, Block SL, et al. Relation of the outcome of conjunctivitis and the conjunctivitis-otitis syndrome to identifiable risk factors and oral antimicrobial therapy. Pediatr Infect Dis J. 1987;6:536-40. [pmid: 3497379].
Harrison CJ, Marks MI, Welch DF. Microbiology of recently treated acute otitis media compared with previously untreated acute otitis media. Pediatr Infect Dis J. 1985;4:641-6.
Harsten G, Prellner K, Heldrup J, et al. Treatment failure in acute otitis media. A clinical study of children during their first three years of life. Acta Otolaryngol. 1989;108:253-8. [pmid: 2816339].
Harsten G, Prellner K, Lofgren B, et al. Serum antibodies against respiratory tract viruses in episodes of acute otitis media. J Laryngol Otol. 1991;105:337-40. [pmid: 1645761].
Hathaway TJ, Katz HP, Dershewitz RA, et al. Acute otitis media: Who needs posttreatment follow-up?. Pediatrics. 1994;94:143-7. [pmid: 8036064].
Hauch AM, Sorensen H. [Acute mastoiditis. Occurrence in relation to the antibiotic treatment of acute otitis media]. Ugeskr Laeger. 1986;148:388-91. [pmid: 3952876].
Hayden, GF. Acute Suppurative Otitis Media in Children: Diversity of Clinical Diagnostic Criteria. Clin Pediatr. 1981;20:99-104.
Hebblethwaite EM, Brown GW, Cox DM. A comparison of the efficacy and safety of cefuroxime axetil and augmentin in the treatment of upper respiratory tract infections. Drugs Exp Clin Res. 1987;13:91-4. [pmid: 3582135].
Heikkinen T, Ruuskanen O, Waris M et al Influenza vaccination in the prevention of acute otitis media in children Am J Dis Child 1991 145(4):445 8 1849344
Helwig H, Luechtrath M, Hostalek U. Efficacy and safety of cefixime once daily compared to twice daily in otitis media, URTI and LRTI in children. J Drug Dev. 1993;6:27-9.
Hendrickse WA, Kusmiesz H, Shelton S, Nelson JD Five vs. ten days of therapy for acute otitis media Pediatr Infect Dis J 1988 7(1):14 23 3277153
Herz G. Respiratory infections in children: When is brodimoprim indicated?. J Chemother. 1993;5:556-61. [pmid: 8195857].
Hirota J, Watanabe S, Tsurumaru H, et al. Cefdinir in otorhinolaryngology. Chemotherapy. 1989;37:1087-95.
Hirschmann JV. Methods for decreasing antibiotic use in otitis media. Lancet. 1998;352.
Hoberman A, Paradise JL, Block S, et al. Efficacy of amoxicillin/clavulanate for acute otitis media: Relation to Streptococcus pneumoniae susceptibility. Pediatr Infect Dis J. 1996;15:955-62. [pmid: 8895940].
Hoberman A, Paradise JL, Burch DJ, et al Equivalent efficacy and reduced occurrence of diarrhea from a new formulation of amoxicillin/clavulanate potassium (Augmentin) for treatment of acute otitis media in children Pediatr Infect Dis J 1997 16(5):463 70 9154538
Hoberman A, Paradise JL, Reynolds EA et al Efficacy of Auralgan for treating ear pain in children with acute otitis media Arch Pediatr Adolesc Med 1997 151(7):675 8 9232040
Hoffman WH. Treatment of Hemophilus influenzae otitis media. J Pediatr. 1970;76.
Holborow C, McPherson B. Simple treatment for the infected ear. Trop Doct. 1986;16:31-2. [pmid: 3765064].
Hondoh J, Baba S, Wada K, et al. Laboratory and clinical studies on netilmicin in otorhinolaryngological field. Chemotherapy 1981;29.
Hopkins S. Clinical safety and tolerance of azithromycin in children. J Antimicrob Chemother 1993; 31 Suppl:111-7.
Horev Z, Cohen A. Comparison of the efficacy and safety of amoxycillin/clavulanate given once daily vs. three times daily in the treatment of acute otitis media. Pediatr Res 1997;41.
Howard JE, Nelson JD, Clahsen J, et al. Otitis media of infancy and early childhood. A double-blind study of four treatment regimens. Am J Dis Child. 1976;130:965-70. [pmid: 8980].
Howard JE, Nelson JD, Clahsen J, et al. Otitis media of infancy and early childhood. A double-blind study of four treatment regimens. Curr Ther. 1977;18.
Howie VM. Natural history of otitis media. Ann Otol Rhinol Laryngol. 1975;84:67-72. [pmid: 1093478].
Howie VM, Dillard R, Lawrence B In vivo sensitivity test in otitis media: efficacy of antibiotics Pediatrics 1985 75(1):8 13 3871251
Howie VM, Owen MJ. Bacteriologic and clinical efficacy of cefixime compared with amoxicillin in acute otitis media. Pediatr Infect Dis J. 1987;6:989-91. [pmid: 3696839].
Howie V, Owen M, Pohl J. Bacteriologic and clinical efficacy of ceftriaxone in treatment of acute otitis media (AOM). J Investig Med 1995;43.
Howie VM, Ploussard JH. The "in vivo sensitivity test"-bacteriology of middle ear exudate, during antimicrobial therapy in otitis media. Pediatrics. 1969;44:940-4. [pmid: 4391491].
Howie VM, Ploussard JH. Bacterial etiology and antimicrobial treatment of exudative otitis media: Relation of antibiotic therapy to relapses. South Med J. 1971;64:233-9. [pmid: 5313487].
Howie VM, Ploussard JH Efficacy of fixed combination antibiotics versus separate components in otitis media. Effectiveness of erythromycin estrolate, triple sulfonamide, ampicillin, erythromycin estolate triple sulfonamide, and placebo in 280 patients with acute otitis media under two and one-half years of age Clin Pediatr 1972 11(4):205 14
Howie VM, Ploussard JH, Sloyer J Comparison of ampicillin and amoxicillin in the treatment of otitis media in children J Infect Dis 1974 129suppl:S181 4 4152132
Howie VM, Schwartz RH. Acute otitis media: one year in general pediatric practice. Am J Dis Child. 1983;137:155-8. [pmid: 6681578].
Hueston WJ, Ornstein S, Jenkins RG, et al. Treatment of recurrent otitis media after a previous treatment failure. Which antibiotics work best?. J Fam Pract. 1999;48:43-6. [pmid: 9934382].
Hyams JS, Feder H, Jr., Krause PJ, et al. Occurrence of clostridium difficile toxin-associated gastroenteritis following antibiotic therapy for otitis media in young children. Pediatr Infect Dis J. 1984;3:433-6.
Ingvarsson L, Lundgren K. The duration of penicillin treatment of acute otitis media in children. Transactions of the 21st Congress of the Scandinavian Oto Laryngological Society, 1981:112-4.
Ingvarsson L, Lundgren K Penicillin treatment of acute otitis media in children. A study of the duration of treatment Acta Otolaryngol 1982 94(3-4):283 7 6816006
Ionescu N. [Critical study of antibiotic therapy of auricular suppurations]. Otorinolaringologie. 1969;14:331-7. [pmid: 5378797].
Ishii T, Takayama M, Unno T, et al. Phase III clinical study of levofloxacin in otitis media and otitis externa. Chemotherapy. 1992;40:334-51.
Iwai N, Taneda Y, Nakamura H, et al. Pharmacokinetic, bacteriological and clinical evaluation of cefpodoxime proxetil in pediatrics. Jpn J Antibiot. 1989;42:1571-92. [pmid: 2810731].
Iwasawa T. [Media by means of terra-cortril ear drops]. Jibiinkoka. 1965;37:1117-24. [pmid: 5893338].
Iwasawa T. [The effect of colimycin F ear-drops in treatment of purulent otitis media]. Jibiinkoka. 1965;37:1211-9. [pmid: 5895555].
Iwasawa T. [The broad-spectrum antibiotic gentamicin for local application in the treatment of purulent otitis media]. Jibiinkoka. 1968;40:901-11. [pmid: 4975538].
Iwasawa T. Fundamental and clinical studies on cefmenoxime (SCE-1365) in the otorhinolaryngologic field. Chemotherapy 1981;29.
Iwasawa T. Fundamental and clinical studies on cefotetan (YM09330) in the otorhinolaryngologic field. Chemotherapy 1982;30.
Jacobs MR. Increasing importance of antibiotic-resistant Streptococcus pneumoniae in acute otitis media. Pediatr Infect Dis J. 1996;15:940-3. [pmid: 8895938].
Jacobson JA, Metcalf TJ, Parkin JL, et al Evaluation of cefaclor and amoxycillin in the treatment of acute otitis media Postgrad Med J 1979 55(Suppl 4):39 41
Jacobsson S, Rigner P, von Sydow C, et al. Clinical and bacteriological efficacy of amoxycillin/clavulanate (Spektramox) and cefaclor (Kefolor) in children with recurrent AOM or therapy failure. Acta Otolaryngol Suppl. 1988;449:43-4. [pmid: 3201955].
Jacobsson S, Fogh A, Larsson P, et al. Evaluation of amoxicillin clavulanate twice daily versus thrice daily in the treatment of otitis media in children. Danish-Swedish Study Group. Eur J Clin Microbiol Infect Dis. 1993;12:319-24. [pmid: 8354296].
Jacobsson S, Rigner P, von Sydow C, et al. Recurrent and penicillin V-resistant otitis media. A treatment study with amoxycillin/clavulanate and cefaclor. Acta Otolaryngol. 1988;106:171-7. [pmid: 3140574].
Jadad AR, Moore AR, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17:1-12. [pmid: 8721797].
Jenner PN, Tierney HE, Carle WK. A general practice study of a new approach to the use of antibiotics in the treatment of acute otitis media in children aged three and over. Br J Clin Pract. 1987;41:820-6. [pmid: 3446282].
Jensen W. Drug treatment of otitis media. S D J Med. 1997;50:137-8. [pmid: 9136263].
Jeppsson P, Nylen O, Liden G. Audiological aspects of acute otitis media. Acta Otolaryngol. 1973;75:439-42. [pmid: 4125920].
Jero J, Virolainen A, Virtanen M, et al. Prognosis of acute otitis media: factors associated with poor outcome. Acta Otolaryngol. 1997;117:278-83. [pmid: 9105466].
John WR, Valle-Jones JC. Treatment of otitis media in children. A comparison between cefaclor and amoxycillin. Practitioner. 1983;227:1805-9. [pmid: 6361721].
Johnson CE, Carlin SA, Super DM, et al Cefixime compared with amoxicillin for treatment of acute otitis media J Pediatrics 1991 119(1 (Pt 1)):117 22
Johnson HW. Twice daily treatment with cephradine of infections in children. N C Med J. 1980;41:143-6. [pmid: 6929409].
Johnson SE, Foord RD. Cephalexin dosage in general practice assessed by double-blind trial. Curr Med Res Opin. 1972;1:37-48. [pmid: 4589401].
Jones JD Treatment of otitis media in pediatric practice: amoxicillin versus ampicillin J Infect Dis 1974 129suppl:S187 8 4152134
Jones R, Bain J. Three-day and seven-day treatment in acute otitis media: a double-blind antibiotic trial. J R Coll Gen Pract. 1986;36:356-8. [pmid: 3735223].
Juhn SK. Studies on middle ear effusions. Laryngoscope. 1982;92:287-91. [pmid: 7200175].
Juselius H, Kaltiokallio K. Complications of acute and chronic otitis media in the antibiotic era. Acta Otolaryngol. 1972;74:445-50. [pmid: 4656173].
Kafetzis DA. Multi-investigator evaluation of the efficacy and safety of cefprozil, amoxicillin-clavulanate, cefixime and cefaclor in the treatment of acute otitis media. Eur J Clin Microbiol Infect Dis. 1994;13:857-65. [pmid: 7889960].
Kafetzis DA, Astra H, Mitropoulos L. Five-day versus ten-day treatment of acute otitis media with cefprozil. Eur J Clin Microbiol Infect Dis. 1997;16:283-6. [pmid: 9177961].
Kafetzis DA, Malaka-Zafiriou C, Bairamis T, et al. Comparison of the efficacy and tolerability of clarithromycin suspension and cefuroxime axetil suspension in the treatment of acute otitis media in paediatric patients. Clin Drug Invest. 1997;14:192-9.
Kaleev, II. [The course of otitis in conditions of the tropical climate of Cuba]. Vestn Otorinolaringol. 1966;28.
Kaleida PH, Bluestone CD, Rockette HE, et al. Amoxicillin-clavulanate potassium compared with cefaclor for acute otitis media in infants and children [published erratum appears in Pediatr Infect Dis J 1987 Aug;6(8):734]. Pediatr Infect Dis J. 1987;6:265-71. [pmid: 3554125].
Kaleida PH, Casselbrant ML, Rockette HE, et al Amoxicillin or myringotomy or both for acute otitis media: results of a randomized clinical trial Pediatrics 1991 87(4):466 74 2011422
Kaleida PH and Stool SE. Assessment of otoscopists' accuracy regarding middle-ear effusion: otoscopic validation. Am J Dis Child. 1992;146:433-5. [pmid: 1558077].
Kammer RB. Cefaclor in management of streptococcal pharyngitis, otitis media, and skin infections. Ann Otol Rhino Laryngol Suppl. 1981;90:79-81.
Kanaya T, Unno T, Yoshida C, et al. Clinical study on TFLX in otorhinolaryngological infections. Pract Otorhinolaryngol. 1993;86:295-301.
Kangsanarak J, Navacharoen N, Fooanant S, et al. Intracranial complications of suppurative otitis media: 13 years' experience. Am J Otol. 1995;16:104-9. [pmid: 8579165].
Kaplan B, Wandstrat TL, Cunningham JR. Overall cost in the treatment of otitis media. Pediatr Infect Dis J. 1997;16:S9-11. [pmid: 9041621].
Kaprio E, Haapaniemi J, Bondesson G. Clinical efficacy of amoxycillin/clavulanic acid and cefaclor in acute otitis media. Acta Otolaryngol Suppl. 1988;449:45-6. [pmid: 3059751].
Kara CO, Ozuer MZ, Kilic I, et al Comparison of amoxicillin with second and third generation cephalosporins in the treatment of acute otitis media Infez Med 1998 6(2):93 5 12750572
Karabaev KE, Antoniv VF, Bekmuradov RU. [Pathogenetic validation of optimal antioxidant therapy in suppurative inflammatory otic diseases in children]. Vestn Otorinolaringol 1997:5-7.
Karma PH, Penttila MA, Sipila MM et al. Otoscopic diagnosis of middle ear effusion in acute and non-acute otitis media. I. The value of different otoscopic findings. Int J Pediatr Otorhinolaryngology. 1989;17:37-49.
Kawakami S, Yoneda T, Okada S, et al. Clinical studies of sultamicillin in the otorhinolaryngeal field. Chemotherapy 1985;33.
Kawamura S. Clinical studies on cefoperazone in otorhinolaryngological field. Jpn J Antibiot. 1980;33:1313-17. [pmid: 6454015].
Kawamura S. Clinical studies on fortimicin in otorhinolaryngological infections. Jpn J Antibiot. 1982;35:1391-4. [pmid: 7131764].
Kawamura S, Fujimaki Y, Iwasawa T, et al. A comparative double-blind study of Dl-8280 and pipemidic-acid in suppurative otitis media. Otologia Fukuoka. 1984;30:642-70.
Kawamura S, Horikawa H, Watanabe H, et al. A comparative double-blind study of T-2588 with cefaclor for the treatment of suppurative otitis media. Otologia Fukuoka. 1986;32:758-81.
Kawamura S, Ichikawa G, Itabashi T, et al. Fleroxacin in otorhinolaryngological infections. Chemotherapy. 1990;38:720-3.
Kawamura S, Ichikawa G, Watanabe I, et al. Fundamental and clinical studies on cefdinir in otorhinolaryngological infections. Chemotherapy. 1989;37:1043-52.
Kawamura S, Itabashi T, Wada M, et al. Comparative study of lomefloxacin NY-198 and pipemidic acid PPA in the treatment for suppurative otitis media. Otologia Fukuoka. 1989;35:434-57.
Kawamura S, Itabashi T, Watanabe H, et al. Comparative study of ciprofloxacin BAY-O-9867 and pipemidic acid in the treatment for suppurative otitis media. Otologia Fukuoka. 1987;33:100-25.
Kawamura S, Kimura Y. Clinical experience with cefadroxil in the treatment of acute tonsillitis and acute otitis media. Chemotherapy. 1980;28:476-9.
Kawamura S, Sugita R, Fujimaki T, et al. A randomized, controlled trial of bacampicillin vs. cephalexin in the treatment of acute purulent otitis media. Pract Otol (Kyoto). 1985;78:1147-65.
Kawamura S, Sugita R, Fujimaki Y, et al. Fundamental and clinical studies on BRL 25000, clavulanic acid amoxicillin, in the field of otorhinolaryngology. Jpn J Antibiot. 1983;36:500-8. [pmid: 6553606].
Kawamura S, Sugita R, Itabashi T, et al. Evaluation of sultamicillin in acute suppurative otitis media and acute exacerbation of chronic otitis media. A comparative double-blind study with cefaclor. Otologia Fukuoka. 1985;31:1023-46.
Kawamura S, Watanabe H, Itabashi T, et al. Cefetamet pivoxil in otorhinolaryngological infections. Chemotherapy. 1990;38:463-6.
Kawamura S. Clinical evaluation of TMS-19-Q. Gc tablet in suppurative otitis media a comparative double-blind study with midecamycin. Pract Otol (Kyoto). 1985;78:439-63.
Kenna MA, Bluestone CD, Fall P, et al. Cefixime vs. cefaclor in the treatment of acute otitis media in infants and children. Pediatr Infect Dis J. 1987;6:992-6. [pmid: 3696840].
Khurana C, McLinn S, Block S, et al Trial of azithromycin (AZ) vs augmentin (AUG) for treatment of acute otitis media (AOM) Abstracts of the 34th interscience conference on antimicrobial agents and chemotherapy 1994 34(0):
Khurana CM A multicenter, randomized, open label comparison of azithromycin and amoxicillin/clavulanate in acute otitis media among children attending day care or school Pediatr Infect Dis J 1996 15(9 Suppl):S24 9 8878243
Kikuchi N, Shoji H. The use of tobramycin in the treatment of suppurative otitis media. Otologia Fukuoka. 1978;24:674-6.
Kim HK, Bluestone CD, Blatter MM, et al. Comparison of bacampicillin and amoxicillin in acute otitis media with effusion. Bull N Y Acad Med. 1983;59:515-23. [pmid: 6349733].
Kimura Y, Aoyagi M, Ichige A, et al. A clinical study of the therapeutic effect of norfloxacin on acute and chronic otitis media. Pract Otol. 1990;83:495-501.
Kimura Y, Fuse T, Koike Y, et al. A clinical study of the therapeutic effect of TA-058 on infectious diseases in the field of otorhinolaryngology. Pract Otol. 1984;77:2575-84.
Kissling M, Germano G, Fernex M. Cefetamet pivoxil a new oral cephalosporin: Clinical evaluation. Chemotherapy. 1988;34:519-29. [pmid: 3243094].
Klaus JR, Ross MF, Knodel LC. New drug therapy: augmentin. J Pediatr Health Care. 1988;2:113-5. [pmid: 3258378].
Klein JO. Protecting the therapeutic advantage of antimicrobial agents used for otitis media. Pediatr Infect Dis J. 1998;17:571-5. [pmid: 9655563].
Klein JO. The "in vivo sensitivity test" for acute otitis media revisited. Pediatr Infect Dis J. 1998;17:774-5. [pmid: 9779759].
Klein JO, Bluestone CD. Acute otitis media. Pediatric Infect Dis. 1982;1:66-73.
Klein JO, Teele DW, Rosner M, et al Epidemiology of otitis media in Boston children observed from birth to 7 years of age Ann Otol Rhinol Laryngol 1990 149(Suppl):27 8
Kleinfeldt D, Reincke E. On the antibiotic therapy of acute otitis media. Dtsch. Gesundheitswes. 1978;33:807-9.
Klonowski S, Semczuk B, Burzynska A. [Evaluation of the results of conservative and surgical treatment of otitis media in children]. Pol Tyg Lek. 1967;22:135-7. [pmid: 6042958].
Koban A. Acute otitis media in infancy. Quick recovery by means of a combination therapy with penicillin g-sodium, procaine-penicillin g and benzathine-penicillin g. TW Padiatr. 1993;6.
Kobayashi Y, Morikawa Y, Haruta T, et al. Fundamental and clinical studies of cefaclor dry syrup in children. Chemotherapy 1979;27.
Koeppel FW. [Treatment of diseases of the ear canal and middle ear with Otobacid]. Munch Med Wochen Schrt. 1970;112:806-9.
Kos AO, Castro JC. Cotrimazina in the treatment of otorhinolaringologic infections. Folha Med. 1989;99:49-51.
Kossowska E, Chmielik M, Komorowska A, et al. [Sultamicillin in treatment of acute middle ear infection in children]. Pol Tyg Lek. 1993;48:9-10. [pmid: 8008666].
Kostyshin AT. [Experience in use of quinosol in certain otolaryngological diseases]. Zh Ushn Nos Gorl Bolezn. 1968;28:96-9. [pmid: 5738115].
Kozak LJ, Hall MJ, Pokras R, Lawrence L. Ambulatory surgery in the United States, 1994. Advance data from vital and health statistics, No. 283. Hyattsville, MD: National Center for Health Statistics, 1997.
Kozak LJ, Owings MF. Ambulatory and inpatient procedures in the United States, 1995. National Center for Health Statistics. Vital Health Stat 13 (139). Hyattsville, MD: U.S. Department of Health and Human Services, 1997.
Kozyrskyj AL, Hildes-Ripstein GE, Longstaffe SEA, et al Treatment of acute otitis media with a shortened course of antibiotics: A meta-analysis JAMA 1998 279(21):1736 42 9624028
Kubas G, Gospodarek T. [The use of clarithromycin and amoxycillin in pediatric acute otitis media]. Otolaryngol Pol. 1997;51:165-7. [pmid: 9757683].
Kubo M, Hamaguchi F, Inagaki M. A clinical study of norfloxacin in the treatment of otitis media. Practica Otol (Kyoto). 1989;82:1325-8.
Kukso C. Acute otorhinolaryngological infections in pediatric patients. Their management with a combination of ambroxol plus amoxicillin. Prensa Med Argent. 1986;73:216-22.
Kummer A. An open comparative random study with Brodimoprim (Reg.trademark) and doxycyclin in 46 patients affected with upper airway infections. Chemioterapia. 1982;1. No-153.
Kuriyama K. Evaluation of effectiveness of doxycycline in oto-laryngological infections. Oto Rhino Laryngology Tokyo. 1980;23.
Kuriyama K, Baba K, Shimizu M, et al. Clinical evaluation and the effect on host defense mechanism of ceftriaxone (Ro 13-9904) in otolaryngological infections. Chemotherapy 1984;32.
Lagace E. Antibiotic treatment for AOM. J Fam Pract. 1997;45:202-3. [pmid: 9312561].
Laird NM and Mosteller F. Some statistical methods for combining experimental results. Int J Technol Assess Health Care. 1990;6:5-30. [pmid: 2361819].
Lamb C. Otitis media: Selecting the therapy. Patient Care. 1983;17:108-10, 115, 119-20.
Lampe RM, Weir MR, McLeod HL, et al. A clinical trial of antihistamine, decongestant, or placebo in antibiotic-treated acute otitis media followed with pneumatic otoscopy and impedance tympanometry. Mil Med. 1981;146:259-61. [pmid: 6784022].
Lampe RM, Weir MR, McLeod H, et al. Tympanometry in acute otitis media: Prognostic implications. Am J Dis Child. 1981;135:233-5. [pmid: 6111216].
Landholt TF, Kotschwar TR. A pharmacoeconomic comparison of amoxicillin/clavulanate and cefpodoxime proxetil in the treatment of acute otitis media. Clin Ther. 1994;16:327-33. [pmid: 8062326].
Lanoel JL, McLaughlin GF, Stamboulian D. Amoxicillin-sulbactam in pediatric acute otitis media. Prensa Med Argent. 1989;76:235-7.
Lanoel JL, Steinberg S, McLaughlin GF, et al. Comparative study of cefaclor vs. amoxicillin in children with acute otitis media. Prensa Med Argent. 1992;79:459-62.
Laupacis A, Feeny D, Detsky AS, Tugwell PX. How attractive does a new technology have to be to warrant adoption and utilization? Tentative guidelines for using clinical and economic evaluations. Can Med Assoc J. 1992;146:473-81. [pmid: 1306034]. [pmcid: 1488412].
Laurencena E, Forti MJ. Roxithromycin in the treatment of acute otitis in children. Prensa Med Argent. 1992;79:577-9.
Laxdal OE, Merida J, Jones RH Treatment of acute otitis media: a controlled study of 142 children Can Med Assoc J 1970 102(3):263 8 4190002
Le Bideau M, Mouzard A, Chamoux C, et al. [Bacteriological study in acute otitis media]. Arch Pediatr. 1997;4:213-8. [pmid: 9181013].
Leach AJ, Boswell JB, Asche V, et al. Bacterial colonization of the nasopharynx predicts very early onset and persistence of otitis media in Australian aboriginal infants. Pediatr Infect Dis J. 1994;13:983-9. [pmid: 7845752].
Leigh AP, Robinson D, Millar ED A general practice comparative study of a new third-generation oral cephalosporin, cefixime, with amoxycillin in the treatment of acute paediatric otitis media Br J Clin Pract 1989 43(4):140 3 2686744
Lenoski EF, Wingert WA, Wehrle PF Drug trials in acute otitis media Curr Ther Res Clin Exp 1968 10(12):631 9 4972759
Leonardo VA, Castillo E, Antonio Acevedo M. Treatment of acute otitis media in children with erythromycin-sulfisoxazole. Invest Med Int. 1986;12:289-95.
Leveque B, Lambert-Zechovsky N, Cthlin C. Cefaclor in the treatment of upper respiratory tract bacterial infections in children. A comparative trial of cefaclor/cefalexin. Ann Pediatr (Paris). 1980;27:405-8. [pmcid: 358317]. [pmid: 7013629].
Levine LR. Quantitative comparison of adverse reactions to cefaclor vs. amoxicillin in a surveillance study. Pediatr Infect Dis. 1985;4:358-61. [pmid: 3161007].
Leysen DC, Haemers A. Fluoroquinolones in the treatment of suppurative otitis. Farmaceutisch Tijdschrift voor Belgie. 1989;66:217-8.
Liden M, Flodstrom A, Thore M. Treatment of early recurrences of acute purulent otitis media: Value of myringotomy. Acta Otolaryngol. 1988;106:441-7. [pmid: 3207009].
Lindeman HH. [Treatment of acute otitis]. Tidsskr Nor Laegeforen. 1976;96:42-4. [pmid: 1257953].
Lopes Filho O, Mimica I, Betti E, et al. Clinical and bacteriological efficacy of the association amoxicillin clavulanate potassium compared with cefaclor for acute otitis media in children. Folha Med. 1992;104:39-42.
Lopes FO. Amoxicillin versus amoxicillin + nimeulide in otolaryngologic infections - A randomized study. Folha Medica. 1991;102:81-5.
Lopes FO, Da SL, De MJC. Controlled randomized study of cefixime versus amoxicillin/clavulante in the treatment of acute otitis media. Folha Med. 1996;112:245-50.
Lopez JL, Novelo EG. An evaluation of the efficacy of ambroxol in the treatment of otitis media. Invest Med Int. 1989;16:55-9.
Lorentzen P, Haugsten P. [Treatment of acute suppurative otitis media. Paracentesis and/or antibiotics]. Tidsskr Nor Laegeforen. 1978;98:1273-5. [pmid: 754336].
Ludman H. Discharge from the ear: otitis externa and acute otitis media. Br Med J. 1980;281:1616-7. [pmid: 7448539]. [pmcid: 1715058].
Lundgren K, Ingvarsson L. Acute otitis media in Sweden. Role of Branhamella catarrhalis and the rationale for choice of antimicrobial therapy. Drugs. 1986;31:125-31. [pmid: 3488192].
MacLoughlin GJ, Barreto DG, de la Torre C, et al. Cefpodoxime proxetil suspension compared with cefaclor suspension for treatment of acute otitis media in paediatric patients. J Antimicrob Chemother. 1996;37:565-73. [pmid: 9182113].
Maeyama T, Furuta S, Moriyama I, et al. Fundamental and clinical studies on cefuroxime axetil (CXM-AX) in otorhinolaryngology field. Chemotherapy 1986;34.
Magit Anthony E, Dolitsky Jay N, Doyle William J, et al. An experimental study of cefixime in the treatment of Streptococcus pneumoniae otitis media. Int J Pediatr Otorhinolaryngol. 1994;29:1-9. [pmid: 8169042].
Majima Y, Saida S, Sakakura Y, et al. Clinical evaluation on cefclidin in the treatment of otorhinolaryngological infections. Chemotherapy. 1992;40:857-60.
Mamedov MZ. [Intratympanic application of hydrocortisone and penicillin in acute otitis media]. Voen Med Zh. 1971;2:72-3. [pmid: 5127296].
Mandel EM, Bluestone CD, Cantekin EI, et al. Comparison of cefaclor and amoxicillin for acute otitis media with effusion. Ann Otol Rhinol Laryngol Suppl. 1981;90:48-52. [pmid: 6791563].
Mandel EM, Bluestone CD, Rockette HE, et al. Duration of effusion after antibiotic treatment for acute otitis media: Comparison of cefaclor and amoxicillin. Pediatr Infect Dis J. 1982;1:310-6.
Mandel EM, Casselbrant ML, Rockette HE, et al. Efficacy of 20- versus 10-day antimicrobial treatment for acute otitis media. Pediatrics. 1995;96:5-13. [pmid: 7596722].
Mandel EM, Kardatzke D, Bluestone CD, et al. A comparative evaluation of cefaclor and amoxicillin in the treatment of acute otitis media. Pediatr Infect Dis J. 1993;12:726-32. [pmid: 8414799].
Marchant C, Shurin PA. Antibacterial therapy for acute otitis media: a critical analysis. Rev Infect Dis. 1982;4:506-13. [pmid: 7051243].
Marchant CD, Shurin PA, Johnson CE, et al. A randomized controlled trial of amoxicillin plus clavulanate compared with cefaclor for treatment of acute otitis media. J Pediatr. 1986;109:891-6. [pmid: 3534203].
Marchant CD, Shurin PA, Turcyzk VA, et al. A randomized controlled trial of cefaclor compared with trimethoprim-sulfamethoxazole for treatment of acute otitis media. J Pediatr. 1984;105:633-8. [pmid: 6384453].
Marchant CD, Shurin PA, Turczyk VA, et al. Course and outcome of otitis media in early infancy: A prospective study. J Pediatr. 1984;104:826-831. [pmid: 6539373].
Marchisio P, Marzano D, Sorella S, et al. Azithromycin compared with augmentin in the treatment of children with acute otitis media. International Congress Series, 1993:145-7.
Maresova V, Havlik J. Our experience with cefadroxil. Sb Lek. 1988;90:344-7. [pmid: 3217740].
Marks MI, Vose AD. Evaluation of amoxicillin therapy in ill children. J Clin Pharmacol. 1978;18:61-6. [pmid: 338647].
Markzitser AL. [Urea in the treatment of suppurative otitis media]. Zh Ushn Nos Gorl Bolezn. 1969;29.
Marone C, Quadri F. Beware of ciprofloxacin in acute otitis media. Br Med J. 1992;305.
Martin H, Martin C. [Clinical trial of polydexa in middle ear diseases]. JFORL. J Fr Otorhinolaryngol Audiophonoi Chir. 1975;24:157-61.
Marx J, Osguthorpe D, Parsons G. Day care and the incidence of otitis media in young children. Otolarygol Head Neck Surg. 1995;112:695-99.
Mawson S, Gray JD, Hewlett AB. Terramycin [oxytetracycline] in the treatment of acute otitis media in children. Br Med J. 1953;1:817-9. [pmid: 13032512].
McCarty JM, Deabate CA, Hofer JW, et al Trimethoprim (TMP) monotherapy vs. trimethoprim + sulfamethoxazole (TMP+SMX) combination therapy for the treatment of children with acute otitis media (AOM) Pediatr Res 1997 4(part2):
McCarty J, Good C, Renteria A, et al. Comparative safety and efficacy of clarithromycin (C) vs amoxicillin/clavulanate (A) or cefaclor (Cf) in the treatment of acute otitis media (AOM) in children. Program and abstracts of the 35^th^ interscience conference on antimicrobial agents and chemotherapy; 1995:334.
McCarty JM, Phillips A, Wiisanen R. Comparative safety and efficacy of clarithromycin and amoxicillin/clavulanate in the treatment of acute otitis media in children. Pediatr Infect Dis J. 1993;12:S122-7. [pmid: 8295813].
McCarty JM, Siepman N, Craft JC. Comparative safety and efficacy of clarithromycin versus amoxicillin/clavulanate in the treatment of acute otitis media in pediatric patients. Curr Ther Res Clin Exp. 1994;55:1016-26.
McCracken GH. Treatment of acute otitis media in an era of increasing microbial resistance. Pediatr Infect Dis J. 1998;17:576-9. [pmid: 9655564].
McGuinness BW, Cooper J, Kent PL. Trimethoprim versus amoxycillin for upper respiratory tract infection. Practitioner. 1986;230:905-8. [pmid: 3309920].
McKendrick AD, Mohr AR, Pattison A, et al. A comparative study of talampicillin and ampicillin syrups in the treatment of paediatric infections in general practice. Practitioner. 1981;225:1181-3. [pmid: 7033952].
McLinn SE. Comparative study of cefaclor a new cephalosporin and amoxicillin in the treatment of acute otitis media in children relationship of antibiotic concentrations of cefaclor and amoxicillin found in the middle ear effusions and their in-vitro activity. siegenthaler, In: Luethy W, Luethy R, eds. Current chemotherapy. Proceedings of the 10th International Congress of Chemotherapy, Vols. I and II. Washington, D.C.: 1978. p. 123-5. ISBN 0-914826-16-6.
McLinn SE. Recurrence of otitis media after antibiotic therapy: Comparison of cephradine and amoxycillin. J Int Med Res. 1979;7:546-50. [pmid: 391628].
McLinn SE Cefaclor in treatment of otitis media and pharyngitis in children Am J Dis Child 1980 134(6):560 3 6770673
McLinn SE Randomized open label multicenter trial of cefixime compared with amoxicillin for treatment of acute otitis media with effusion Pediatr Infect Dis 1987 6(10):997 1001
McLinn S A multicenter, double blind comparison of azithromycin and amoxicillin/clavulanate for the treatment of acute otitis media in children Pediatr Infect Dis J 1996 15(9 Suppl):S20 3 8878242
McLinn SE, Goldberg F, Kramer R, et al. Double-blind multicenter comparison of cyclacillin and amoxicillin for the treatment of acute otitis media. J Pediatr. 1982;101:617-21. [pmid: 6750067].
McLinn SE, McCarty JM, Perrotta R, et al. Multicenter controlled trial comparing ceftibuten with amoxicillin/clavulanate in the empiric treatment of acute otitis media. Members of the Ceftibuten Otitis Media United States Study Group. Pediatr Infect Dis J. 1995;14:S108-14. [pmid: 7567310].
McLinn SE, Moskal M, Goldfarb J, et al. Comparison of cefuroxime axetil and amoxicillin-clavulanate suspensions in treatment of acute otitis media with effusion in children [published erratum appears in Antimicrob Agents Chemother 1994 Oct;38(10):2516]. Antimicrob Agents Chemother. 1994;38:315-8. [pmcid: 284446]. [pmid: 8192458].
McLinn SE, Serlin S. Cyclacillin versus amoxicillin as treatment for acute otitis media. Pediatrics. 1983;71:196-9. [pmid: 6337365].
McLinn SE, Werner K, Cocchetto DM. Clinical trial of cefuroxime axetil versus cefaclor for acute otitis media with effusion. Curr Ther Res Clin Exp. 1988;43:1-11.
McNeill RA. Phenethicillin and penicillin G in acute suppurative otitis media in childhood. Br Med J. 1962;1:360-2. [pmid: 20789335].
Megraud F, De Lestapis X, Devars F, et al. [Bacteriological study of acute otitis media in children. Therapeutic consequences]. Arch Fr Pediatr. 1987;44:419-22. [pmid: 3650065].
Meistrup-Larsen KI, Mygind N, Thomsen J, et al. Oral norephedrine in the treatment of acute otitis media. Results of a double-blind, placebo-controlled trial. Acta Otolaryngol. 1978;86:248-50. [pmid: 360764].
Meistrup-Larsen KI, Mygind N, Thomsen J, et al. Oral nor-ephedrine therapy in acute otitis media. Report of a double-blind, placebo-controlled clinical trial. Ugeskr Laeg. 1980;142:2773-5. [pmid: 7003877].
Meistrup-Larsen KI, Mygind N, Thomsen J, et al. Penicillin therapy in acute otitis media. Report of a double-blind, placebo-controlled clinical trial. Ugeskr Laeg. 1980;142:2768-72. [pmid: 6777929].
Meistrup-Larsen KI, Sorensen H, Johnsen NJ, et al. Two versus seven days penicillin treatment for acute otitis media. A placebo controlled trial in children. Acta Otolaryngol. 1983;96:99-104. [pmid: 6412508].
Meistrup-Larsen KI, Thomsen J, Mygind N, et al. Penicillin treatment of acute middle ear infections in children. How long should treatment continue?. Ugeskr Laeg. 1983;145:1201-4. [pmid: 6410565].
Mendelman PM, Del Beccaro MA, McLinn SE, et al. Cefpodoxime proxetil compared with amoxicillin-clavulanate for the treatment of otitis media [published erratum appears in J Pediatr 1993 Mar;122(3):502]. J Pediatr. 1992;121:459-65. [pmid: 1517926].
Mendoza G, Oreggia F. Efficacy of the erythromycin/sulfisoxazole association in pediatric patients carriers of otitis media. Invest Med Int. 1985;12:125-31.
Mengoli C, Luzzati R, Bassetti D. Cefotetan in pediatric patients. G Mal Infett Parassit. 1985;37:219-21.
Menon AD, Crespo C, Cruz FA, et al. Treatment of ENT infections with cefadroxil. Folha Med. 1983;86:191-3.
Men'shikov NM. [The use of lyase and desoxyribonuclease in acute otitis in children]. Zh Ushn Nos Gorl Bolezn. 1968;28:77-9. [pmid: 5748127].
Messinger P. Zur Behandlung der Otitis media mit Pulsatilla. Der Kinderarzt. 1985;16:581-2.
Michaels RH. Ampicillin-resistant Haemophilus influenzae and otitis media. Am J Dis Child. 1981;135:403-5. [pmid: 7015826].
Miniti A, De Barros RA. Clinical evaluation of cefadroxil in acute ENT infections. Folha Medica. 1983;86:151-3.
Miriszlai E, Bodanszky H. [The use of the drainage technic in the conservative treatment of middle ear inflammation in infancy and childhood]. HNO. 1968;16:116-8. [pmid: 5685978].
Miyake H, Tanaka J. [Clinico-bacteriological study on recent phlogogenic bacteria in acute otitis media and therapy with erythromycin estolate]. Jibiinkoka. 1966;38:1109-14. [pmid: 6009621].
Miyamoto N, Kobayashi T, Baba S. Ciprofloxacin in the treatment of suppurative otitis media and sinusitis. Drugs. 1993;46:325-6.
Miyamoto N, Kobayashi T, Yamamoto S, et al. Bacteriological, pharmacokinetic and clinical studies on ME1207 in otorhinolaryngological infection. Chemotherapy. 1992;40:636-42.
Miyoshi T. A clinical study of cefmetazole (CMZ) against infections in the otorhinolaryngological field. Pract Otol. 1983;76:1859-71.
Modai J. Azithromycin: Clinical assessment. Pathol Biol. 1995;43.
Modugno V, Staffieri A, Teatini GP. Comparative study between amoxicillin and bacampicillin in the treatment of O. R.L. infections. Rivista Italiana di Otorinolaringologia Audiologia e Foniatria. 1982;2:298-301.
Moher D, Jadad AR, Nichol G, et al. Assessing the quality of randomized controlled trials: An annotated bibliography of scales and checklists. Control Clin Trial. 1995;16:62-73.
Moher D, Jones A, Cook DJ, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352:609-13. [pmid: 9746022].
Mohs E, Rodriguez-Solares A, Rivas E, et al. A comparative study of azithromycin and amoxycillin in paediatric patients with acute otitis media. J Antimicrob Chemother. 1993;31:73-9.
Moody SA, Alper CM, Doyle WJ. Daily tympanometry in children during the cold season: Association of otitis media with upper respiratory tract infections. Int J Pediatr Otorhinolaryngol. 1998;45:143-50. [pmid: 9849682].
Moran DG. A multicentre general practice study comparing pivampicillin (Pondocillin) and amoxycillin (Amoxil) in respiratory tract infections. J Int Med Res. 1983;11:370-4. [pmid: 6360752].
Moran DM, Mutchie KD, Higbee MD, et al. The use of an antihistamine-decongestant in conjunction with an antiinfective in treating acute otitis media. Drug Intell Clin Pharm. 1982;16.
Morris PS, Yonovitz A, Leach AJ, et al. Are diseases the same in developing countries? Diagnosing acute otitis media in a high risk population [abstract]. Annual Meeting of International Society of Technology Assessment in Health Care. 1997;13.
Morrison AW. Phenethicillin and benzylpenicillin in acute otitis media. BMJ. 1961;2:8-11. [pmid: 13772875].
Moszynski B, Piotrowska A. [Treatment of otitis media with Synalar and Synalar N preparations]. Otolaryngol Pol. 1977;31:511-5. [pmid: 600525].
Mudry A, Monnier P. [Complications of acute otitis media in children: Myth or reality?]. Rev Med Suisse Romande. 1992;112:61-4. [pmid: 1535963].
Muller R. Indications for the clinical treatment of acute otitis media in the childhood. Pediatr Rel Top. 1994;32:423-9.
Murai K, Baba S, Wada K, et al. Laboratory and clinical studies on T-1982 in otorhinolaryngological field. Chemotherapy 1982;30.
Murph JR, Dusdieker LB, Booth B, et al. Is treatment of acute otitis media with once-a-day amoxicillin feasible? Results of a pilot study. Clin Pediatr. 1993;32:528-34.
Muta H, Sakamoto Y, Hommura Y, et al. A clinical study on cefmetazole in the field of otorhinolaryngology. Pract Otol. 1982;75:2083-91.
Mygind N, Larsen KI, Thomsen J, et al A placebo controlled trial in acute otitis media First Meeting Of The Oto Rhino Laryngological Research Society; Clin Otolaryngol Allied Sci (Oxford) 1979 4(2):
Mygind N, Meistrup-Larsen KI, Thomsen J, Thomsen VF, Josefsson K, Sorensen H Penicillin in acute otitis media: a double-blind placebo-controlled trial Clin Otolaryngol Appl Sci 1981 6(1):5 13
Nakajima S. [Clinical use of colimycin F otic solution]. Jibiinkoka. 1965;37:693-7. [pmid: 5890449].
Nakajima Y, Hattori Y. [Clinical observation of acute otitis media in children]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1989;92:347-52.
Nanjyo S, Suga A. [Comparative study of clinical effects of cephalexin and aminobenzyl penicillin on acute suppurative inflammation of the middle ear by double blind test]. Jibiinkoka. 1970;42:719-24. [pmid: 4917278].
Nasedkin AN. [Acute inflammation of the middle ear in children]. Feldsher Akush. 1981:28-31.
Nassar WY, Allen BM. A double-blind comparative clinical trial of cephalexin and ampicillin in the treatment of childhood acute otitis media. Curr Med Res Opin. 1974;2:198-203. [pmid: 4841306].
National Center for Health Statistics. Current estimates from the National Health Interview Survey, 1982. Vital Health Stat 10 (150). Hyattsville, MD: U.S. Department of Health and Human Services, 1985.
Navarro KH, Scott L. Evaluation of primary treatment of otitis media in the managed care setting. ASHP Annual Meeting. 1991:P-69R.
Neil JF, Harrison SH, Morbey RD, et al. Deafness in acute otitis media. BMJ. 1966;5479:75-7. [pmid: 4955162].
Nelson C, Woodwell D. National Ambulatory Medical Care Survey: 1993 Summary. National Center for Health Statistics. Vital Health Stat 13 (136). Hyattsville, MD: U.S. Department of Health and Human Services, 1998.
Nelson JD, Ginsburg CM, Clahsen JC, et al. Treatment of acute otitis media of infancy with cefaclor. Am J Dis Child. 1978;132:992-6. [pmid: 31084].
Nelson JD, Ginsburg CM, Tetzlaff TR, et al. Cefaclor therapy of otitis media in infancy. In: Luethy W, Luethy R, eds. Current chemotherapy. Proceedings of the 10th International Congress of Chemotherapy, Vols. I and II; Washington, D.C.: 1978. p. 121-3. ISBN 0-914826-16-6.
Nilson BW, Poland RL, Thompson RS, et al Acute otitis media: treatment results in relation to bacterial etiology Pediatrics 1969 43(3):351 8 4975539
Norstedt S. [Acute otitis media in children in general practice]. Lakartidningen. 1967;64:787-93. [pmid: 6079554].
Novotny O. [Conservative treatment of acute and chronic otitis media]. Wien Med Wochenschr. 1970;120:654-7. [pmid: 5518008].
Odio CM, Kusmiesz H, Shelton S, et al. Comparative treatment trial of augmentin versus cefaclor for acute otitis media with effusion. Pediatrics. 1985;75:819-26. [pmid: 4039433].
O'Doherty B. An open comparative study of azithromycin versus cefaclor in the treatment of patients with upper respiratory tract infections. J Antimicrob Chemother. 1996;37:71-81. [pmid: 8818848].
Ogino H, Asai H, Matsunaga T. Clinical investigation on cefuroxime axetil (CXM-AX) in the infections of the otorhinolaryngology field. Chemotherapy 1986;34.
Ogino H, Koizuka I, Matsunaga T, et al. Cefdinir in otorhinolaryngological infections. Chemotherapy. 1989;37:1062-9.
Ogino H, Ohya Y, Matsunaga T. Clinical investigation of BAY o 9867 in the infections of the otorhinolaryngological field. Chemotherapy 1985;33.
Ogra PL, Tsutsumi H, Bernstein JM Natural history of acute otitis media in infancy mechanisms underlying the development of recurrent or chronic middle ear effusions. Joint meeting of the American Pediatric Society and the Society for Pediatric Research Pediatr Res 1986 20(4 part2):
Oh PI, Maerov P, Pritchard D, Knowles SR, Einarson TR, Shear NH. A cost-utility analysis of second-line antibiotics in the treatment of acute otitis media in children. Clin Ther. 1996;18:160-182. [pmid: 8851461].
Onion DK, Taylor C. The epidemiology of recurrent otitis media. Am J Public Health. 1977;67:472-4. [pmid: 857688]. [pmcid: 1653632].
Onishi S, Ueda R, Kobayashi K, et al. Clinical studies on cefixime in the field of otorhinolaryngology. Chemotherapy 1985;33.
Onishi S, Ueda R, Kobayashi K, et al. Loracarbef in otorhinolaryngological infections. Chemotherapy. 1993;41:441-7.
Oreggia F. Acute otitis media in pediatric patients. Invest Med Int. 1986;13:56-61.
Orengo P, Upmeyer HJ, Thriene W. Ceftibuten in the therapy of otitis media. TW Padiatr. 1996;9:160-1.
Osman MF. Treatment of infections of the ear with Pondocillin. Br J Clin Pract. 1982;36:99-102.
Ostfeld E, Harell M, Michaeli D, et al. Acute gram-negative bacillary otitis media. Am J Dis Child. 1978;132:721-2. [pmid: 665603].
Ostfeld F, Segal J, Kaufstein M, Gelernter I. Management of acute otitis media without primary administration of systemic antimicrobial agents. In: Proceedings of the fourth international symposium on recent advances in otitis media, 1988:235-9.
Ostropolets SS, Rodin VI, Olimpieva NI, et al. [Characteristics of the course of otitis media of staphylococcal etiology in young children]. Zh Ushn Nos Gorl Bolez. 1978:29-31.
Ottaviani A, Mantovani M, Scaricabarozzi I, et al. Multicenter study on the efficacy and tolerability of nimesulide in upper respiratory tract inflammatory diseases. Otorinolaringologia. 1989;39:579-88.
Ottolini MG, Ascher DP, Cieslak TJ, et al. Pneumococcal bacteremia during oral treatment with cefixime for otitis media. Pediatr Infect Dis J. 1991;10:467-8. [pmid: 1852543].
Owen MJ, Anwar R, Nguyen H, et al Efficacy of once daily cefixime in treatment of acute otitis media Joint meeting of the Southern Society for Clinical Investigation, Southern Section American Federation for Clinical Research, Southern Society for Pediatric Research, and Southern Region Society for Investigative Dermatology, Clin Res 1990 38(4):
Owen MJ, Anwar R, Nguyen HK, et al Efficacy of cefixime in the treatment of acute otitis media in children Am J Dis Child 1993 147(1):81 6 8418608
Oxman AD, Cook DJ, Guyatt GH Users guides to the medical literature: VI. How to Use an Overview JAMA 1994 Nov 2 272(17):1367 71
Paavolainen M. Incidence, etiology and prognosis of acute purulent otitis media in Helsinki residents of various ages. Acta Otolaryngol. 1966;Suppl:360-71. [pmid: 5992687].
Paez R, Musa HE. A microbiological and therapeutic study of otitis media in pediatrics. Invest Med Int. 1986;13:150-3.
Pallestrini E, Cimino A, Colleti V, et al. Comparative study of rufloxacin versus clarithromycin in the short term treatment of patients with torhinolaryngological infections. Rvista Italiani Di Otorinolaringologia Audiologia e Foniatria. 1995;15:236-45.
Palva T, Karma P. [Treatment of acute otitis media]. Duodecim. 1973;89:1216-20. [pmid: 4771793].
Paparella, MM, Bluestone CD, Arnold W, et al 1A. Definition and Classification Ann Otol Rhinol Laryngol 1985 94(suppl 116):8 9
Paradise JL. Inadequate resolution of acute otitis media following antimicrobial therapy. Pediatr Ann. 1984;13:382-90. [pmid: 6739177].
Paradise JL. Short-course antimicrobial treatment for acute otitis media: Not best for infants and young children. JAMA. 1997;278:1640-2. [pmid: 9388072].
Paradise JL, Bluestone CD, Rogers KD, et al Efficacy of adenoidectomy for recurrent otitis media in children previously treated with tympanostomy-tube placement. Results of parallel randomized and nonrandomized trials JAMA 1990 263(15):2066 73 2181158
Paradise JL, Rockette HE, Colborn DK, et al. Otitis media in 2253 Pittsburgh-area infants: Prevalence and risk factors during the first two years of life. Pediatrics. 1997;99:318-3. [pmid: 9041282].
Pastori A, Neri E, Viviano G. A clinical trial of 7-chlorolincomycin palmitate in infants. Minerva Pediatr. 1979;31:1305-8. [pmid: 537598].
Pavlopoulou J, Leotsacos P, Sereti E, et al. Randomized controlled study of clarithromycin versus cefaclor suspensions in the treatment of acute otitis media in children. J Chemother. 1995;7:150-3. [pmid: 8904139].
Peltner HU, Wiese K. Uncomplicated treatment of respiratory tract infections in children. TW Padiatr. 1997;10:290-3.
Perras C. Macrolides in community-acquired pneumonia and otitis media. Canadian Coordinating Office for Health Technology Assessment, 1997:14.
Perry BP, Zieno SA, Yonkers AJ, et al. Outcome-oriented managed care comparing efficacies of cefaclor and amoxicillin in acute and recurrent acute otitis media. Ear Nose Throat J. 1995;74:840-4. [pmid: 8556984].
Pestalozza G. Otitis media in newborn infants. Int J Pediatr Otorhinolaryngol. 1984;8:109-24. [pmid: 6526580].
Pestalozza G, Romagnoli M, Tessitore E, et al. [Diagnostic and therapeutic protocol in otitis media in the 1st year of life]. Acta Otorhinolaryngol Ital. 1988;8:11-8.
Pestalozza G, Cioce C, Facchini M. Azithromycin in upper respiratory tract infections: a clinical trial in children with otitis media. Scand J Infect Dis Suppl. 1992;83:22-5. [pmid: 1336892].
Pestalozza G. Azithromycin in the treatment of upper airway infection and acute otitis media in infants; In: Frior R, Pestalozza G, eds. The child and the environment: Present and future trends. (1012). International Congress Series: New York: Elsevier Science Publishers, 1993:135-40.
Physicians Desk Reference, 52 edition. Montvale, NJ: Medical Economics Company, 1998.
Pichichero M, Aronovitz GH, Gooch WM, et al. Comparison of cefuroxime axetil, cefaclor, and amoxicillin-clavulanate potassium suspensions in acute otitis media in infants and children. South Med J. 1990;83:1174-7. [pmid: 2218657].
Pichichero ME. Assessing the treatment alternatives for acute otitis media. Pediatr Infect Dis J. 1994;13:S27-34. [pmid: 8159512].
Pichichero ME, Cohen R. Shortened course of antibiotic therapy for acute otitis media, sinusitis and tonsillopharyngitis. Pediatr Infect Dis J. 1997;16:680-95. [pmid: 9239773].
Piippo T, Stefansson S, Pitkajarvi T, et al. Double-blind comparison of cefixime and cefaclor in the treatment of acute otitis media in children. Scand J Infect Dis. 1991;23:459-65. [pmid: 1957129].
Pimentel FL. Efficacy and safety of cefixime in 1,891 patients with otorhinolaryngologic and paediatric infections. J Drug Dev Suppl. 1993;6:77-9.
Pimentel FL. Efficacy and safety of cefixime in 19,393 outpatients with infections treated in general practice. J Drug Dev Suppl. 1993;6:73-5.
Pitts J. Shared decision-making in the informed treatment of acute otitis media. Practitioner. 1987;231:1232-3.
Pliszczynska-Brennenstuhl M, Zderkiewicz H. [Complicated otitis media in the course of antibiotic treatment]. Otolaryngol Pol. 1974;28:357-60. [pmid: 4845343].
Ploussard JH Evaluation of five days of cefaclor vs. ten days of amoxicillin therapy in acute otitis media Curr Ther Res 1984 36(Oct):641 5
Podvinec M [Co-tetroxazin (Tibirox) and doxycycline (Vibramycin) in treatment of upper respiratory tract infections: A double-blind study] Ther Umsch 1982 39(10):815 20 6760445
Podvinec M Co-tetroxazine (Tibirox(TM)) and doxycyclin (Vibramycin(TM)) in the treatment of upper airway infections. A comparative clinical study Chemioterapia 1982 1(4).
Pogue J and Yusuf S. Overcoming the limitations of current meta-analysis of randomised controlled trials. Lancet. 1998;351:47-52. [pmid: 9433436].
Poole JM, Rosenberg R, Aronovitz GH, et al. Cefprozil vs. cefixime and cefaclor in otitis media in children. Infect Med. 1992;9:21-32.
Poole MD. Implications of drug-resistant Streptococcus pneumoniae for otitis media. Pediatr Infect Dis J. 1998;17:953-6. [pmid: 9802652].
Portier H, Berche P, Gehanno P, et al. Child acute otitis media: Epidemiology and efficacy, safety of cefatrizine (Cefaperos(TM)) and cefadroxil (Oracefal(TM)) in general medical practice. Med Mal Infect. 1996;26:562-71.
Portmann M, Portmann D, Rohou S, et al. Efficacy and tolerance of morniflumate for the treatment of acute otitis media in infants. Rev Laryngol Otol Rhinol. 1990;111:507-10.
Prellner K. Is beta-lactamase-producing bacteria of major importance for unfavourable development of acute otitis media?. Acta Otolaryngol Suppl. 1992;493:109-11. [pmid: 1636409].
Principi N, Marchisio P, Bigalli L, Massironi E Amoxicillin twice daily in the treatment of acute otitis media in infants and children Eur J Pediatr 1986 145(6):522 5 3545844
Principi N, Marchisio P Cefixime vs amoxicillin in the treatment of acute otitis media in infants and children Drugs 1991 42(Suppl 4):25 9
Principi N, Marchisio P, Ambrosioni G, et al. Azithromycin versus amoxicillin-clavulanate in pediatric acute otitis media: Comparative, randomized, open study. In: Neu HC, Young LS, Zinner SH, et al. Infectious Disease & Therapy; New macrolides, azalides, and streptogramins in clinical practice. Second International Conference on Macrolides, Azalides, and Streptogramins; 1994 Jan; New York: Marcel Dekker Inc.; 1995:422-7.
Principi N. Multicentre comparative study of the efficacy and safety of azithromycin compared with amoxicillin/clavulanic acid in the treatment of paediatric patients with otitis media. Eur J Clin Microb Infect Dis. 1995;14:669-76.
Puczynski M, Stankiewicz J, Okeefe P Failure of single-dose amoxicillin therapy in the treatment of acute otitis media in children. The 43rd annual meeting of the American Federation for Clinical Research (Midwest Section) Clin Res 1985 33(4):
Puczynski MS, Stankiewicz JA, O'Keefe JP Single dose amoxicillin treatment of acute otitis media Laryngoscope 1987 97(1):16 8 3796171
Pugliese WM, Mesches DN, Wiersum J, et al. Double-blind study: Cleocin palmitate and Erythrocin Pediatric in otitis media in children. Curr Ther Res Clin Exp. 1972;14:31-4. [pmid: 4621563].
Puhakka H, Virolainen E, Eskola J, et al. Cefadroxil in the treatment of acute otitis media in children. J Antimicrob Chemother. 1982;10:99-103.
Puhakka H, Virolainen E, Aantaa E. Treatment of acute otitis media in children penicillin V or amoxicillin? Transactions of the 21st Congress of the Scandinavian Oto Laryngological Society; 1981 Aug 16-19; Turku, Finland. Acta Otolaryngol Suppl. 1982;Suppl(386):108-11.
Puhakka HJ, Haapaniemi J, Tuohimaa P, et al. Clinical efficacy and tolerance of bacampicillin and amoxycillin suspensions in children with acute otitis media. J Int Med Res. 1989;17:41-7. [pmid: 2651176].
Pukander JS, Paloheimo SH, Sipila MM. Cefetamet pivoxil in pediatric otitis media. Chemotherapy. 1992;38:25-8. [pmid: 1516461].
Pukander JS, Jero JP, Kaprio EA, et al. Clarithromycin vs. amoxicillin suspensions in the treatment of pediatric patients with acute otitis media. Pediatr Infect Dis J. 1993;12:S118-21. [pmid: 8295812].
Quevedo A, Sossouhounto R, Kissling M. Cefetamet pivoxil in otitis media. J Otorhinolaryngol Relat Spec. 1993;55:93-6.
Qvarnberg Y. Acute otitis media. A prospective clinical study of myringotomy and antimicrobial treatment. Acta Otolaryngol Suppl. 1981;375:1-157. [pmid: 6274132].
Raball JA. [Suppurative otitis media]. Rev Med Suisse Romande. 1983;103:817-8. [pmid: 6648192].
Raikundalia KB. Analysis suppurative otitis media in children: Aetiology of non-suppurative otitis media. Med J Aust. 1975;1:749-50. [pmid: 1152752].
Ramet J. A safety and efficacy comparative study of clarithromycin and amoxillin/clavulanate suspensions in the short course treatment of children with acute otitis media. Acta Therapeutica. 1995;21:231-41.
Ramet J, Casneuf J, Demay M, et al. Comparative safety and efficacy of clarithromycin and azithromycin suspensions in the short course treatment of children with acute otitis media. Clin Drug Invest. 1995;9:61-6.
Rasmussen F, Jensen K. [Antimicrobial chemotherapy in acute otitis media]. Ugeskr Laeger. 1975;137:1836-9. [pmid: 1145889].
Reed D, Dunn W. Epidemiologic studies of otitis media among Eskimo children. Public Health Rep. 1970;85:699-706. [pmid: 4988671].
Roddey OF Jr, Earle R Jr, Haggerty R. Myringotomy in acute otitis media. A controlled study. JAMA. 1966;197:849-53.
Rodriguez WJ, Schwartz RH, Sait T, et al Erythromycin sulfisoxazole pediazole vs. amoxicillin in the treatment of acute otitis media in children: A double-blind multiple dose comparative study Combined Meeting of the American Pediatric Society and the Society For Pediatric Research. Pediatr Res 1984 18(4part2):
Rodriguez AF. An open study to compare azithromycin with cefaclor in the treatment of children with acute otitis media. J Antimicrob Chemother. 1996;37:63-9. [pmid: 8818847].
Rodriguez RS, Sanchez Sanchez C, De La Torre Gonzalez C Bacteriology and therapeutic response to a combination of erythromycin-sulfisoxazole in children with acute otitis media Bol Med Hosp Infant Mexico 1987 44(12):728 34
Rodriguez WJ, Schwartz RH, Sait T, et al. Erythromycin-sulfisoxazole vs amoxicillin in the treatment of acute otitis media in children. A double-blind, multiple-dose comparative study. Am J Dis Child. 1985;139:766-70. [pmid: 3895889].
Rodriguez WJ, Chhabra OP, Guarinello AP, et al Cefuroxime axetil vs. cefaclor in acute otitis media with effusion Joint meeting of the American Pediatric Society and the Society for Pediatric Research. Pediatr Res 1986 20(4part2):
Roffo LM, Rodriguez H, Casellas JM, et al. Otitis media in pediatrics: Microbiology and therapeutic effects of a new formulation. Invest Med Int. 1986;12:326-30.
Roge J, Durand B, Pappo M. Cefuroxime-axetil for ENT infection. J Fr Otorhinolaryngol Audiophonol Chir Maxillo Fac. 1989;38:138-43.
Roland PS, Finitzo T, Friel-Patti S, et al. Otitis media: Incidence, duration, and hearing status. Arch Otolaryngol Head Neck Surg. 1989;115:1049-53. [pmid: 2765220].
Roland RK, Assef MCV, Kallas EG, et al. Treatment of bacterial infections with a new macrolide antibiotic: Miocamycin. Rev Bras Med. 1992;49:429-34.
Roos K, Lind L, Holm SE. Beta-lactamase production and bacterial tolerance in recurrent acute otitis media. Int J Pediatr Otorhinolaryngol. 1991;21:155-61. [pmid: 1909690].
Rosen C, Forsgren A, Lofkvist T, et al. Acute otitis media in older children and adults treated with phenoxymethyl penicillin or erythromycin stearate. Bacteriological and immunological aspects. Acta Otolaryngol. 1983;96:247-53. [pmid: 6416018].
Rosen C, Forsgren A, Lofkvist T, et al. Acute otitis media in older children and adults treated with penicillin or erythromycin. Acta Otolaryngol Suppl. 1984;407:23-5. [pmid: 6437133].
Rosenfeld RM. An evidence-based approach to treating otitis media. Pediatr Clin North Am. 1996;43:1165-81. [pmid: 8973506].
Rosenfeld RM. Natural history of untreated otitis media. In: Rosenfeld RM, Bluestone CD, eds. Evidence-based otitis media. Saint Louis, BC: Decker Inc.; 1999a:157-77.
Rosenfeld RM. What to expect from medical therapy. In: Rosenfeld RM, Bluestone CD, eds. Evidence-based otitis media. Saint Louis, BC: Decker Inc.; 1999b:179-205.
Rosenfeld RM, Goldsmith AJ, Tetlus L, Balzano A Quality of life for children with otitis media Arch Otolaryngol Head Neck Surg 1997 123(10):1049 54 9339979
Rosenfeld RM, Vertrees JE, Carr J, et al Clinical efficacy of antimicrobial drugs for acute otitis media: Meta-analysis of 5400 children from thirty-three randomized trials J Pediatr 1994 124(3):355 67 8120703
Roulleau P. Trial of metacycline in ENT infections. J Agreges. 1980;13:422-3.
Rowe DS. Acute suppurative otitis media. Pediatrics. 1975;56:285-94. [pmid: 240150].
Roydhouse N. A controlled study of adenotonsillectomy. Arch-Otolaryngol. 1970;92:611-6. [pmid: 4922436].
Rubenstein McBean JB, Hedgecock LD, et al. The treatment of acute otitis media in children. III. A third clinical tiral. Am J Dis Child. 1965;109:308-13. [pmid: 14261009].
Russell LB, Siegel JE, Daniels N, et al. Cost-effectiveness analysis as a guide to resource allocation in health: Roles and limitations. In: Gold MR, Siegel JE, Russell LB, Weinstein MC, eds. Cost-effectiveness in health and medicine. New York: Oxford University Press; 1996:3-24.
Saah AJ, Blackwelder WC, Kaslow RA. Treatment of acute otitis media. JAMA. 1982;248:1071-2. [pmid: 7050451].
Sackett DL. How to read clinical journals. V: To distinguish useful from useless or even harmful therapy. Can Med Assoc J. 1981;124:1156-62. [pmid: 7016293]. [pmcid: 1705333].
Sackett DL, Haynes RB, Tugwell P. Clinical Epidemiology: A Basic Science for Clinical Medicine. Boston: Little, Brown and Company; 1985.
Saeed Kokab A, Heikkinen T, McCormick DP, et al. A single intramuscular dose of ceftriaxone changes nasopharyngeal bacterial flora in children with acute otitis media (AOM). Pediatr Res 1998;43.
Sait T, Rodriguez WM, Chhabra OP, et al Sultamicillin ampicillin-sulbactam in two oral dosage regimen vs. amoxicillin in the treatment of acute otitis media Joint meeting of the American Pediatric Society and the Society for Pediatric Research, Pediatr Res 1986 20(4part2):
Saito C, Yokoyama T. Efficacy of oral antimicrobial agent in children with otitis media or upper respiratory tract infection. Practica Otologica, Suppl Issue. 1993:113-8.
Sakamoto Y. Clinical study of loracarbef in the otorhinolaryngological field. Chemotherapy. 1993;41:714-6.
Salzberg R. [Comparative clinical and bacteriological studies with Bactrim and ampicillin in the pediatrics]. Schweiz Rundsch Med Prax. 1972;61:1051-2. [pmid: 4563621].
Sambe B, Iida H. [Therapeutic results in otorhinolaryngological infections with dicloxacillin (Staphcillin A)]. J Antibiot (B). 1967;20:137-9. [pmid: 5299155].
Sambe B, Ueda R, Murakami H, et al. Fundamental and clinical study of netilmicin in otorhinolaryngological field. Chemotherapy 1981;29.
Sambe B, Ueda R, Kobayashi K, et al. Fundamental and clinical study of cefotetan (YM09330) in otorhinolaryngology. Chemotherapy 1982;30.
Sambe B, Kawakubo J, Shibui K, et al. Fundamental and clinical studies of ASPC. Pract Otol. 1985;78:763-77.
Sanchez F, Ortega S, Quintos C. Amoxicillin in treatment of pediatric respiratory infections. Compend Invest Clinlatinoam. 1981;1:40-5.
Saracaydin A, Katircioglu S, Sunay T, et al. Evaluation of cefuroxime axetil and phenoxymethyl penicillin in the treatment of acute otitis media in children. In: Sade J, ed. Infections in childhood: Ear, nose and throat aspects. (1040). International Congress Series: 1994. New York: Elsevier Science Publishers, 1993:67-71.
Sato K, Ichikawa T, Yamada Y. Clinical experience of AM-715 in the otorhinolaryngological infections. Chemotherapy 1981;29.
Sawaki S, Kitamura K, Sato Y, et al. [Double-blind studies of the effect of ampicillin-cloxacillin (Rectocillin) on acute otorhinolaryngological infections (author's transl)]. Jpn J Antibiot. 1976;29:340-3. [pmid: 775145].
Sawaki S. [Clinical evaluation of cephalexin (Lilly) in oto-laryngological infections by a double blind method]. Saishin Igaku. 1970;25:1556-62. [pmid: 4916002].
Schaad UB, Farine JC, Fux TH, et al. Prospective placebo-controlled double-blind evaluation of bacterial lysate in respiratory and ear-nose-throat infections in childhood. Helv Paediatr Acta. 1986;41:7-17. [pmid: 3755127].
Schaad UB Multicentre evaluation of azithromycin in comparison with co-amoxiclav for the treatment of acute otitis media in children J Antimicrob Chemother 1993 31(Suppl E):81 8 8396101
Schappert, SM. Office visits for otitis media: United States, 1975-90. Advance data from vital and health statistics. Hyattsville, MD: National Center for Health Statistics, 1992.
Schappert, SM. National ambulatory medical care survey: 1994 summary. Advance data from vital and health statistics. Hyattsville, MD: National Center for Health Statistics, 1996.
Schappert SM. Ambulatory care visits to physician offices, hospital outpatient departments, and emergency departments: United States, 1995. National Center for Health Statistics. Vital Health Stat 13 (129). Hyattsville, MD: U.S. Department of Health and Human Services, 1997.
Schloss MD, Dempsey EE, Sorger S. Clinical evaluation of erythromycin-sulfisoxazole (pediazole(TM)) t.i.d. in the treatment of 'resistant' acute otitis media. Todays Ther Trends. 1987;5:31-41.
Scholz H, Noack R Multicenter, randomized, double-blind comparison of erythromycin estolate versus amoxicillin for the treatment of acute otitis media in children AOM Study Group. Eur J Clin Microbiol Infect Dis 1998 17(7):470 8
Schulz, KF, Chalmers I, Hayes RJ, Altman DG. Empirical evidence of bias dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273:408-12. [pmid: 7823387].
Schwartz B, Clouse J, Shatin D, et al. Evaluation of treatment outcome for children with acute otitis media (AOM) using a health maintenance organization (HMO) claims database. Abstracts of the 35th interscience conference on antimicrobial agents the chemotherapy; 1995 Sep 17-20; San Fransisco, CA; 1995; 35(0):290.
Schwartz R, Rodriguez WJ, Khan W, et al Trimethoprim sulfamethoxazole in the treatment of otitis media secondary to ampicillin resistant strains of haemophilus-influenzae. The 2nd international symposium on recent advances in otitis media with effusion Ann Otol Rhinol Laryngol 1980 80(3part2):281 4
Schwartz RH, Hayden GF, Rodriguez WJ, et al. Leukocyte counts in children with acute otitis media. Pediatr Emerg Care. 1986;2:10-4. [pmid: 3774566].
Schwob MF. Cefadroxil in the treatment of otitis media. J Int Med Res. 1980;8:103-5. [pmid: 7439497].
Scott HV, Pannowitz D, Ketelbey JW. Cefixime: Clinical trial against otitis media and tonsillitis. N Z Med J. 1990;103:25-6.
Sekiya T, Nagayasu M, Miyagawa K, et al. Result of clinical application of TA-058 against otorhinolaryngological infectious diseases. Chemotherapy 1984;32.
Sell SH, Wilson DA, Stamm JM, et al. Treatment of otitis media caused by Hemophilus influenzae: Evaluation of three antimicrobial regimens. South Med J. 1978;71:1493-7. [pmid: 310164].
Senturia BH, Paparella MM, Lowery HW, et al Definition and Classification Ann Otol Rhinol Laryngol 1980 89(suppl: 69):4 8
Serra A, Vancheri M, Saita V, et al. Clinical experience of ofloxacin in the otorhinolaryngohyatric infections. G Mal Infett Parassit. 1986;38:1325-7.
Shenderey K, Marsh BT, Talbot DJ. A multi-centre general practice comparison of a fixed-dose combination of pivmecillinam plus pivampicillin with amoxycillin in respiratory tract infections. Pharmatherapeutica. 1985;4:300-5. [pmid: 4070323].
Shepard DS, Thompson MS. First principles of cost effectiveness analysis in health. Public Health Rep. 1979;94:535-43. [pmid: 117509]. [pmcid: 1431742].
Shibui H. Clinical studies on TMS-19-Q. GC tablet in the field of otorhinolaryngology. Chemotherapy 1984;32.
Shinkawa A, Kimura H, Sakai M, et al. Loracarbef in otorhinolaryngological infections. Chemotherapy. 1993;41:448-57.
Shinkawa A, Kimura H, Sakai M, et al. Pharmacokinetic and clinical studies of T-3761 in otorhinolaryngeal infections. Drugs. 1995;49:401-2. [pmid: 8549377].
Shinkawa A, Miyake H. Clinical evaluation of cefuroxime axetil (CXM-AX) in the otorhinolaryngology. Chemotherapy 1986;34.
Shiraishi T, Kubo T, Ashida K, et al. Evaluation of cefclidin in treatment of otorhinolaryngological infections. Chemotherapy. 1992;40:649-654.
Shurin PA, Pelton SI, Donner A, et al. Persistence of middle-ear effusion after acute otitis media in children. N Engl J Med. 1979;300:1121-3. [pmid: 431635].
Shurin PA, Pelton SI, Donner A, et al. Trimethoprim-sulfamethoxazole compared with ampicillin in the treatment of acute otitis media. J Pediatr. 1980;96:1081-7. [pmid: 6966331].
Shurin PA. Evaluation of antimicrobial drugs for acute otitis media. Int J Pediatr Otorhinolaryngol. 1996;34:219-223. [pmid: 8839071].
Siclari S, Salviera C. Clindamycin palmitate in ear, nose and throat infections. Otorinolaringol Ital. 1984;34:55-58.
Simon MW Five- vs 10-day treatment of acute otitis media with ceftibuten in infants and children Adv Ther 1997 14(6):312 7
Siri Arce Ma T, Bercovich WM, Prado Jimenez V, et al. Comparative and prospective study of sulfamethopyrazine efficacy (kelfiprim) in relation to oral ampicillin in infants with acute otitis media. Rev Chil Infect. 1984;1:70-6.
Soda Merhy A, Hernandez Goribar M. Treatment of otitis media with trimethoprim-sulfamethoxypirazine. Invest Med Int. 1985;12:103-7.
Soejima R, Matsushima T, Niki Y, et al. Clinical studies on lenampicillin (KBT-1585). Chemotherapy 1984;32.
Sokoliuk MV, Pavlovskaia TV. [Peculiarities of the course of otoantritis in infants treated with antibiotics]. Zh Ushn Nos Gorl Bolezn. 1968;28:78-80. [pmid: 5737161].
Sorensen H, Frolund Thomsen V, Sederberg-Olsen J, et al. [Bacteria and antibiotics in acute suppurative otitis media]. Ugeskr Laeger. 1977;139:1842-6. [pmid: 302998].
Sorri M, Maki-Torkko E, Alho OP. Otitis media and long-term follow-up of hearing. Acta-Otolaryngol-(Stockholm). 1995;115:193-5. [pmcid: 245392].
Spindler JJ, Marsh BT, Talbot DJ. Respiratory infections in general practice: A clinical comparison of Pivmecillinam-plus-pivampicillin (miraxid) and Cephalexin (Ceporex). Clin Trials J. 1985;22:293-9.
Stahl JP, Archimbaud A, Baud P, et al. Treatment of actue otitis media in children: Comparison of cefuroxime axetil and amoxicillin-clavulanate suspensions. Med Mal Infect. 1995;25:147-53.
Stamboulian D, Fernandez MacLoughlin GJ, Lanoel JL, et al. Clinical evaluation of roxithromycin in 101 children. Br J Clin Pract. 1988;42:115-6.
Starfield B, Katz H, Gabriel A, et al. Morbidity in childhood-a longitudinal view. N Engl J Med. 1984;310:824-9. [pmid: 6700671].
Stechenberg BW, Anderson D, Chang MJ, et al. Cephalexin compared to ampicillin treatment of otitis media. Pediatrics. 1976;58:532-6. [pmid: 787913].
Stephenson H, Higson J, Haggard M. Binaural hearing in adults with histories of otitis media in childhood. Audiology. 1995;34:113-23. [pmid: 8561689].
Stickler GB, Rubenstein NM, McBean JB, et al. Treatment of acute otitis media in children IV. A fourth clinical trial. Am J Dis Child. 1967;114:123-30.
Stool SE, Field MJ The impact of otitis media Pediatr Infect Dis J 1989 8(Suppl):S11 4 2494641
Stool SE, Berg AO, Berman S, et al. Otitis media with effusion in young children. Clinical practice guideline, Number 12. Rockville, MD: Agency for Health Care Policy and Research, Public Health Service, U.S. Department of Health and Human Services, July 1994a. AHCPR Publication No. 94-0622.
Stool SE, Berg AO, Berman S, et al. Managing otitis media with effusion in young children. Quick reference guide for clinicians. Agency for Health Care Policy and Research, Public Health Service, U.S. Department of Health and Human Services, July 1994b. AHCPR Publication No. 94-0623.
Stutman HR, Argueda AG. Comparison of cefprozil with other antibiotic regimens in the treatment of children with acute otitis media. Clin Infect Dis. 1992:S204-8.
Sugita R, Kawamura S, Ichikawa G, et al. [Chemotherapy of acute purulent otitis media (author's transl)]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1979;82:1381-7.
Sugita R, Kawamura S, Fujimaki Y, et al. Concentrations in aural discharge and clinical effect of cephem antibiotics. Pract Otol. 1982;75:1571-84.
Sugita R, Kawamura S, Ichikawa G, et al. A fundamental and clinical study of AM-715 in the otorhinolaryngologic field. Pract Otol. 1982;75:1859-65.
Sugita R, Kawamura S, Fujimaki Y, et al. In vitro antibacterial activity, tissue concentration and clinical efficacy of cefotiam, a second generation cephem, in otorhinolaryngological infections. Pract Otol. 1983;76:1693-709.
Sugita R, Kawamura S, Fujimaki Y, et al. Laboratory and clinical studies on lenampicillin (KBT-1585) in otorhinolaryngological field. Chemotherapy 1984;32.
Sugita R, Kawamura S, Fujimara Y, et al. Fundamental and clinical studies on TMS-19-Q in the otorhinolaryngological infections. Chemotherapy 1984;32.
Sugita R, Deguchi K, Fujimaki Y, et al. Clinicobacteriologic study of sultamicillin fine granules for pediatric acute suppurative otitis media. Chemotherapy. 1993;41:1018-26.
Sunakawa K, Saito N, Ishizuka Y, et al. [Fundamental and clinical studies of cefixime granules in pediatrics]. Jpn J Antibiot. 1986;39:1035-54. [pmid: 3761536].
Sunderland RL, Atkin KJ. Cefixime versus co-amoxiclav in the treatment of pediatric upper respiratory tract infections and otitis media. A multicenter clinical study of empirical treatment in general practice in the United Kingdom. Curr Ther Res Clin Exp. 1994;55:22-9.
Supance JS, Kaleida PH, Casselbrant ML, et al. Antibitoic or myringotomy, or both, for acute otitis media. Ann Otol Rhinol Laryngol 1983;96.
Szczypiorski K, Wroblewska E, Tomaszewska E, et al. [Bacterial flora in otitis media in infants and children under age 2]. Otolaryngol Pol. 1969;23:183-90. [pmid: 4389313].
Szczypiorski K, Tomaszewska E, Wroblewska E, et al. [Comparative analysis of the bacterial flora and antibiotic resistance in otitis media in children up to the age of 2 years]. Otolaryngol Pol. 1969;23:191-9. [pmid: 4389314].
Szczypiorski K, Gutkowska J, Okolska W, et al. [Analysis of the absence of correlation between the effectiveness of treatment of otitis media and the in vitro sensitivity to antibiotics of microorganisms]. Otolaryngol Pol. 1971;25:199-203. [pmid: 5206640].
Tachibana M, Mizukoshi O. Clinical investigation of BAY o 9867 on infections in the orhinolaryngological field. Chemotherapy 1985;33.
Takebayashi S, Miyawaki S. A fundamental study of the effect of cefotiam (CTM) on inflammatory diseases in otorhinolaryngology. Pract Otol. 1983;76:2017-21.
Taketomo CK (editor). Childrens Hospital Los Angeles pediatric dosing handbook & formulary. Hudson, OH: Lexi-Comp, Inc., 1999.
Tamaki H, Ishida M, Matsunaga T, et al. A clinical study of cefmenoxime in the field of otolaryngology. Pract Otol. 1982;75:1727-33.
Tamaki N, Yonei K, Murata K, et al. Effect of tarivid(TM) (ofloxacin) on otorhinolaryngological infections. Pract Otol. 1989;82:1667-73.
Tamotsu H, Takeshi K, Sakata Y, et al. Clinical study on S-1108 for otorhinolaryngological infections. Chemotherapy. 1993;41:671-80.
Tanaka O, Matsunaga T, Miyahara H. Comparative study of the efficacy of cefpodoxime proxetil (CPDX-PR) dry syrup at two doses in pediatric otorhinolaryngology. Practica Otologica. 1995;88:1513-20.
Tanigaito Y, Nagae D, Murai N, et al. Fundamental and clinical studies on cefuroxime axetil (CXM-AX) in the otorhinolaryngology. Chemotherapy 1986;34.
Tarantino V, Stura M, Marenco G, et al. Therapeutic role of bromhexine in the treatment of child otitis media. Randomised double-blind study versus placebo. Otorinolaringologia. 1989;39:187-91.
Tarasov DI, Nikolaevskaia VP, Ababii. [Use of lekozim in middle ear diseases]. Vestn Otorinolaringol 1985:43-7.
Tarpay M, Marks MI, Hopkins C, et al. Cefaclor therapy twice daily for acute otitis media. Controlled comparative study of twice-daily vs thrice-daily dose schedule. Am J Dis Child. 1982;136:33-5. [pmid: 7055107].
Tavares W. Multicenter trial with miocamycin in paediatric bacterial infections. Folha Med. 1987;95:363-7.
Taylor C, Onion DK. The first six months after otitis media. A preliminary report. J Maine Med Assoc. 1975;66:280-1. [pmid: 1194772].
Taylor RB, Pugliese WM, Wiersum J, et al. A comparison of lincomycin with penicillin in acute otitis media in children. Am J Dis Child. 1969;117:139-41. [pmid: 4884569].
Teele DW, Klein JO, Rosner BA Epidemiology of otitis media in children Ann Otol Rhinol Laryngol 1980 89(Suppl 68):5 6
Teele DW, Klein JO, Rosner BA. Epidemiology of otitis media during the first seven years of life in children in Greater Boston: A prospective, cohort study. J Infect Dis. 1989;160:83-94. [pmid: 2732519].
Teele DW, Klein JO, Chase C, Menyuk P, Rosner BA. Otitis media in infancy and intellectual ability, school achievement, speech, and language at age 7 years: Greater Boston Otitis Media Study Group. J Infect Dis. 1990;162:685-94. [pmid: 2387994].
Teele DW, Greig MH. Antimicrobial therapy of acute otitis media [published erratum appears in N Z Med J 1994 Sep 14;107(985):363]. N Z Med J. 1994;107:61-3. [pmid: 8192759].
Thalin A, Densert O, Larsson A, et al. Is penicillin necessary in the treatment of acute otitis media? In: Proceedings of the international conference on acute and secretory otitis media, Part I; 1986: p. 441-6.
Thomsen J, Mygind N, Meistrup-Larsen KI, et al. Oral decongestant in acute otitis media. Results of a double-blind trial. Int J Pediatr Otorhinolaryngol. 1979;1:103-8. [pmid: 399953].
Thomsen J, Meistrup-Larsen KI, Sorensen H, et al. Penicillin and acute otitis: Short and long-term results. Ann Otol Rhinol Laryngol Suppl. 1980;89:271-4. [pmid: 6778324].
Thomsen VF, Olsen JS, Sorensen H, et al. Bacteriology and antibiotics in acute suppurative otitis media. J Otolaryngol. 1976;5:289-97. [pmid: 9519].
Thore M, Liden M. Relapse of acute purulent otitis media: Antibiotic sensitivities of nasopharyngeal pathogens. Scand J Infect Dis. 1987;19:315-23. [pmid: 3616495].
Tilyard MW, Dovey SM, Walker SA Otitis media treatment in New Zealand general practice N Z Med J 1997 110(1042):143 5 9152355
Tom CM, Lombardi TP. Management of otitis media: assessment of compliance and treatment response in an uninsured and underserved pediatric population treated at a community health center. ASHP midyear clinical meeting. 1998;33:P-159E.
Tomiyama M. [Clinical observation of acute otitis media in children]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1993;96:1133-40.
Tomiyama M. [The effect of cefaclor and cefixime on nasopharyngeal pathogens in children]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1995;98:659-68.
Toral Martin R, Hernendez Tepichin G, et al. Diclofenac potassium in the treatment of the acute otitis media. Acta Pediatr Mex 1990:3.
Totsuka M. [Evaluation of the effect of antibiotics on acute otitis media]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1972;75:1461-3.
Townsend E. Otitis media in private practice. NY State J Med. 1964;64:1591-7.
Trevino Garza C, Amarante Gutierrez M, Quiroga Garza A, et al. Efficacy of low-dose sultamicillin in the treatment of mild and moderate infections in pediatrics. Invest Med Int. 1991;18:68-73.
Trofimov OA. [Iontophoresis with penicillin in therapy of acute catarrhal and suppurative otitis media in children during the 1st year of life]. Pediatr Akush Ginekol. 1970;1.
Trout KS. How to read clinical journals: IV. To determine etiology or causation. Can Med Assoc J. 1981;124:985-90. [pmid: 7260801]. [pmcid: 1705401].
Trujillo H. Cefadroxil monohydrate versus erythromycin in paediatric patients. J Int Med Res. 1981;9:132-7. [pmid: 7227625].
Tsai H-Y, Huang L-M, Chiu H-H, et al. Comparison of once daily cefpodoxime proxetil suspension and thrice daily cefaclor suspension in the treatment of acute otitis media in children. Chin J Microbiol Imm. 1998;31:165-70.
Tsubaki S. Basic and clinical studies on loracarbef in the field of otorhinolaryngology. Chemotherapy. 1993;41:436-40.
Tugwell P. How to read clinical journals: III. To learn the clinical course and prognosis of disease. Can Med Assoc J. 1981;124:869-72. [pmid: 7214286]. [pmcid: 1705372].
Statistical abstract of the United States, 1992. Springfield, VA: National Technical Information Service, 1992.
Statistical abstract of the United States, 1996. Springfield, VA: National Technical Information Service, 1996.
Statistical abstract of the United States, 1998. Springfield, VA: National Technical Information Service, 1998.
Consumer prices-all urban consumers. Econ Indic. Washington DC: Government Printing Office, 1999:23.
Uhari M, Mantysaari K, Niemela M. A meta-analytic review of the risk factors for acute otitis media. Clin Infect Dis. 1996;22:1079-83. [pmid: 8783714].
Uhari M, Kontiokari T, Niemela M A novel use of xylitol sugar in preventing acute otitis media Pediatrics 1998 102(4):879 84 9755259
Uno Y. Acute otitis media in infants and children due to benzylpenicillin- insensitive or resistant Streptococcus pneumoniae. Jpn J Chemother. 1998;46:396-403.
Valtonen M, Piippo T, Pitkajarvi T, et al. Comparison of amoxycillin given two and three times a day in acute respiratory tract infections in children. Scand J Prim Health Care. 1986;4:201-4. [pmid: 3797879].
Van Buchem FL, Dunk JH, van't Hof MA. Acute otitis media: Paracentesis, antibiotics or neither?. Ned Tijdschr Geneeskd. 1982;126:462-7. [pmid: 7078672].
Van Buchem FL, Dunk JH, va''t Hof MA Therapy of acute otitis media: myringotomy, antibiotics, or neither? A double-blind study in children Lancet 1981 2(8252):883 7 6117681
Van Buchem FL, Dunk J, van't H of M Treatment of Acute Otitis Media. Meeting of the Netherlands Ent Society, The Hague; 1981 May 8-9 Clin Otolaryngol Allied Sci (Oxford) 1982 7(5):
Van Buchem FL, Peeters MF, van't Hof MA. Acute otitis media: a new treatment strategy. Br Med J (Clin Res Ed.). 1985;290:1033-7.
Van Buchem FL, Peeters MF, Van't Hof MA. Acute otitis media: Favourable spontaneous course, adjustment of treatment. Ned Tijdschr Geneeskd. 1985;129:1093-9. [pmid: 3894997].
Van Buchem FL. [The treatment of acute otitis media]. Ned Tijdschr Geneeskd. 1989;133:290-2. [pmid: 2927544].
Varga G. [On the timely management of middle-ear infection]. HNO. 1967;15:292-4. [pmid: 5590830].
Varghese M, Kumar K, Khan AJ, et al. Controlled blind evaluation of netilmicin in pediatric patients. The 82nd annual meeting of the American Society for Microbiology; 1982 Mar 7-12; Atlanta, GA; 1982. Abstract A97.
Varsano I, Frydman M, Amir J, et al Single intramuscular dose of ceftriaxone as compared to 7-day amoxicillin therapy for acute otitis media in children A double-blind clinical trial. Chemotherapy 1988 34(Suppl 1):39 46
Varsano I, Volovitz B, Horev Z, et al. Intramuscular ceftriaxone compared with oral amoxicillin-clavulanate for treatment of acute otitis media in children. Eur J Pediatr. 1997;156:858-63. [pmid: 9392401].
Vasiu O, Radu C. [Results of treating ear suppurations with propolis]. Rev Chi Oncol Radiol O R L Oftalmol Stomatol Chir. 1983;28:147-9.
Veljak C. Use of a new antibiotic for treatment of acute and recurrent otitis media at pediatric age. In: Frior R, Pestalozza G, eds. The child and the future: Present and future trends. International Congress Series. New York: Elsevier Science Publishers, 1993:112-5.
Vellucci A, Marcucci L, Greco D, et al. Use of ceftazidime in the treatment of otorhinolaryngoiatric bacterial infections. Int J Clin Pharmacol Ther Toxicol. 1987;25:282-8. [pmid: 3298082].
Wada K, Baba S, Hatano T, et al. Laboratory and clinical studies of cefotetan (YM09330) in oto-rhino-laryngological field. Chemotherapy 1982;30.
Wald ER. Antihistamines and decongestants in otitis media. Pediatr Infect Dis. 1984;3:386-8. [pmid: 6147813].
Wallace RB, Marsh BT, Talbot DJ. A multi-centre general practice clinical evaluation of pivmecillinam plus pivampicillin ('Miraxid') and co-trimoxazole ('Septrin') in respiratory tract infections. Curr Med Res Opin. 1985;9:659-65. [pmid: 3907987].
Weinstein MC, Fineberg HV. Clinical decision analysis. Philadelphia: WB Saunders, 1980; ch. 8.
Weiss JC, Melman ST. Cost-effectiveness in the choice of antibiotics for the initial treatment of otitis media in children: a decision analysis approach. Pediatr Infect Dis J. 1988;7:23-6. [pmid: 3124072].
Westphal JF. Cefuroxime axetil, a new oral cephalosporin for the treatment of infection in E.N.T. clinical synthesis. Rev Laryngol Otol Rhinol. 1990;111:503-5.
Wheeler MT. Tympanometry in children with treated acute otitis media. Lancet. 1986;1:529-32. [pmid: 2869263].
White LL, Holimon TD, Tepidino JT, et al. Antimicrobials prescribed for otitis media in a pediatric Medicaid population. Am J Health Syst Pharm. 1996;53:2963-9. [pmid: 8974159].
Whittam DE, Pickard BH, Wilson TD. Brain abscess and otitis media. Acta Otorhinolaryngol Belg. 1969;23:375-83. [pmid: 5405053].
Wiersbitzky S, Weigert SR, Ewald A, et al. [Diagnosis and treatment of acute otitis media in children. An analysis of the status in the Rostock district]. Kinderarztl Praxis. 1989;57:597-603.
Wiet RJ, DeBlanc GB, Stewart J, et al. Natural history of otitis media in the American native. Acta Otol Rhinol Laryngol Suppl. 1980;89:14-9.
Willner MM, Dull TA, Macdonald H. Comparison of trimethoprim sulfamethoxazole and ampicillin in the treatment of acute bacterial otitis media in children. In: Siegenthaler W, Luethy R, eds. Current chemotherapy. Proceedings of the 10th international congress of chemotherapy, Vols. I and II; American Society for Microbiology, Washington, DC: 1978: 125-127. ISBN 0-914826-16-6.
Woodwell, DA. National ambulatory medical care survey: 1995 summary. Advance data from vital and health statistics. Hyattsville (MD): National Center for Health Statistics. 1997a.
Woodwell, DA. National ambulatory medical care survey. Advance data from vital and health statistics. Hyattsville, MD: National Center for Health Statistics, 1997b.
Woodwell, DA. and Schappert SM. National ambulatory medical care survey: 1993 summary. Advance data from vital and health statistics. Hyattsville, MD: National Center for Health Statistics, 1995.
Yawn BP, Yawn RA, Lydick E. The relative community burden of otitis media and varicella. Clin Ther. 1996;18:877-86. [pmid: 8930431].
Zbaeren P. Double-blind clinical comparison of co-tetroxacin and amoxicillin in frequent ORL infections. Chemioterapia. 1982.
Zbaren P, Pradervand M. Randomized double-blind study between co-tetroxacine and amoxicilline in common ENT-infections. Schweiz Rundsch Med Prax. 1983;72:1491-3. [pmid: 6361727].
Zimmerman DR, Allegra JR, Cody RP. The epidemiology of pediatric visits to New Jersey general emergency departments. Pediatr Emerg Care. 1998;14:112-5. [pmid: 9583391].
Zuniga A. Treatment of acute otitis media (A. O.M.) with Brodimoprim(TM) vs. ampicillin in children. Chemioterapia. 1982.