# References

Adams PF, Benson V. Current estimates from the National Health Interview Survey, 1990. National Center for Health Statistics. Vital Health Stat 10 (181). Hyattsville, MD: U.S. Department of Health and Human Services, 1991.
Adams PF, Benson V. Current estimates from the National Health Interview Survey, 1994. National Center for Health Statistics. Vital Health Stat 10 (193). Hyattsville, MD: U.S. Department of Health and Human Services, 1995.
Alsarraf R, Jung CJ, Perkins J, et al Otitis media health status evaluation: a pilot study for the investigation of cost-effective outcomes of recurrent acute otitis media treatment Ann Otol Rhinol Laryngol 1998 107(2):120 8 9486906
Amadasun JE. The cost effective medical treatment of suppurative otitis media in a Nigerian environment. W Afr J Med. 1997;16:85-7.
Anonymous. Average hours and earnings of roduction or nonsupervisory workers on private nonfarm payrolls by major industry, 1964 to date. Employment. 1999;46.
Appelman CL, Claessen JQ, Touw-Otten FW, et al Co-amoxiclav in recurrent acute otitis media: placebo controlled study BMJ 1991 303(6815):1450 2 1773154 1671677
Arguedas A, Loaiza C, Herrera M, et al. Comparative trial of 3-day azithromycin versus 10-day amoxycillin/clavulanate potassium in the treatment of children with acute otitis media. Int J Antimicrob Agents. 1996;6:233-8. [pmid: 18611713].
Arguedas A, Loaiza C, Rodriguez F, et al Comparative trial of 3 days of azithromycin versus 10 days of clarithromycin in the treatment of children with acute otitis media with effusion J Chemother 1997 9(1):44 50 9106017
Aronovitz G A multicenter, open label trial of azithromycin vs. amoxicillin/clavulanate for the management of acute otitis media in children Pediatr Infect Dis J 1996 15(9 Suppl):S15 9 8878241
Bain J, Murphy E, Ross F Acute otitis media: clinical course among children who received a short course of high dose antibiotic Br Med J (Clin Res Ed) 1985 291(6504):1243 6
Banz K, Schwicker D, Thomas AM. Economic evaluation of immunoprophylaxis in children with recurrent ear, nose, and throat infections. Pharmacoeconomics. 1994;6:464-77. [pmid: 10155274].
Barnett ED, Klein JO, Hawkins KA, et al. Comparison of spectral gradient acoustic reflectometry and other diagnostic techniques for detection of middle ear effusion in children with middle ear disease. Pediatr Infect Dis J. 1998;17:556-9. [pmid: 9655560].
Barnett ED, Levatin JL, Klein JO, et al. Challenges of evaluating homeopathic treatment of acute otitis media. In: Lim, DJ and Bluestone, CD, eds. Abstracts of the 7^th^ international symposium on recent advances in otitis media; 1999:110.
Barnett ED, Teele DW, Klein JO, et al Comparison of ceftriaxone and trimethoprim-sulfamethoxazole for acute otitis media. Greater Boston Otitis Media Study Group Pediatrics 1997 99(1):23 8 8989332
Bass JW, Cashman TM, Frostad AL, et al Antimicrobials in the treatment of acute otitis media. A second clinical trial Am J Dis Child 1973 125(3):397 402 4632555
Bass JW, Cohen SH, Corless JD, Mamunes P Ampicillin compared to other antimicrobials in acute otitis media JAMA 1967 202(8):697 702 4964192
Bauchner H, Adams W, Barnett E, Klein J Therapy for acute otitis media. Preference of parents for oral or parenteral antibiotic Arch Pediatr Adolesc Med 1996 150(4):396 9 8634735
Begg C, Cho M, Eastwood S, et al. Improving the quality of reporting of randomized controlled trials: the CONSORT statement. JAMA. 1996;276:637-9. [pmid: 8773637].
Benson V, Marano MA. Current estimates from the National Health Interview Survey, 1995. National Center for Health Statistics. Vital Health Stat 10 (199). Hyattsville, MD: U.S. Department of Health and Human Services, 1998.
Berman S, Byrns PJ, Bondy J, Smith PJ, Lezotte D. Otitis media-related antibiotic prescribing patterns, outcomes, and expenditures in a pediatric Medicaid population. Pediatrics. 1997;100:585-92. [pmid: 9310510].
Berman S, Lauer BA A controlled trial of cefaclor versus amoxicillin for treatment of acute otitis media in early infancy Pediatr Infect Dis 1983 2(1):30 3 6340079
Berman S, Roark R, Luckey D. Theoretical cost-effectiveness of management options for children with persisting middle ear infusions. Pediatrics. 1994;93:353-63. [pmid: 8115191].
Biles RW, Buffler PA, O'Donell AA. Epidemiology of otitis media: a community study. Am J Public Health. 1980;70:593-8. [pmid: 7377434]. [pmcid: 1619433].
Bisonni RS, Lawler FH, Pierce L. Recurrent otitis media: a cost-utility analysis of simulated treatment using tympanostomy tubes vs antibiotic prophylaxis. Fam Pract Res J. 1991;11:371-8. [pmid: 1767684].
Bluestone CD, Klein JO. Otitis media, atelectasis, and eustachian tube dysfunction. In: Bluestone CD, Stool SE, Kenna M, eds. Pediatric otolaryngology. Philadelphia: W. B. Saunders Company, 1996.
Blumer JL, Bertino JS Jr, Husak MP Comparison of cefaclor and trimethoprim-sulfamethoxazole in the treatment of acute otitis media Pediatr Infect Dis 1984 3(1):25 9 6366771
Bollag U, Bollag-Albrecht E Recommendations derived from practice audit for the treatment of acute otitis media Lancet 1991 338(Jul 13):96 9 1676479
Bottenfield GW, Burch DJ, Hedrick JA, et al Safety and tolerability of a new formulation (90 mg/kg/day divided every 12 h) of amoxicillin/clavulanate (Augmentin) in the empiric treatment of pediatric acute otitis media caused by drug-resistant Streptococcus pneumoniae Pediatr Infect Dis J 1998 17(10):963 8 9802654
Boulesteix J, Dubreuil C, Moutot M, et al Cefpodoxime proxetil five days versus cefixime eight days in the treatment of acute otitis media in children Medecine Et Maladies Infectieuses 1995 25(3 Bis):534 9
Branthaver B, Greiner DL, Eichelberger B. Determination of cost-effective treatment of acute otitis media from HMO records. Am J Health Syst Pharm. 1997;54:2736-40. [pmid: 9408521].
Brodie DP, Griggs JV, Cunningham K Comparative study of cefuroxime axetil suspension and amoxycillin syrup in the treatment of acute otitis media in general practice J Int Med Res 1990 18(3):235 9 2113874
Burke P, Bain J, Robinson D, Dunleavey J Acute red ear in children: controlled trial of non-antibiotic treatment in general practice BMJ 1991 303(6802):558 62 1912887 1670875
Callahan CW Cost effectiveness of antibiotic therapy for otitis media in a military pediatric clinic Pediatr Infect Dis J 1988 7(9):622 5 3140210
Cantekin EI, Mandel EM, Bluestone CD, et al Lack of efficacy of a decongestant-antihistamine combination for otitis media with effusion ("secretory" otitis media") in children. Results of a double-blind, randomized trial N Engl J Med 1983 308(6):297 301 6337322
Casselbrant ML, Brostoff LM, Cantekin EI, et al. Otitis media with effusion in preschool children. Laryngoscope. 1985;95:428-36. [pmid: 4039020].
Casselbrant ML, Kaleida PH, Rockette HE, et al Efficacy of antimicrobial prophylaxis and of tympanostomy tube insertion for prevention of recurrent acute otitis media: results of a randomized clinical trial Pediatr Infect Dis J 1992 11(4):278 86 1565551
Chalmers I, Adams M, Dickersin K, et al A cohort study of summary reports of controlled trials JAMA 1990 Mar 9 263(10):1401 5
Chamberlain JM, Boenning DA, Waisman Y, et al Single-dose ceftriaxone versus 10 days of cefaclor for otitis media Clin Pediatr 1994 33(11):642 6
Chaput de Saintonge DM, Levine DF, Savage IT, et al. Trial of three-day and ten-day courses of amoxycillin in otitis media. Br Med J (Clin Res Ed.). 1982;284:1078-81.
Chow AW, Hall CB, Klein JO, et al Evaluation of new anti-infective drugs for the treatment of respiratory tract infections Clin Infect Dis 1992 15(suppl 1):S62 88 1477253
Claessen JQ, Appelman CL, Touw-Otten FW, et al. Persistence of middle ear dysfunction after recurrent acute otitis media. Clin Otolaryngol Appl Sci. 1994;19:35-40.
Cohen R, Bingen E, Varon E, et al. Change in nasopharyngeal carriage of Streptococcus pneumoniae resulting from antibiotic therapy for acute otitis media in children. Pediatr Infect Dis J. 1997;16:555-60. [pmid: 9194104].
Cohen R, de La Rocque F, Boucherat M, et al Randomized trial comparing 5-day cefpodoxime proxetil and 8-day amoxicillin-clavulanate treatment of acute otitis media in children Medecine Et Maladies Infectieuses 1997 27(5):596 602
Cohen R, Levy C, Boucherat M, et al A multicenter, randomized, double-blind trial of 5 versus 10 days of antibiotic therapy for acute otitis media in young children J Pediatrics 1998 133(5):634 9
Coles SJ, Addlestone MB, Kamdar MK, et al. A comparative study of clarithromycin and amoxycillin suspensions in the treatment of pediatric patients with acute otitis media. Infection. 1993;21:272-8. [pmid: 8225637].
Croteau N, Hai-Vu, Pless IB, Infante-Rivard C. Trends in medical visits and surgery for otitis media among children. Am J Dis Child. 1990;144:535-8. [pmid: 2330920].
Culpepper L, Froom J Routine antimicrobial treatment of acute otitis media: Is it necessary? JAMA 1997 278(20):1643 5 9388073
Culpepper L, Long D, Sisk J. Appendix E. Report of the AHCPR Otitis Media Guideline Panel Committee for Scientific Assessment of Pittsburgh Otitis Media Research Center (OMRC) and Cantekin Publications. In: Stool SE, Berg AO, Berman S, et al. Otitis media with effusion in young children. Clinical practice guideline, Number 12. Rockville, MD: U.S. Department of Health and Human Services, Agency for Health Care Policy and Research, Public Health Service, 1994. AHCPR Publication No. 94-0622.
Damoiseaux RAMJ, van Balen RAM, Hoes AW, et al. Antibiotic treatment of acute otitis media in children under two years of age: evidence based?. Br J Clin Pract. 1998;48:1861-4.
Daniel RR Comparison of azithromycin and co-amoxiclav in the treatment of otitis media in children J Antimicrob Chemother 1993 31(Suppl E):65 71 8396099
Day JC. U. S. Bureau of the Census: Current population reports. Washington, DC: U.S. Government Printing Office, 1996; No. P25-1130.
Del Mar C, Glasziou P, Hayem M. Are antibiotics indicated as initial treatment for children with acute otitis media? A meta-analysis. BMJ. 1997 May 24;314:1526-9.
DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7:177-88. [pmid: 3802833].
Detsky AS, Naglie JG. A clinician's guide to cost-effectiveness analysis. Ann Intern Med. 1990;113:147-54. [pmid: 2113784].
Dowell SF, Butler JC, Giebink GS, et al. Acute otitis media: management and surveillance in an era of pneumococcal resistance -- a report from the Drug-resistant Streptococcus pneumoniae Therapeutic Working Group. Pediatr Infect Dis J. 1999;18:1-9. [pmid: 9951971].
Dowell SF, Marcy SM, Phillips WR, et al Principles of judicious use of antimicrobial agents for pediatric upper respiratory tract infections Pediatrics 1998 101(1, suppl):163 5
Engelhard D, Cohen D, Strauss N, et al. Randomised study of myringotomy, amoxycillin/clavulanate, or both for acute otitis media in infants. Lancet. 1989;2:141-3. [pmid: 2567903].
Feigin RD, Keeney RE, Nusrala J, et al. Efficacy of clindamycin therapy for otitis media. Arch Otolaryngol. 1973;98:27-31. [pmid: 4145912].
Feldman W, Sutcliffe T, Dulberg C Twice-daily antibiotics in the treatment of acute otitis media: trimethoprim-sulfamethoxazole versus amoxicillin-clavulanate CMAJ 1990 142(2):115 8 2403833 1451732
Fletcher RH, Fletcher SW, Wagner EH. Clinical epidemiology -- the essentials. Baltimore: Williams & Wilkins, 1982.
Foshee WS, Qvarnberg Y. Comparative United States and European trials of loracarbef in the treatment of acute otitis media. Pediatr Infect Dis J. 1992;11:S12-9. [pmid: 1513607].
Fried VM. Ambulatory health care visits by children: principal diagnosis and place of visit. National Center for Health Statistics. Vital Health Stat 13 (137). Hyattsville, MD: U.S. Department of Health and Human Services, 1998.
Froom J, Culpepper L, Bridges-Webb C, et al. Effect of patient characteristics and disease manifestation on the outcome of acute otitis media at 2 months. Arch Fam Med. 1993;2:841-6. [pmid: 8111513].
Froom J, Culpepper L, Grob P, et al. Diagnosis and antibiotic treatment of acute otitis media: report from International Primary Care Network. BMJ. 1990;300:582-6. [pmid: 2108756]. [pmcid: 1662354].
Froom J, Culpepper L, Jacobs M, et al Antimicrobials for acute otitis media? A review from the International Primary Care Network BMJ 1997 315(7100):98 102 9240050
Fry J. Antibiotics in Acute Tonsillitis and Acute Otitis Media. Br Med J. 1958;2:883-6. [pmid: 13572934].
Ganiats TG, Schneiderman LJ. Principles of cost-effectiveness research. J Fam Pract. 1988;27:77-84. [pmid: 3134508].
Gates GA. Cost-effectiveness considerations in otitis media treatment. In: Lim D, Bluestone CD, Casselbrant M, Klein J, Ogra P, eds. Proceedings of the sixth international symposium: Recent advances in otitis media, 1996a:1-4.
Gates GA. Cost-effectiveness considerations in otitis media treatment. Otolaryngol Head Neck Surg. 1996b;114:525-30. [pmid: 8643261].
Gebhart DE. Tympanostomy tubes in the otitis prone child. Laryngoscope. 1981;91:849-66. [pmid: 7017311].
Giebink GS, Batalden PB, Russ JN, Le CT Cefaclor v amoxicillin in treatment of acute otitis media Am J Dis Child 1984 138(3):287 92 6367432
Glass RI, Lew JF, Gangarosa RE, LeBaron CW, Ho M-S. Estimates of the morbidity and mortality from diarrheal diseases in American children. J Pediatr. 1991;118:S27-33. [pmid: 2007954].
Gold MR, Patrick DL, Torrance GW, et al. Identifying and valuing outcomes. In: Gold MR, Siegel GE, Russell LB, Weinstein MC, eds. Cost-effectiveness in health and medicine. New York: Oxford University Press, 1996:82-134.
Gonzalez ML (ed). Socioeconomic aspects of medical practice 1996. Chicago: American Medical Association; 1996.
Gonzalez C, Arnold JE, Woody EA, et al. Prevention of recurrent acute otitis media: Chemoprophylaxis versus tympanostomy tubes. Laryngoscope. 1986;96:1330-4. [pmid: 3537596].
Gooch WM, 3rd, Blair E, Puopolo A, et al. Effectiveness of five days of therapy with cefuroxime axetil suspension for treatment of acute otitis media. Pediatr Infect Dis J. 1996;15:157-64. [pmid: 8822290].
Green SM, Rothrock SG Single-dose intramuscular ceftriaxone for acute otitis media in children Pediatrics 1993 91(1):23 30 8416502
Haggard MP, Smith SC. Impact of otitis media on child quality of life. In: Lim DJ, Bluestone CD, directors. Abstracts of the seventh international symposium on recent advances in otitis media, 1999a:7.
Haggard MP and Smith SC. Impact of otitis media on child quality of life. In: Rosenfeld RM and Bluestone CD, eds. Evidence-based otitis media. Saint Louis, BC: Decker Inc., 1999b:375-98.
Hall MJ, Lawrence L. Ambulatory surgery in the United States, 1995. Advance data from vital and health statistics; no. 296. Hyattsville, MD: National Center for Health Statistics. 1997; PHS publication no. 98-1250 8-0144.
Halsted C, Lepow ML, Balassanian N, et al Otitis media: microbiology and evaluation of therapy Ann NY Acad Sci 1967 145(2):372 8 4397881
Halsted C, Lepow ML, Balassanian N, et al. Otitis media. Clinical observations, microbiology, and evaluation of therapy. Am J Dis Child. 1968;115:542-51. [pmid: 4384577].
Hayden, GF. Acute suppurative otitis media in children: diversity of clinical diagnostic criteria. Clin Pediatr. 1981;20:99-104.
Hendrickse WA, Kusmiesz H, Shelton S, Nelson JD Five vs. ten days of therapy for acute otitis media Pediatr Infect Dis J 1988 7(1):14 23 3277153
Hoberman A, Paradise JL, Burch DJ, et al Equivalent efficacy and reduced occurrence of diarrhea from a new formulation of amoxicillin/clavulanate potassium (Augmentin) for treatment of acute otitis media in children Pediatr Infect Dis J 1997 16(5):463 70 9154538
Hoberman A, Paradise JL, Reynolds EA, et al Efficacy of Auralgan for treating ear pain in children with acute otitis media Arch Pediatr Adolesc Med 1997 151(7):675 8 9232040
Howie VM, Dillard R, Lawrence B In vivo sensitivity test in otitis media: efficacy of antibiotics Pediatrics 1985 75(1):8 13 3871251
Howie VM, Owen MJ. Bacteriologic and clinical efficacy of cefixime compared with amoxicillin in acute otitis media. Pediatr Infect Dis J. 1987;6:989-91. [pmid: 3696839].
Howie VM, Ploussard JH Efficacy of fixed combination antibiotics versus separate components in otitis media. Effectiveness of erythromycin estrolate, triple sulfonamide, ampicillin, erythromycin estolate-triple sulfonamide, and placebo in 280 patients with acute otitis media under two and one-half years of age Clin Pediatr 1972 11(4):205 14
Ingvarsson L, Lundgren K. The duration of penicillin treatment of acute otitis media in children. Transactions of the 21st Congress of the Scandinavian Oto Laryngological Society; 1981 Aug 16-19; Turku, Finland; 1981. p. 112-114.
Ingvarsson L, Lundgren K Penicillin treatment of acute otitis media in children. A study of the duration of treatment Acta Otolaryngol 1982 94(3-4):283 7 6816006
Jacobson JA, Metcalf TJ, Parkin JL, et al Evaluation of cefaclor and amoxycillin in the treatment of acute otitis media Postgrad Med J 1979 55(Suppl 4):39 41
Jadad AR, Moore AR, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17:1-12. [pmid: 8721797].
Johnson CE, Carlin SA, Super DM, et al Cefixime compared with amoxicillin for treatment of acute otitis media J Pediatr 1991 119(1 (Pt 1)):117 22 1906097
Jones R, Bain J. Three-day and seven-day treatment in acute otitis media: a double-blind antibiotic trial. J Royal Coll Gen Practitioners. 1986;36:356-8.
Kafetzis DA, Astra H, Mitropoulos L. Five-day versus ten-day treatment of acute otitis media with cefprozil. Eur J Clin Microbiol Infect Dis. 1997;16:283-6. [pmid: 9177961].
Kaleida PH, Casselbrant ML, Rockette HE, et al Amoxicillin or myringotomy or both for acute otitis media: Results of a randomized clinical trial Pediatrics 1991 87(4):466 474 2011422
Kaleida PH, Stool SE. Assessment of otoscopists' accuracy regarding middle-ear effusion: otoscopic validation. Am J Dis Child. 1992;146:433-5. [pmid: 1558077].
Kaplan B, Wandstrat TL, Cunningham JR. Overall cost in the treatment of otitis media. Pediatr Infect Dis J. 1997;16:S9-11. [pmid: 9041621].
Kara CO, Ozuer MZ, Kilic I, et al Comparison of amoxicillin with second and third generation cephalosporins in the treatment of acute otitis media Infez Med 1998 6(2):93 5 12750572
Karma PH, Penttila MA, Sipila MM, et al Otoscopic diagnosis of middle ear effusion in acute and non-acute otitis media. I. The value of different otoscopic findings Int J Pediatr Otorhinolaryngol 1989 17(1):37 49 2707977
Khurana CM A multicenter, randomized, open label comparison of azithromycin and amoxicillin/clavulanate in acute otitis media among children attending day care or school Pediatr Infect Dis J 1996 15(9 Suppl):S24 9 8878243
Klein JO. Protecting the therapeutic advantage of antimicrobial agents used for otitis media. Pediatr Infect Dis J. 1998;17:571-5. [pmid: 9655563].
Klein JO, Teele DW, Rosner M, et al Epidemiology of otitis media in Boston children observed from birth to 7 years of age Ann Otol Rhinol Laryngol 1990 149(Suppl):27 8
Kozak LJ, Hall MJ, Pokras R, Lawrence L. Ambulatory Surgery in the United States, 1994. Advance data from vital and health statistics, No. 283. Hyattsville, MD: National Center for Health Statistics, 1997.
Kozyrskyj AL, Hildes-Ripstein GE, Longstaffe SEA, et al Treatment of acute otitis media with a shortened course of antibiotics: A meta-analysis JAMA 1998 279(21):1736 42 9624028
Landholt TF, Kotschwar TR. A pharmacoeconomic comparison of amoxicillin/clavulanate and cefpodoxime proxetil in the treatment of acute otitis media. Clin Ther. 1994;16:327-33. [pmid: 8062326].
Laupacis A, Feeny D, Detsky AS, Tugwell PX. How attractive does a new technology have to be to warrant adoption and utilization? Tentative guidelines for using clinical and economic evaluations. Can Med Assoc J. 1992;146:473-81. [pmid: 1306034]. [pmcid: 1488412].
Laxdal OE, Merida J, Jones RH Treatment of acute otitis media: a controlled study of 142 children Can Med Assoc J 1970 102(3):263 8 4190002
Leigh AP, Robinson D, Millar ED A general practice comparative study of a new third-generation oral cephalosporin, cefixime, with amoxycillin in the treatment of acute paediatric otitis media Br J Clin Pract 1989 43(4):140 3 2686744
Lenoski EF, Wingert WA, Wehrle PF Drug trials in acute otitis media Curr Ther Res Clin Exp 1968 10(12):631 9 4972759
Marchant C, Shurin PA. Antibacterial therapy for acute otitis media: a critical analysis. Rev Infect Dis. 1982;4:506-13. [pmid: 7051243].
Marchant CD, Shurin PA, Turczyk VA, Wasikowski DE, Tutihasi MA, Kinney SE. Course and outcome of otitis media in early infancy: a prospective study. J Pediatr. 1984;104:826-31. [pmid: 6539373].
McCracken GH. Treatment of acute otitis media in an era of increasing microbial resistance. Pediatr Infect Dis J. 1998;17:576-9. [pmid: 9655564].
McLinn SE. Recurrence of otitis media after antibiotic therapy: comparison of cephradine and amoxycillin. J Int Med Res. 1979;7:546-50. [pmid: 391628].
McLinn SE Cefaclor in treatment of otitis media and pharyngitis in children Am J Dis Child 1980 134(6):560 3 6770673
McLinn SE Randomized, open label, multicenter trial of cefixime compared with amoxicillin for treatment of acute otitis media with effusion Pediatr Infect Dis J 1987 6(10):997 1001 3320928
McLinn S A multicenter, double blind comparison of azithromycin and amoxicillin/clavulanate for the treatment of acute otitis media in children Pediatr Infect Dis J 1996 15(9 Suppl):S20 3 8878242
Meistrup-Larsen KI, Sorensen H, Johnsen NJ, et al. Two versus seven days penicillin treatment for acute otitis media. A placebo controlled trial in children. Acta Otolaryngol. 1983;96:99-104. [pmid: 6412508].
Moher D, Jadad AR, Nichol G, et al. Assessing the quality of randomized controlled trials: an annotated bibliography of scales and checklists. Control Clin Trials. 1995;16:62-73. [pmid: 7743790].
Moher D, Jones A, Cook DJ, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352:609-13. [pmid: 9746022].
Mygind N, Meistrup-Larsen KI, Thomsen J, Thomsen VF, Josefsson K, Sorensen H Penicillin in acute otitis media: a double-blind placebo-controlled trial Clin Otolaryngol Appl Sci 1981 6(1):5 13
Nassar WY, Allen BM. A double-blind comparative clinical trial of cephalexin and ampicillin in the treatment of childhood acute otitis media. Curr Med Res Opin. 1974;2:198-203. [pmid: 4841306].
Current estimates from the National Health Interview Survey, 1982. Vital Health Stat 10 (150). Hyattsville, MD: U.S. Department of Health and Human Services, 1985.
Nelson C, Woodwell D. National Ambulatory Medical Care Survey: 1993 Summary. National Center for Health Statistics. Vital Health Stat 13 (136). Hyattsville, MD: U.S. Department of Health and Human Services, 1998.
Nilson BW, Poland RL, Thompson RS, et al Acute otitis media: treatment results in relation to bacterial etiology Pediatrics 1969 43(3):351 8 4975539
Oh PI, Maerov P, Pritchard D, Knowles SR, Einarson TR, Shear NH. A cost-utility analysis of second-line antibiotics in the treatment of acute otitis media in children. Clin Ther. 1996;18:160-82. [pmid: 8851461].
Ostfeld F, Segal J, Kaufstein M, Gelernter I. Management of acute otitis media without primary administration of systemic antimicrobial agents. In: Proceedings of the fourth international symposium on recent advances in otitis media, 1988: 235-9.
Owen MJ, Anwar R, Nguyen HK, et al Efficacy of cefixime in the treatment of acute otitis media in children Am J Dis Child 1993 147(1):81 6 8418608
Oxman AD, Cook DJ, Guyatt GH Users' guides to the medical literature: VI. How to use an overview JAMA 1994 272(17):1367 71 7933399
Paparella, MM, Bluestone CD, Arnold W, et al 1A. Definition and Classification Ann Otol Rhinol Laryngol 1985 94(suppl 116):8 9
Paradise JL. Short-course antimicrobial treatment for acute otitis media: not best for infants and young children. JAMA. 1997;278:1640-42. [pmid: 9388072].
Paradise JL, Bluestone CD, Rogers KD, et al Efficacy of adenoidectomy for recurrent otitis media in children previously treated with tympanostomy-tube placement. Results of parallel randomized and nonrandomized trials JAMA 1990 263(15):2066 73 2181158
Paradise JL, Rockette HE, Colborn DK, et al. Otitis media in 2253 Pittsburgh-area infants: prevalence and risk factors during the first two years of life. Pediatrics. 1997;99:318-33. [pmid: 9041282].
Pestalozza G, Cioce C, Facchini M. Azithromycin in upper respiratory tract infections: a clinical trial in children with otitis media. Scand J Infect Dis Suppl. 1992;83:22-5. [pmid: 1336892].
Montvale, NJ: Medical Economics Company, 1998.
Ploussard JH Evaluation of five days of cefaclor vs. ten days of amoxicillin therapy in acute otitis media Curr Ther Res 1984 36(Oct):641 5
Pogue J, Yusuf S. Overcoming the limitations of current meta-analysis of randomised controlled trials. Lancet. 1998;351:47-52. [pmid: 9433436].
Principi N Multicentre comparative study of the efficacy and safety of azithromycin compared with amoxicillin/clavulanic acid in the treatment of paediatric patients with otitis media Eur J Clin Microbiol Infect Dis 1995 14(8):669 76 8565983
Principi N, Marchisio P Cefixime vs. amoxicillin in the treatment of acute otitis media in infants and children Drugs 1991 42(Suppl 4):25 9
Principi N, Marchisio P, Bigalli L, Massironi E Amoxicillin twice daily in the treatment of acute otitis media in infants and children Eur J Pediatr 1986 145(6):522 5 3545844
Puczynski MS, Stankiewicz JA, O'Keefe JP Single dose amoxicillin treatment of acute otitis media Laryngoscope 1987 97(1):16 8 3796171
Pukander JS, Jero JP, Kaprio EA, et al. Clarithromycin vs. amoxicillin suspensions in the treatment of pediatric patients with acute otitis media. Pediatr Infect Dis J. 1993;12:S118-21. [pmid: 8295812].
Rodriguez WJ, Schwartz RH, Sait T, et al. Erythromycin-sulfisoxazole vs amoxicillin in the treatment of acute otitis media in children. A double-blind, multiple-dose comparative study. Am J Dis Child. 1985;139:766-70. [pmid: 3895889].
Rodriguez AF. An open study to compare azithromycin with cefaclor in the treatment of children with acute otitis media. J Antimicrob Chemother. 1996;37:63-9. [pmid: 8818847].
Rosenfeld, RM. An evidence-based approach to treating otitis media. Pediatr Clin North Am. 1996;43:1165-81. [pmid: 8973506].
Rosenfeld RM. Natural history of untreated otitis media. In: Rosenfeld RM, Bluestone CD, eds. Evidence-based otitis media. Saint Louis, BC: Decker Inc, 199a:157-77.
Rosenfeld RM. What to expect from medical therapy. In: Rosenfeld RM, Bluestone CD, eds. Evidence-based otitis media. Saint Louis, BC: Decker Inc., 1999b:179-205.
Rosenfeld RM, Goldsmith AJ, Tetlus L, Balzano A Quality of life for children with otitis media Arch Otolaryngol Head Neck Surg 1997 123(10):1049 54 9339979
Rosenfeld RM, Vertrees JE, Carr J, et al Clinical efficacy of antimicrobial drugs for acute otitis media: Meta-analysis of 5400 children from thirty-three randomized trials J Pediatr 1994 124(3):355 67 8120703
Rubenstein MM, McBean JB, Hedgecock LD, Stickler GB. The treatment of acute otitis media in children.III. A third clinical trial. Am J Dis Child. 1965;109:308-13. [pmid: 14261009].
Russell LB, Siegel JE, Daniels N, et al. Cost-effectiveness analysis as a guide to resource allocation in health: roles and limitations. In: Gold MR, Siegel JE, Russell LB, Weinstein MC, eds. Cost-effectiveness in health and medicine. New York: Oxford University Press, 1996:3-24.
Sackett DL. How to read clinical journals. V: To distinguish useful from useless or even harmful therapy. Can Med Assoc J. 1981;124:1156-62. [pmid: 7016293]. [pmcid: 1705333].
Sackett DL, Haynes RB, Tugwell P. Clinical epidemiology: A basic science for clinical medicine. Boston: Little, Brown and Company, 1985.
Schaad UB Multicentre evaluation of azithromycin in comparison with co-amoxiclav for the treatment of acute otitis media in children J Antimicrob Chemother 1993 31(Suppl E):81 8 8396101
Schappert SM. Office visits for otitis media: United States, 1975-90. Advance data from vital and health statistics. Hyattsville, MD: National Center for Health Statistics,1992.
Schappert SM. National ambulatory medical care survey: 1994 summary. Advance data from vital and health statistics. Hyattsville, MD: National Center for Health Statistics, 1996.
Schappert SM. Ambulatory care visits to physician offices, hospital outpatient departments, and emergency departments: United States, 1995. National Center for Health Statistics. Vital Health Stat 13 (129). Hyattsville, MD: U.S. Department of Health and Human Services, 1997.
Scholz H, Noack R Multicenter, randomized, double-blind comparison of erythromycin estolate versus amoxicillin for the treatment of acute otitis media in children. AOM Study Group Eur J Clin Microbiol Infect Dis 1998 17(7):470 8 9764549
Schulz, KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273:408-12. [pmid: 7823387].
Senturia BH, Paparella MM, Lowery HW, et al Definition and Classification Ann Otol Rhinol Laryngol 1980 89(suppl 69):4 8
Shepard DS, Thompson MS. First principles of cost-effectiveness analysis in health. Public Health Rep. 1979;94:535-43. [pmid: 117509]. [pmcid: 1431742].
Simon MW Five- vs. 10-day treatment of acute otitis media with ceftibuten in infants and children Adv Ther 1997 14(6):312 7
Stechenberg BW, Anderson D, Chang MJ, et al. Cephalexin compared to ampicillin treatment of otitis media. Pediatrics. 1976;58:532-6. [pmid: 787913].
Stickler GB, Rubenstein NM, McBean JB, et al. Treatment of acute otitis media in children IV.A fourth clinical trial. Am J Dis Child. 1967;114:123-30. [pmid: 4952777].
Stool SE, Berg AO, Berman S, et al. Otitis media with effusion in young children. Clinical practice guideline, Number 12. Rockville, MD: Agency for Health Care Policy and Research, Public Health Service, U.S. Department of Health and Human Services, July 1994a. AHCPR Publication No. 94-0622.
Stool SE, Berg AO, Berman S, et al. Managing otitis media with effusion in young children. Quick reference guide for clinicians. Agency for Health Care Policy and Research, Public Health Service, U.S. Department of Health and Human Services, July 1994b. AHCPR Publication No. 94-0623.
Stool SE, Field MJ The impact of otitis media Pediatr Infect Dis J 1989 8(Suppl):S11 4 2494641
Taketomo CK (editor). Children's Hospital Los Angeles pediatric dosing handbook and formulary. Hudson, Ohio: Lexi-Comp, Inc., 1999.
Teele DW, Klein JO, Chase C, et al. Otitis media in infancy and intellectual ability, school achievement, speech, and language at age 7 years. Greater Boston Otitis Media Study Group. J Infect Dis. 1990;162:685-94. [pmid: 2387994].
Teele DW, Klein JO, Rosner BA Epidemiology of otitis media in children Ann Otol Rhinol Laryngol 1980 89(Suppl 68):5 6
Teele DW, Klein JO, Rosner BA. Epidemiology of otitis media during the first seven years of life in children in greater Boston: a prospective, cohort study. J Infect Dis. 1989;160:83-94. [pmid: 2732519].
Thalin A, Densert O, Larsson A, et al. Is penicillin necessary in the treatment of acute otitis media? In: Proceedings of the international conference on acute and secretory otitis media, part I. 1986:441-6. [pmcid: 322875].
Tilyard MW, Dovey SM, Walker SA Otitis media treatment in New Zealand general practice N Z Med J 1997 110(1042):143 5 9152355
Townsend E. Otitis media in private practice. NY State J Med. 1964;64:1591-97.
Trout KS. How to read clinical journals: IV. To determine etiology or causation. Can Med Assoc J. 1981;124:985-90. [pmid: 7260801]. [pmcid: 1705401].
Tugwell P. How to read clinical journals: III. To learn the clinical course and prognosis of disease. Can Med Assoc J. 1981;124:869-72. [pmid: 7214286]. [pmcid: 1705372].
Uhari M, Kontiokari T, Niemela M A novel use of xylitol sugar in preventing acute otitis media Pediatrics 1998 102(4):879 84 9755259
Uhari M, Mantysaari K, Niemela M. A meta-analytic review of the risk factors for acute otitis media. Clin Infect Dis. 1996;22:1079-83. [pmid: 8783714].
Consumer prices-all urban consumers. Econ Indic. Washington D.C.: Government Printing Office, 1999, 23.
Van Buchem FL, Dunk JH, van't Hof MA Therapy of acute otitis media: myringotomy, antibiotics, or neither? A double-blind study in children Lancet 1981 2(8252):883 7 6117681
Van Buchem FL, Peeters MF, van't Hof MA. Acute otitis media: a new treatment strategy. Br Med J (Clin Res Ed). 1985;290:1033-7.
Varsano I, Frydman M, Amir J, et al Single intramuscular dose of ceftriaxone as compared to 7-day amoxicillin therapy for acute otitis media in children. A double-blind clinical trial Chemotherapy 1988 34(Suppl 1):39 46 3246170
Varsano I, Volovitz B, Horev Z, et al. Intramuscular ceftriaxone compared with oral amoxicillin-clavulanate for treatment of acute otitis media in children. Eur J Pediatr. 1997;156:858-63. [pmid: 9392401].
Weinstein MC, Fineberg HV. Clinical decision analysis. Philadelphia: WB Saunders, 1980; ch. 8.
Weiss JC, Melman ST. Cost-effectiveness in the choice of antibiotics for the initial treatment of otitis media in children: a decision analysis approach. Pediatr Infect Dis J. 1988;7:23-26. [pmid: 3124072].
White LL, Holimon TD, Tepedino JT, et al. Antimicrobials prescribed for otitis media in a pediatric Medicaid population. Am J Health Syst Pharm. 1996;53:2963-69. [pmid: 8974159].
Woodwell DA. National ambulatory medical care survey. Advance data from vital and health statistics. Hyattsville, MD: National Center for Health Statistics, 1997a.
Woodwell DA. National ambulatory medical care survey: 1995 summary. Advance data from vital and health statistics. Hyattsville, MD: National Center for Health Statistics, 1997b.
Woodwell DA, Schappert SM. National ambulatory medical care survey: 1993 summary. Advance data from vital and health statistics. Hyattsville, MD: National Center for Health Statistics, 1995.
Yawn BP, Yawn RA, Lydick E. The relative community burden of otitis media and varicella. Clin Ther. 1996;18:877-86. [pmid: 8930431].
Zimmerman DR, Allegra JR, Cody RP. The epidemiology of pediatric visits to New Jersey general emergency departments. Pediatr Emerg Care. 1998;14:112-5. [pmid: 9583391].