# Future Research

## Key Questions

Randomized controlled studies of high internal validity and adequate generalizability are still needed to adequately assess the key questions asked at the start of this systematic review. There is still a need to adequately address the role of antibiotics in the initial treatment of AOM in children compared to placebo or observational treatment, especially in terms of various influencing factors such as age and otitis-prone status. Close monitoring of patients in these studies with a priori plans for appropriate intervention should allay any concerns about suppurative complications and should also be a focus of research. Strong consideration should be given to establishing uniform criteria -- based on bacterial spectrum, pharmacokinetics, bioavailability, minimum inhibitory concentrations to specific bacteria, and other relevant factors, including cost -- to guide investigators in the comparison of antibiotics. In addition, bacterial resistance is an increasingly important factor and should be considered in future studies comparing antibiotics with one another in treating AOM.

## Definition and Diagnostic Criteria

It is critical to establish a definition of AOM that is acceptable to both researchers and practitioners. The diversity of definitions that presently exists makes it difficult to generalize findings or to apply findings to specific patient populations. The tasks in this area are to determine what terms are needed and uniform definitions for those terms. Accuracy of diagnosis also must be investigated and is an important research issue because comparability of assessment across studies depends on accuracy of diagnosis as the primary inclusion criteria for subject recruitment. In addition, all terms describing the specific structures, processes, and outcomes related to the management of AOM must be defined to facilitate rational decisionmaking with respect to this clinical condition.

## Quality of Studies

Future studies on antibiotics in the treatment of AOM should strengthen the factors related to the internal validity of the studies. In particular, assignment of subjects to treatment groups should be performed using appropriate methods of randomization. Studies also should be conducted in a double-blind fashion: this is a particular weakness in the studies in this evidence-based analysis. Relative to both these issues is the maintenance of allocation concealment. Studies should account for all subject withdrawals and use appropriate denominators in analysis.

Editors of study reports should require that documentation of studies allow the reader to readily assess the internal validity of the study. Several groups, culminating in the Consolidated Standards of Reporting Trials discussions, have recommended guidelines for reporting controlled trials (Begg, Cho, Eastwood, et al., 1996), and controlled trials on AOM should follow these guidelines for reporting. Improved reporting on subject characteristics, treatment description, and outcome definition would increase the generalizability of findings and improve the entire process of evidence synthesis used in this report.

## Study Subjects

The issue of subject selection must be a conscientious balance between the generalizability of findings and the applicability of findings to specific patients or patient populations rather than a matter of convenience, even in the setting of a randomized controlled trial.

Future studies should try to include sufficient numbers of subjects in randomized controlled trials to allow generalization of the findings to other patient populations. Future studies also should include sufficient variation in study population to evaluate important influencing factors such as age and otitis-prone state. The data should be available for secondary analysis to provide results that may be more applicable to more specific patient populations (e.g., based on age or otitis-prone status).

## Study Outcomes

In future studies, outcomes should be defined in detail; agreed upon by researchers, practitioners, and patients; and adhered to in all forms of communication to promote rational discussions of the treatment of AOM. All outcomes should be uniformly measured in all studies on AOM as the resources of the investigator allow. They also should be prioritized so that investigators with limited resources can decide which outcomes to measure. If pain and fever remain as relevant AOM outcomes, the effect of analgesics and antipyretics also should be considered. Future studies should assess the long-term outcomes of AOM, as well as the short-term outcomes that most studies presently concentrate on. To make informed decisions in the treatment of AOM, information must be available on all relevant outcomes and not just those that are most convenient to measure. Because bacterial resistance to antibiotics is growing, bacteriologic outcomes should be considered along with clinical outcomes. Finally, future studies are needed to assess the cost-effectiveness of alternative treatments of AOM using a societal perspective that looks at direct and indirect costs and also incorporates the viewpoint of the patient and family and measures of quality of life and functional status.