# Conclusions

## Natural History

### Observation or Placebo

It is difficult to come to conclusions about the natural history of AOM without intervention because of the few studies available -- less than half are of adequate quality and most of the literature lacks uniformity in the definition of outcomes, the specific outcomes monitored, and the time of measurement. In addition, most of the studies did not report results, including adequate information on denominators, stratified by the influencing factors of age and otitis-prone state, thought to be of importance by the Technical Expert Panel. The studies eligible for the natural history question represent a heterogeneous collection of investigations with respect to the primary influencing factors of age and otitis-prone state. Most of the studies report close followup of patients and clinical criteria for administering antibiotics to the placebo or observational group in the case of persistent or worsening symptoms or complications. Few patients in the placebo or observational groups appeared to require antibiotics.

Clinical failure rate at 24-48 hours was 7.7 percent for nonsevere cases of AOM not treated with antibiotics in the study by Kaleida, Casselbrant, Rockette, et al. (1991); at 24-72 hours, clinical failure occurred in 26 percent of children with AOM not treated with antibiotics in Halsted, Lepow, Balassanian, et al. (1968). Pooling the data on failure rates from 4 to 7 days yielded an estimate of 22.2 percent (three studies; 220 children; 95 percent CI, 10.1 percent and 34.3 percent); that is, 77.8 percent of these children not initially treated with antibiotics for AOM would have clinical resolution. The pooled estimate for failure from 1 to 7 days yielded an estimate of 18.9 percent (five studies; 739 children; 95 percent CI, 9.9 percent and 28.0 percent); that is, 81.1 percent of these children would have clinical resolution. Rosenfeld (1999a) had estimated that 73 percent of children with AOM not initially treated with antibiotics would have clinical resolution by 7-14 days after diagnosis. Failures as defined by recurrences and other factors, including presence of serous otitis media in one study (Townsend, 1964), may accrue up to a year from the onset of the initial episode of AOM; those estimates were as low as 5.8 percent in the cohort study by Townsend (1964) and as high as 27.1 percent in the randomized controlled trial by Kaleida, Casselbrant, Rockette, et al. (1991). The proportion with pain and fever in children with AOM not treated with antibiotics decreased rapidly in the time periods reported. Van Buchem, Dunk, van't Hof, et al. (1981) reported 28 percent had pain after 24 hours, and Burke, Bain, Robinson, et al. (1991) reported that 48 percent had pain at 2 days. At 5-7 days, 25 percent (Burke, Bain, Robinson, et al., 1991) reported pain and at more than 7 days, 10 percent of children still reported pain (van Buchem, Dunk, van't Hof, et al., 1981.) A similar discrepancy in findings existed for the presence of fever: 0 percent at 2-7 days (Howie and Ploussard, 1972), and 20 percent at 2 days, and 11 percent at 5-7 days (Burke, Bain, Robinson, et al., 1991).

In studies reporting on pain or fever, most children with AOM were without either symptom by 3 days (Appleman, Claessen, Touw-Otten, et al., 1991; Kaleida, Casselbrant, Rockette, et al., 1991; Mygind, Meistrup-Larsen, Thomsen, et al., 1981; van Buchem, Dunk, van't Hof, et al., 1981). As estimated by Rosenfeld (1999a), the pooled data indicate that 59 percent (three studies; 315 children; 95 percent CI, 53 percent and 65 percent) of children not treated with antibiotics did not have pain or fever within 24 hours of diagnosis of AOM, 87 percent (five studies; 808 children; 95 percent CI, 84 percent and 89 percent) of children did not have pain or fever by 2-3 days, and 88 percent (five studies; 503 children; 95 percent CI, 85 percent and 91 percent) of children did not have pain or fever by 4-7 days.

Asymptomatic middle ear effusion was confirmed as a common condition following AOM in children not treated with antibiotics. At 3 months, the cited studies show 24 percent (Mygind, Meistrup-Larsen, Thomsen, et al., 1981) and 28 percent (Burke, Bain, Robinson, et al., 1991) of children with middle ear effusion. The evidence suggests that younger children compared with older children had a greater likelihood of failing to meet the definitions of clinical success or resolution when not treated with antibiotics for AOM. The threshold appears to be sometime around 2-3 years of age based on the studies of Laxdal, Merida, and Jones (1970) and Kaleida, Casselbrant, Rockette, et al. (1991). Only one study looked at the possible effect of otitis-prone state (defined as more than two episodes of prior AOM) and found little difference in rates of treatment failure at 1-week evaluation (Burke, Bain, Robinson, et al., 1991). The one study that looked at age and resolution of pain and fever suggests a significant association with age: 58 percent of those under 2 years of age with pain or fever at more than 3 days compared with 7 percent of children 2 years or older among those not treated with antibiotics for AOM (Appelman, Claessen, Touw-Otten, et al., 1991). In the one study that looked at the presence of middle ear effusion in relation to age in children with AOM not treated with antibiotics, the findings suggest a greater propensity to middle ear effusion with younger age (Kaleida, Casselbrant, Rockette, et al., 1991).

The available evidence on natural history of AOM shows that few episodes of mastoiditis or other suppurative complications were reported in children with AOM not initially treated with antibiotics. It is important to note that the children in these studies had close followup and intervention as appropriate. In these studies, the number of suppurative complications reported was comparable whether or not the child was initially treated with antibiotic.

## Antibiotics vs. No Antibiotics

### Previous Meta-Analyses

Del Mar, Glasziou, and Hayem (1997) found favorable rate differences in the children with AOM treated with antibiotics in terms of pain at 2-7 days (41 percent) (95 percent CI, 14 percent and 60 percent), and contralateral otitis media (43 percent) (95 percent CI, 9 percent and 64 percent). They did not find any differences in pain at 24 hours, tympanic membrane perforation, vomiting/diarrhea/rash, 1-month tympanometry, or recurrent AOM. Rosenfeld, Vertrees, Carr, et al. (1994) found a rate difference of 12.9 percent (95 percent CI, 8.2 percent and 19.2 percent) in favor of children with AOM treated with aminopenicillins compared with those not treated with antibiotics, and 13.7 percent (95 percent CI, 8.2 percent and 19.2 percent) in favor of children treated with any antibiotic compared to no antibiotic. Rosenfeld (1999a) found that pain and fever relief at 24 hours was not related to antibiotic use in children with AOM (rate difference of 0 percent, 95 percent CI, −7 percent and 8 percent), but pain and fever relief at 2 days was improved by 4 percent (95 percent CI, 2 percent and 7 percent) with antibiotic use. The difference in pain and fever relief at 4-7 days, however, was not significant. Clinical resolution at 7-14 days was 13 percent (95 percent CI, 8 percent and 19 percent) higher in those on antibiotics vs. those not on antibiotics.

### Ampicillin or Amoxicillin vs. Placebo or Observation

The present analysis adds to the prior meta-analytic studies (Del Mar, Glasziou, and Hayem, 1997; Rosenfeld, 1999b; Rosenfeld, Vertrees, Carr, et al., 1994) by assessing the efficacy of specific antibiotics. Because of differences in definitions of treatment failure and the units of analysis, sensitivity analyses were performed, and the results indicate that ampicillin or amoxicillin was beneficial in the treatment of AOM compared with placebo (with pooled rate differences of −9.7 percent to −12.9 percent). The results were generally insensitive to the studies included, except that as the number of studies decreased, the 95 percent confidence limits increased. About eight children with AOM would need to be treated with ampicillin or amoxicillin to prevent a case of clinical failure. Subgroup analyses based on age or otitis-prone status were not possible.

### Other Antibiotics vs. No Antibiotics Comparisons

Other treatment regimens we compared to placebo or observational treatment included: amoxicillin-clavulanate, pencillin G plus sulfisoxazole, penicillin V, erythromycin estolate, triple sulfonamide, and erythromycin estolate plus triple sulfonamide.

In general, there appears to be a trend of modest improvement in specific outcomes with antibiotic administration compared to placebo or observational treatment in terms of pain and fever and other symptom resolution and presence of exudate. No statements can be made regarding the effect of age or otitis-prone status on these comparisons.

## Antibiotic vs. Antibiotic

### Penicillin vs. Ampicillin or Amoxicillin

The results of the three individual studies showed a pooled rate difference minimally favoring ampicillin or amoxicillin compared with penicillin, although each was statistically insignificant. The quantitative synthesis affirms that the effects of penicillin and ampicillin or amoxicillin on treatment of AOM are not different based on these three studies. The three studies do not allow for subgroup meta-analysis of the data by age or otitis-prone status, although data from one of the studies suggests that ampicillin may be more effective than penicillin in children under 6 years of age (Laxdal, Merida, and Jones, 1970). Another study suggests that ampicillin was more effective than penicillin if Haemophilus influenzae grew from culture (Nilson, Poland, Thompson, et al., 1969), but this finding must be tempered by the fact that this study was conducted 30 years ago -- before the recent rise in bacterial resistance to antimicrobial agents.

### Cefaclor vs. Ampicillin or Amoxicillin

The meta-analyses looking at cefaclor vs. ampicillin or amoxicillin show statistically insignificant rate differences in terms of failure at 3-7 days and at 5-21 days. This finding is in accord with the results of the individual studies. One study suggests that this finding also is true in infants 1-3 months of age (Berman and Lauer, 1983). The reported data from these five studies, however, do not allow for any further subgroup analysis on age or otitis-prone status.

### Cefixime vs. Ampicillin or Amoxicillin

The meta-analyses comparing cefixime to ampicillin or amoxicillin demonstrate insignificant rate differences with respect to failure at 10-15 days, recurrence rate at 3-5 weeks, incidence of vomiting, and incidence of rash. The incidence of diarrhea was higher among those on cefixime and was statistically significant. Twelve children with AOM would need to be treated with ampicillin or amoxicillin rather than cefixime to avoid a case of diarrhea. Subgroup analysis based on age or otitis-prone status was not possible using these five studies.

### Other Antibiotics vs. Ampicillin or Amoxicillin Comparisons

None of the following antibiotics showed any difference in failure rates measured at various points in time compared with ampicillin or amoxicillin: cephalexin, cephradine, cerufoxime-axetil, ceftriaxone, loracarbef, erythromycin-estolate, erythromycin-ethylsuccinate, clarithromycin, clindamycin, triple sulfonamide, penicillin G plus sulfisoxazole, penicillin V plus sulfisoxazole, penicillin V plus triple sulfonamide, procaine-penicillin-benthazine-penicillin G plus sulfisoxazole, erythromycin-ethylsuccinate-sulfisoxazole, erythromycin-ethylsuccinate-acetyl-sulfafurazole, and erythromycin-sulfisoxazole. This also was true in the one study that stratified the outcome by age, but the numbers were very small in that comparison. None of the studies stratified by otitis-prone status.

### Trimethoprim-Sulfamethoxazole vs. Cefaclor

No difference was seen between cefaclor and trimethoprim-sulfamethoxazole in terms of failure at less than 14 days of treatment. No comment can be made regarding the role of age or otitis-prone state.

### Amoxicillin-Clavulanate and Ceftriaxone vs. Trimethoprim-Sulfamethoxazole

No difference was seen based on the few studies that studied the comparisons of amoxicillin-clavulanate and ceftriaxone with trimethoprim-sulfamethoxazole.

### Utility of Oral Fluoroquinolone

No studies were available that compared oral fluoroquinolone with another antibiotic for the treatment of AOM in children.

### High-Dose Amoxicillin or Amoxicillin-Clavulanate vs. Standard-Dose Amoxicillin or Amoxicillin-Clavulanate

In the single study on high-dose amoxicillin-clavulanate vs. standard-dose of the same antibiotic, no difference in effectiveness could be demonstrated. We note, however, that showing a lack of difference is not the same as establishing equivalence of effect. No comment can be made on the influence of age or otitis-prone status.

### High-Dose Amoxillin or Amoxicillin-Clavulanate Twice a Day vs.Three Times a Day

In the single study on high-dose amoxicillin prescribed twice a day vs. three times a day, no difference in effectiveness could be demonstrated. We note, however, that showing a lack of difference is not the same as establishing equivalence of effect. Although the authors comment that age and the number of previous episodes of AOM had no influence on the outcomes, the data were not presented; therefore, we can not comment directly on the influence of these factors.

### Short-Term vs. Long-Term Antibiotic Therapy

#### Ceftriaxone (One dose) vs. Amoxicillin (7-10 days)

No difference in failure rate at 5-10 days was found comparing single-injection ceftriaxone with 7-10 days of amoxicillin therapy for the treatment of AOM.

#### Azithromycin (<5 days) vs. Amoxicillin-Clavulanate (7-10 days)

No difference in failure rate at 10-14 days was found in comparing less than 5-day azithromyicn therapy to 7-10 days of amoxicillin-clavulanate therapy.

#### Azithromycin (5 days) vs. Amoxicillin-Clavulanate (7-10 days)

Amoxicillin-clavulanate was associated with a statistically greater proportion of adverse effects, predominantlygastrointestinal effects, compared with azithromycin therapy. Eight children would need to be treated with azithromycin rather than amoxicillin-clavulanate to avoid a case of diarrhea. (Although not reported in the studies, the clavulanate concentration was most likely 31.25 mg per 125 mg of amoxicillin.) These meta-analyses, however, were associated with significant statistical heterogeneity. The source of that heterogeneity is not clear.

#### Other Short-Duration vs. Long-Duration Comparisons

We compared the following antibiotic treatments: penicillin V (<5 days) vs. penicillin V (7-10 days), penicillin V (5 days) vs. penicillin V (7-10 days), benthazine penicillin G (one dose) vs. tetracycline (7-10 days), benthazine penicillin G (one dose) vs. benthazine penicillin (one dose) plus triple-sulfonamide (7 days), amoxicillin-clavulanate (5 days) vs. amoxicillin-clavulanate (7-10 days), cefaclor (<5 days) vs. cefaclor (7-10 days), cefaclor (5 days) vs. amoxicillin (7-10 days), cefaclor (5 days) vs. cefaclor (7-10 days), cefuroxime-axetil (5 days) vs. amoxicillin-clavulanate (7-10 days), cefuroxime-axetil (5 days) vs. cefxime (7-10 days), cefpodoxime-proxetil (5 days) vs. amoxicillin-clavulanate (7-10 days), cefpodoxime-proxetil (5 days) vs. cefaclor (7-10 days), cefpodoxime-proxetil (5 days) vs. cefixime (7-10 days), cefprozil (5 days) vs. cefprozil (7-10 days), ceftriaxone (one dose) vs. amoxicillin-clavulanate (7-10 days), ceftriaxone (one dose) vs. cefaclor (7-10 days), ceftriaxone (one dose) vs. cefuroxime-axetil (7-10 days), azithromycin (<5 days) vs. cefaclor (7-10 days), and azithromycin (<5 days) vs. clarithromycin (7-10 days).

The majority of studies of these treatments -- 19 of 24 -- show no difference in effectiveness between the short-duration and long-duration therapies evaluated. Only two of these studies looked at the effect of age on outcome, and only one looked at the effect of otitis-prone status on outcome. Paradise (1997) reported results suggesting that clinical failure at 12-14 days and 32-38 days was significantly higher for children younger than 2 years old and at 12-14 days for children 2-5 years old in the 5-day amoxicillin-clavulanate group than the group taking amoxicillin-clavulanate twice a day for 10 days. Ingvarsson and Lundgren (1982) reported results suggesting that although the difference in failure was not significant between the short-duration penicillin and long-duration penicillin groups in general, there appeared to be a higher percentage of failure in the short-duration group of those younger than 2 years of age. Barnett, Teele, Klein, et al. (1997) reported that otitis-prone status did not seem to have an effect on failure rate, but those who failed appeared to be of younger mean age. The former two studies suggest that age may be an important influencing factor to consider when prescribing shorter-duration antibiotic therapy for AOM.

## General Conclusions

This evidence report supports the following general conclusions (Table 50):

- In children not initially treated with antibiotics, clinical failure at 24-48 hours was 7.7 percent in one study (i.e., 92.3 percent clinical resolution), and 26 percent at 24-72 hours in another study (i.e., 74 percent clinical resolution). The pooled estimate for clinical failure at 1-7 days was 18.9 percent (95 percent CI, 9.9 percent and 28.0 percent) and for 22.2 percent at 4-7 days (95 percent CI, 10.1 percent and 34.3 percent).
- A previous information synthesis estimated that 59 percent (95 percent CI, 53 percent and 65 percent) of children not treated with antibiotics had resolution of pain and fever within 24 hours of AOM diagnosis, 87 percent (95 percent CI, 84 percent and 89 percent) of children had resolution of pain and fever by 2-3 days, and 88 percent (95 percent CI, 85 percent and 91 percent) of children had resolution of pain and fever by 4-7 days.
- The available evidence on natural history of AOM shows that in studies with close followup, few episodes of mastoiditis or other suppurative complications are reported in children with AOM not initially treated with antibiotics.
- Antibiotics in comparison to placebo or observational treatment may have a modest benefit on symptom resolution and failure rates, as variously defined, in children with AOM. For example, about eight children with AOM would need to be treated with ampicillin or amoxicillin rather than no antibiotic treatment to avoid a clinical failure.
- Previous meta-analyses have demonstrated minimal to modest benefits of antibiotics compared to observational intervention without antibiotics during the initial treatment of AOM for pain and fever resolution at 2 days, pain resolution at 2-7 days, contralateral otitis media, and clinical resolution rate at 7-14 days. Pain resolution at 24 hours, pain and fever resolution at 4-7 days, tympanic membrane perforation, vomiting/diarrhea/rash, 1-month tympanometry, and recurrent AOM did not appear to be affected by antibiotic use.
- The study was not able to demonstrate any clinical benefits of other antibiotics in comparison with ampicillin or amoxicillin and to trimethoprim-sulfamethoxazole. However, cefixime was shown to cause greater incidence of diarrhea than ampicillin or amoxicillin. Twelve children would have to be treated with ampicillin or amoxicillin rather than cefixime to avoid a case of diarrhea.
- No comment can be made on the marginal effect of oral fluoroquinolones compared with other antibiotics in the treatment of AOM.
- Although not establishing equivalency of effect, a single study was unable to demonstrate a difference in clinical effect of high-dose amoxicillin-clavulanate vs. standard-dose amoxicillin-clavulanate.
- Although not establishing equivalency of effect, a single study was unable to demonstrate a difference in clinical effect of taking high-dose amoxicillin two times a day vs. three times a day.
- We could not demonstrate any difference in clinical failure rates between short-duration therapy and long-duration therapy of AOM. A previous meta-analysis demonstrated that short-acting antibiotic therapy of less than 2 days was not as effective as therapy that lasted 7 days or longer.
- Azithromycin given for 5 days led to fewer adverse events, particularly gastrointestinal, than 7-10 days of amoxicillin-clavulanate. Eight children with AOM would need to be treated with azithromycin rather than amoxicillin-clavulanate to avoid a gastrointestinal adverse event. (Although not reported in the studies, the clavulanate concentration was most likely 31.25 mg per 125 mg of amoxicillin, i.e., original formulation.)

Table 50. Summary of Comparisons and Meta-Analysis Performed for Key Questions 3, 4a, and 4e

Comparison | Meta-analysis | Rate Difference in % (95% CI) | Test of Heterogeneity | | Number Needed to Treat (NNT) (95% CI)
Comparison | Meta-analysis | Rate Difference in % (95% CI) | Q-Value | P-Value | Number Needed to Treat (NNT) (95% CI)
1 (Q3) Ampicillin or Amoxicillin vs. Placebo | 1.1 Failure rate at 2-7 days of treatment (5 studies) | −12.3 (−21.8, −2.8) | 18.83 | 0.002 | −8 (−36, −5)
1 (Q3) Ampicillin or Amoxicillin vs. Placebo | 1.2 Failure rate at 2-7 days of treatment, excluding Howie studies (4 studies) | −9.7 (−19.2, −0.2) | 13.71 | 0.003 | −10(−437, −5)
1 (Q3) Ampicillin or Amoxicillin vs. Placebo | 1.3 Failure rate at 2-7 days of treatment, excluding Howie and Kaleida studies (3 studies) | −12.9 (−27.5, 1.7) | 5.89 | 0.053 | ND
2 (Q4a) Penicillin vs. Amoxicillin or Ampicillin | 2.1 Failure rate at 7-14 days of treatment (3 studies) | 4.5 (−1.8, 10.7) | 1.97 | 0.374 | ND
3 (Q4a) Cefaclor vs. Amoxicillin or Ampicillin | 3.1 Failure rate at 3-7 days post treatment (4 studies) | −5.4 (−15.2, 4.4) | 3.05 | 0.383 | ND
3 (Q4a) Cefaclor vs. Amoxicillin or Ampicillin | 3.2 Failure rate at 5-21 days post treatment (5 studies) | 0.5 (−5.7, 6.8) | 3.16 | 0.531 | ND
4 (Q4a) Cefixime vs. Amoxicillin or Ampicillin | 4.1 Failure rate at 10-15 days of treatment (4 studies) | −0.1 (−4.2, 3.9) | 0.21 | 0.976 | ND
4 (Q4a) Cefixime vs. Amoxicillin or Ampicillin | 4.2 Recurrence rate at 3-5 weeks of treatment (3 studies) | 1.6 (−5.1, 8.4) | 0.37 | 0.832 | ND
4 (Q4a) Cefixime vs. Amoxicillin or Ampicillin | 4.3 Incidence of diarrhea (5 studies) | 8.4 (3.8, 13.1) | 2.95 | 0.567 | 12 (8, 27)
4 (Q4a) Cefixime vs. Amoxicillin or Ampicillin | 4.4 Incidence of vomiting (5 studies) | 2.0 (0.0, 4.0) | 3.79 | 0.435 | ND
4 (Q4a) Cefixime vs. Amoxicillin or Ampicillin | 4.5 Incidence of rash (4 studies) | 5.8 (−2.4, 13.9) | 12.11 | 0.007 | ND
9 (Q4e) Ceftriaxone (1 dose) versus Amoxicillin (7-10d) | 9.1 Failure rate at 5-10 days of treatment (3 studies) | 3.4 (−1.6, 8.5) | 0.30 | 0.862 | ND
9 (Q4e) Ceftriaxone (1 dose) versus Amoxicillin (7-10d) | 9.2 Failure rate at 5-10 days of treatment (criterion of failure is relaxed to include complications in Green study). | 2.5 (−4.4, 9.5) | 0.51 | 0.775 | ND
10 (Q4e) Azithromycin (<5d) versus Amoxicillin-Clavulanate (7-10d) | 10.1 Failure rate at 10-14 days of treatment (5 studies) | 2.1 (−0.6, 4.8) | 5.34 | 0.254 | ND
11 (Q4e) Azithromycin (5d) versus Amoxicillin-Clavulanate (7-10d) | 11.1 Any mention of adverse events (3 studies) | −19.2 (−29.2, −9.2) | 12.49 | 0.002 | −5 (−11, −3)
11 (Q4e) Azithromycin (5d) versus Amoxicillin-Clavulanate (7-10d) | 11.2 GI related adverse events (3 studies) | −18.0 (−28.0, −8.0) | 13.48 | 0.001 | −6 (−13, −4)

ND=Not Done due to non-significant result.

## Caveats

Estimates generated by quantitative synthesis are subject to error. The issue of heterogeneity is always open to question, particularly with regard to study subjects and treatment regimens. The definitions of AOM found in the studies varied as did the diagnostic criteria in terms of establishing the presence of middle ear effusion, rapid onset, and specific signs and symptoms and in establishing an initial or new episode of AOM. Very few studies rated the severity of AOM. In this evidence-based analysis, the choice of outcomes and the definition of clinical failure also varied from one study to another. Statistical heterogeneity characterized several of our meta-analytic comparisons. We used the random effects model in all cases to provide a more conservative estimate of significance.

Another problem was that most of the studies in this evidence-based analysis had small numbers of subjects. For the most part, the individual studies were unable to establish the significance of any treatment effects seen. Among the antibiotic regimen comparisons, less than 10 percent appeared to be of sufficient statistical power to detect a difference. Relevant to this study, Pogue and Yusuf (1998) pointed out that meta-analysis of trials with small subject numbers may overestimate treatment effects.

Although we are confident that the literature search for this report was thorough, it is possible that some studies were missed, particularly with regard to the comparative analysis of antibiotic treatments. Our search of the non-English literature, which ended with a screening and review of those non-English reports found in five of the seven databases, was not exhaustive. Although that search yielded only two studies, it is possible that non-English citations from other sources may have yielded further studies for the analysis.

Studies of poor quality, particularly those with inadequate randomization procedures or those not double-blind, may inflate estimates of treatment benefit (Moher, Jones, Cook, et al., 1998; Schulz, Chalmers, Hayes, et al., 1995). Although all of the studies included in the meta-analyses were randomized, many studies did not adhere to protocols that would strengthen the internal validity of the findings. Because many of the studies did not report their procedures for randomization, it is difficult to determine whether the randomization process was appropriate in those trials. A large number of studies also were not double-blind. About one-half of the studies were not of adequate quality based on the Jadad scale. Because of the small numbers of studies in each of our meta-analyses, the sensitivity analysis we had planned was not possible.

The generalizability of the findings of this evidence-based analysis is difficult to assess. Looking at the natural history studies, we previously noted the wide range in percentage of subjects 2 to 2-and-a-half years old or younger reported in both the randomized controlled trials and the cohort studies. Only two of the nine randomized controlled trials addressing natural history reported any outcome stratified as 2 years or younger and older than 2 years (Appelman, Claessen, Touw-Otten, et al., 1991; Kaleida, Casselbrant, Rockette, et al., 1991), and only the Kaleida, Casselbrant, Rockette, et al. (1991) study reported early failure rate stratified in this manner. Two of the six cohort studies on natural history reported results stratified for younger and older than 2 years of age (Froom, Culpepper, Grob, et al., 1990; Tilyard, Dovey, and Walker, 1997), with clinical failure rates at 2 months and 1 month, respectively.

One might assume that results stratified by age were not reported because there was no difference, but we hesitate to make this presumption as the two studies that do report by age indicate that children younger than 2 years old do not resolve their clinical symptoms as quickly as older children. On the other hand, we also would not make any conclusions based only on these two studies because one was of very small sample size (Appelman, Claessen, Touw-Otten, et al., 1991) and the other studied children with nonsevere AOM in the placebo group (Kaleida, Casselbrant, Rockette, et al., 1991), using episodes as the unit of analysis.

The question on antibiotics vs. no antibiotics used the same randomized controlled trials just described and, thus, have the same difficulties with reporting outcomes by age. The studies on the clinical effectiveness of specific antibiotic regimens suffer the same problems with regard to reporting outcomes by subject age. We have reported in the individual results sections the wide range in percentage of subjects 2-3 years old or less. In the studies on ampicillin or amoxicillin or trimethoprim-sulfamethoxazole vs. other antibiotics, three studies report outcomes on children younger than 2 years old, one exclusively studying infants younger than 3 months old and another exclusively children younger than 2 years old. Four of the studies on short-duration vs. long-duration therapy of AOM report on age-stratified outcomes. Although the study by Brodie, Griggs, and Cunningham (1990) showed no difference in 1-to 4- day clinical failure rates in those younger and older than 2 years old (all on antibiotics) we cannot presume that results by age were not reported because there were no differences. For example, the Hoberman, Paradise, Burch, et al. (1997) study did not report any outcomes by age in their initial article, but later in an editorial, one of the investigators reported clinical cure or improvement rates at 12-14 days and 32-38 days, suggesting that children younger than 2 years do not do as well as older children (Paradise, 1997). Unfortunately, this investigator did not report on those younger than 2 years old in a third treatment arm of that study.

The remaining three studies also suggest higher clinical failure rates in children younger than 2 years old on antibiotics (Ingvarsson and Lundberg, 1981; Principi, 1995; Schaad, 1993). Most of the studies did not address the otitis-prone status of the child, and even fewer reported outcomes stratified by this influencing factor. Appleman, Claessen, Touw-Otten, et al. (1991) was an exception because this study recruited only patients with recurrent otitis media into their trial. Although many studies had significant numbers of children younger and older than 2 years, we cannot generalize the findings of this study to children in specific age groups because most of the studies did not report outcome by age. Several studies suggest greater caution be taken with children younger than 2 years old; however, these studies do not definitively answer this question. Similarly, we cannot generalize the study findings to children by otitis-prone status.

Two other issues -- although not specifically cited for assessment in the present analysis by the Technical Expert Panel -- that may be significant influencing factors are the degree of severity of AOM and increasing bacterial resistance to antibiotics. Kaleida, Casselbrant, Rockette, et al. (1991) was one of the few studies that explicitly defined severity and treated those with low severity and high severity with different therapeutic regimens. Many of the studies excluded those children with AOM that one might label high severity (i.e. those with complications, comorbid or concurrent conditions, or strong indications for antibiotic). In addition, many of the studies excluded children with acute or chronic perforation of the tympanic membrane. The study findings are, therefore, most applicable to children with AOM of lesser severity without comorbidities.

The majority of studies in this evidence-based analysis do not explicitly address the issue of bacterial resistance. As Klein (1998) notes, group A streptococci and streptococcus pneumonia developed resistance to sulfonamides in the 1940s; Staphylococcus aureus to penicillins, macrolides, and tetracyclines in the 1950s; gram-negative enteric bacilli to aminoglycosides, chloramphenicol, and tetracyclines in the 1960s; Haemophilus influenzae to beta-lactamase-susceptible penicillins in the 1970s; and more recently, S. pneumonia to penicillins, cephalosporins, and macrolides in the 1980s.

Our study did not look at the issue of bacterial resistance and its effect on outcome of AOM. It might have been possible to stratify the studies based on the decade of conduct as a proxy to bacterial resistance pattern, but the prevalence of bacterial resistance also may differ based on locale (McCracken, 1998). A consensus conference convened by the Centers for Disease Control and Prevention has made recommendations with regard to treatment of AOM in light of this issue (Dowell, Butler, Giebink, et al., 1999).

Outcomes measured varied in studies, making comparison difficult. In addition, similar outcomes were defined differently in studies. Most of the clinical outcomes measured were short term rather than long term. The studies in this analysis did not address speech and language development, an obvious long-term outcome. Some of the studies measured adverse effects such as rash, diarrhea, and vomiting. Studies tended to concentrate on clinical outcomes. The studies do not measure the costs and benefits to the family and to society of AOM treatment alternatives.

Another influencing factor that was not controlled in any of the studies in the present evidence-based analysis was the use of antipyretics and analgesics by the study subjects. The investigators should control the use of antipyretics and analgesics in some manner, especially in cases when fever and otalgia or pain are outcome measures.