# Results

## Natural History

To understand the true effect of an intervention on a clinical condition such as AOM, the natural history of that condition without intervention must be known. The timing of processes and intermediate outcomes, as well as the ultimate outcomes of acute otitis media (AOM) without intervention, must be known. Also important are influencing factors, either genetic, familial, cultural, or environmental, that may be difficult to control and that may affect the outcomes of AOM apart from, in addition to, or in interaction with the interventions of interest. The Technical Expert Panel decided to concentrate on age and otitis-prone state as such influencing factors to analyze. To properly estimate the marginal effects of an intervention on the outcomes of AOM, the natural history of AOM without intervention should be clearly understood.

The question we asked was: During an episode of uncomplicated AOM that is initially managed without any active intervention (pharmacologic or surgical) other than topical or systemic medications (that do not contain antibiotics) given for symptomatic relief (e. g., analgesics, antipyretics, antihistamines, decongestants, ear or nose drops), what proportion of children have the outcomes delineated in the Scope of the Evidence Report (Appendix E.4). To what degree are the above outcomes attributable to the influencing factors delineated in the Scope of the Evidence Report (Appendix E.4).

## Previous Information Syntheses

Rosenfeld (1999a) assessed the natural history question in a previous information synthesis. As in the present analysis, Rosenfeld (1999a) evaluated children from epidemiologic studies, untreated control groups in randomized clinical trials, and cohort studies with an untreated group. Rosenfeld (1999a) assessed the same set of studies as in the present evidence-based analysis except for the inclusion of Fry (1958) and the absence of Tilyard, Dovey, and Walker (1997). We excluded Fry (1958) from our analysis because we could not extract the data on children from the data on adults in that study. Data were then pooled to calculate outcome estimates. Rosenfeld (1999a) estimated that 59 percent (3 studies; 315 children; 95 percent confidence limits, 53 percent and 65 percent) of children had relief of pain and fever within 24 hours of diagnosis. We note that one study used in this estimate (Burke, Bain, Robinson, et al., 1991) reported on resolution of pain and fever separately, and another study (Thalin, Densert, Larsson, et al., 1986) reported on pain and ear discharge, but not fever. To include the data in the estimate, an assumption must be made that those without pain did not have fever. Rosenfeld (1999a) estimated that 87 percent (5 studies; 808 children; 95 percent confidence limits, 84 percent and 89 percent) had relief of pain and fever within 2-3 days. Data from the Thalin, Densert, Larsson, et al. (1986) study was used in this estimate. Relief of pain and fever at 4-7 days was estimated to be 88 percent (5 studies; 503 children; 95 percent confidence limits, 85 percent and 91 percent). Again, data from the estimates in two studies -- Burke, Bain, Robinson, et al. (1991) and Thalin, Densert, Larsson, et al. (1986) -- were included in this estimate.

Finally, clinical resolution within 7-14 days of diagnosis was estimated at 73 percent (4 studies; 270 children; 95 percent confidence limits, 65 percent and 78 percent) based on the absence of all presenting signs and symptoms except middle ear effusion. The numerator used from one study (Halsted, Lepow, Balassanian, et al., 1968) appears to include success as judged by clinical or bacteriologic failure rather than clinical failure alone. In another study (Mygind, Meistrup-Larsen, Thomsen, et al., 1981) used in this estimate, the denominator is not clear from the report, and the initial denominator was used. Finally, Rosenfeld (1999a) found two cases of acute mastoiditis in 1,802 patients managed without antibiotics out of 2,368 patients, predominantly children, in six observational studies. (Although we mention some concerns about the data in these estimates, we also acknowledge that the direction and general magnitude of the estimates would not change with exclusion of that data. These same concerns apply to the use of these data in Rosenfeld (1999b), which is mentioned in the previous meta-analyses section Antibiotics vs. No Antibiotics in this chapter.)

## Observation or Placebo

As proxies for natural history, we used the observational arm of cohort studies and the observational or placebo arm of randomized controlled trials of AOM. The treatment arm of such trials could be of any modality, antibiotic, myringotomy, etc., as long as the control arm consisted solely of observation or placebo.

### Study Populations

Nine randomized controlled trials and six cohort studies were identified that address the natural history of AOM (Evidence Table 1). Eight of the randomized controlled trials had a placebo group, and one (Laxdal, Merida, and Jones, 1970) had an observational group that was treated symptomatically. All cohort studies had a group of subjects who were treated without antibiotics at the discretion of the investigators.

With respect to the age of the subjects, of the nine randomized controlled trials, three studies had no children under 2 years of age (Burke, Bain, Robinson, et al, 1991; Thalin, Densert, Larsson, et al., 1986; van Buchem, Dunk, and van't Hof, 1981), one had about one-fifth of the study population under 2 years of age (Appelman, Claessen, Touw-Otten, et al., 1991), two had approximately one-half of their study populations under 2 years of age (Kaleida, Casselbrant, Rockette, et al., 1991; Laxdal, Merida, and Jones, 1970), and two had at least three-fourths of the study population under 2 years of age (Halsted, Lepow, Balassanian, et al., 1968; Howie and Ploussard, 1972). Mygind, Meistrup-Larsen, Thomsen, et al. (1981) reported a mean age of 3.9 years for their study population but did not stratify any further. Of the cohort studies, one study had almost 90 percent of the total 2 years of age or younger (Ostfeld, Segal, Kaufstein, et al., 1988) and two studies had more than one-fourth of their total subjects younger than 30 months of age (Froom, Culpepper, Grob, et al., 1990; Tilyard, Dovey, and Walker, 1997). In the Thalin, Densert, Larsson, et al. (1986) study, all patients were older than 2 years of age. One study reported mean ages for their subjects as a whole, but not specifically for the groups not treated with antibiotics (Bollag and Bollag-Albrecht, 1991). Another study did not report on the ages of the patients (Townsend, 1964).

With regard to the otitis-prone state, four of the nine studies described their study populations with respect to this influencing factor. Appelman, Claessen, Touw-Otten, et al. (1991) reported that 12 percent of their study population had three or more episodes of AOM prior to the study; Burke, Bain, Robinson, et al. (1991) reported 47 percent; and Kaleida, Casselbrant, Rockette, et al. (1991), 21 percent. Thalin, Densert, Larsson, et al. (1986) reported that 27 percent of their patients had more than 10 episodes of AOM, and 23 percent of their patients had no prior episodes of AOM. None of the cohort studies referred to their subjects' past experiences with AOM.

### Outcomes

The outcomes reported for these nine randomized controlled trials and six cohort studies share some commonalities but also many differences (Evidence Table 1). Outcome descriptors often relate to success or failure, pain or otalgia, fever, otoscopic findings, middle ear exudates or otorrhea, middle ear effusion, tympanometry results, relapse, recurrence, need for further intervention such as placement of pressure equalizing tubes, and suppurative complications such as mastoiditis.

The differences in the actual outcomes measured were due both to the outcome selection, measurement description, and the time of measurement relative to the start of the study (Table 20). Forty-eight outcomes are listed in Table 20. In those cases where outcomes seemed to be shared, the description of those outcomes was not always the same. In addition, in those cases where the outcomes seemed to have the descriptors of the same meaning such as success or failure but not the same time of measurement, a reading of the actual definition of those descriptors revealed differences (Table 21). Terms used for the meaning success included "early improvement," "resolved," "excellent" or "good," "improvement," "satisfactory course of acute phase," "recovery," and "cure." In some studies, the reviewer had to assume that the opposite of failure was success. Terms used for failure included "failure," "poor," "irregular course," "complication," and "no" or "uncertain recovery." Some definitions of success or failure were quite detailed (Kaleida, Casselbrant, Rockette, et al., 1991; Mygind, Meistrup-Larsen, Thomsen, et al., 1981). For the most part, the definitions of success or failure were nonspecific and relied solely on: symptoms; signs; signs and symptoms; signs, symptoms, and tympanic membrane appearance, specifically; or signs, symptoms, tympanic membrane appearance, and absence of middle ear effusion, specifically. Of the definitions of success and failure listed in Table 21, each is unique to the study in which it is described.

Table 20. Key question 1: selected outcomes

Author/Year | Outcome(s) Measured ^1^ | Time(s) Measured
Randomized Controlled Trials
Halsted/1968 | early improvement | 24-72 hours
Halsted/1968 | resolved | 14-18 days
Halsted/1968 | recurrence | 1 year
Laxdal/1970 | excellent | 7 days
Laxdal/1970 | good | 14 days
Laxdal/1970 | fair | 21 days
Laxdal/1970 | poor | 21 days
Laxdal/1970 | failure | 7 days
Howie/1972 | improvement/failure | 2-7 days
Howie/1972 | fever | 2-7 days
Howie/1972 | nonsterile exduate | 2-7 days
Mygind/1981 | satisfactory course of acute phase | 7 days
Mygind/1981 | symptom free | 2 days
Mygind/1981 | otorrhea | >5 days
Mygind/1981 | middle ear effusion | 1 week, 1 month, 3 months
Mygind/1981 | contralateral otitis media | 1 week
Mygind/1981 | relapse | 1 week, 1-3 months
van Buchem/1981 | pain | >24 hours, >7 days
van Buchem/1981 | abnormal otoscopy | >7 days, >14 days
van Buchem/1981 | otorrhea | >24 hours, >7 days
van Buchem/1981 | relapse | 6 months
Thalin/1986 | complete resolution | 30 days
Thalin/1986 | failure | 30 days
Thalin/1986 | relapse | 30 days
Appelman/1991 | irregular course | >3 days
Appelman/1991 | tympanometry | 1 month
Burke/1991 | failure | 7 days
Burke/1991 | pain | 2 days, 5-7 days
Burke/1991 | fever | 2 days, 5-7 days
Burke/1991 | abnormal otoscopy | >7 days
Burke/1991 | middle ear effusion | 1 month, 3 months
Burke/1991 | recurrence | 1 year
Kaleida/1991 | treatment failure | 24-48 hours, 1 year
Kaleida/1991 | middle ear effusion | 2 weeks, 6 weeks
Kaleida/1991 | recurrence | 2-6 weeks
Cohort Studies
Townsend/1964 | complication | 1 year
Ostfeld/1988 | otorrhea | 24 months
Ostfeld/1988 | chronic middle ear effusion | 24 months
Ostfeld/1988 | recurrence | 24 months
Ostfeld/1988 | pressure equalizing tube placement | 24 months
Ostfeld/1988 | mastoiditis | 24 months
Froom/1990 | recovery | 2 months
Bollag/1991 | mastoiditis | 2 months
Bollag/1991 | hearing deficit | 2 weeks
Tilyard/1997 | failure | 30 days
van Buchem/1985 | cure | 14 days
van Buchem/1985 | severe course | 3-4 days
van Buchem/1985 | persistent discharge | 14 days

1 See Table 21 for definitions for outcome measures related to success or failure of treatment

Table 21. Key question 1. Terms and definitions: success and failure

Author/Year | Term(s) | Definition(s) | Time Measured
SUCCESS
Randomized Controlled Trials
Halsted/1968 | early improvement | decreased symptoms | 24-72 hours
Halsted/1968 | resolved | asymptomatic and normal tympanic membrane appearance | 14-18 days
Laxdal/1970 | excellent | no evidence of middle ear inflammation | 7 days
Laxdal/1970 | good | signs of otitis media resolved | 14 days
Laxdal/1970 | gair | signs of otitis media resolved | 21 days
Howie/1972 | improvement | absence of exudate | 2-7 days
Mygind/1981 | satisfactory course of acute phase | (1) not crying from pain after 1day (2) no analgesics after 1day (3) no otitis symptoms after 2days (4) otorrhea <6 days (5) no contralateral otitis first week | 1 week
Thalin/1986 | complete resolution | not clear if refers to "satisfactory" defined as normal otomicroscopy and normal audiogram and/or tympanogram | 30 days
Cohort Studies
Townsend/1964 | recovery | (1) tympanic membrane normal (2) pneumatic otoscopy normal (3) audiogram and hearing per parents and teacher normal | 1 year
Van Buchem/1985 | cure | not severe course and without persistent discharge | 14 days
Froom/1990 | recovery | based on pain, ear drainage, hearing problem, or other | 2 months
FAILURE
Randomized Controlled Trials
Laxdal/1970 | poor | persistent signs of minimal infection | 21 days
Laxdal/1970 | failure | no improvement or deterioration | 7 days
Howie/1972 | failure | presence of xudates | 2-7 days
Thalin/1986 | failure | Remaining nonnegligible symptoms (pain, fever, etc.) or insufficient resolution of infectious signs during the medical treatment period | 7 days
Appelman/1991 | irregular course | otalgia or > 38 degrees Centigrade | >3 days
Burke/1991 | failure | second-line antibiotic required, presumably due to nonresolution or recurrence of symptoms | 1 week
Kaleida/1991 | initial treatment failure | "severe" criterion present >24 hours or >38 degrees Centigrade oral or 38.5 degrees Centigrade rectal or >6 otalgia score | 24-48 hours
Kaleida/1991 | ultimate treatment failure | cumulative >180 days middle ear effusion in same ear or > four severe AOM episodes or > five any AOM or new otitis media with effusion within 6 months or fourth myringotomy in 6 months or fifth in 12 months or suppurative complication or cholesteatoma or an allergic reaction to penicillin | 1 year
Cohort Studies
Townsend/1964 | complication | purulent progression of disease or serous otitis media | 1 year
Van Buchem/1985 | Severe course | Persistent high temperature or severe pain | 3-4 days
Van Buchem/1985 | persistent discharge | Persistent discharge | 14 days
Froom/1990 | no or uncertain recovery | based on pain, ear drainage, hearing problem, or other | 2 months
Tilyard/1997 | failure | return <10 days with same problem or change antibiotic within 30 days | 30 days

### Results

This report concentrates on failure of clinical resolution, pain, fever, and middle ear effusion in the natural history of AOM, mastoiditis, and other suppurative complications. The estimates for the other outcomes noted in Table 20 may be found in Evidence Table 1.

For those randomized controlled trials that evaluate some descriptor of success or failure in a placebo or observational group, the following statements may be made while cognizant of the differences in definition of success or failure as noted above and in Table 21. (See Table 22 and Evidence Table 1.) Early failure in a placebo group monitored at 24-72 hours was reported as 7.7 percent by Kaleida, Casselbrant, Rockette, et al. (1991) and 26 percent by Halsted, Lepow,

Table 22. Key question 1: failure1 rate in the placebo or observational group

Author/Year | Time Measured/Influencing Factor | Failure Rate
Randomized Controlled Trials
Halsted/1968 | 24-72 hours | 7/27 (26%)
Halsted/1968 | 14-18 days | 0/21 (0%)
Laxdal/1970 | 7 days | 18/48 (38%)
Laxdal/1970 | 0-3 years old | 46% (denominator not reported)
Laxdal/1970 | 3-6 years old | 38% denominator not reported)
Laxdal/1970 | 6-9 years old | 25% (denominator not reported)
Laxdal/1970 | 9-14 years old | 0% (denominator not reported)
Howie/1972 | 2-7 days | 92/116 (79%)
Mygind/1981 | 7 days | 31% (denominator not reported)
Thalin/1986 | 7 days | 12 (count only, denominator unknown)
Appelman/1991 | >3 days | 10/54 (18%)
Appelman/1991 | <2 years old | 7/12 (58%)
Appelman/1991 | >2 years old | 3/42 (7%)
Burke/1991 | 7 days | 17/118 (14%)
Burke/1991 | 3-5 years old | 10/66 (15%)
Burke/1991 | 6-9 years old | 7/52 (13%)
Burke/1991 | <2 prior AOM ^2^ | 6/55 (11%)
Burke/1991 | >2 prior AOM | 7/48 (15%)
Kaleida/1991 | 24-48 hours | 38/492 (7.7%)
Kaleida/1991 | <2 years age | 25/254 (9.8%)
Kaleida/1991 | >2 years age | 13/238 (5.5%)
Kaleida/1991 | 1 year | 46/170 (27.1%)
Kaleida/1991 | <2 years age | 30/82 (36.6%)
Kaleida/1991 | >2 years age | 16/88 (18.2%)
Cohort Studies
Townsend/1964 | 1 year | 11/189 (5.8%)
Van Buchem/1985 | 14 days | 20/465 (4.3%)
Froom/1990 | 2 months | 40/4 19 (9.5%)
Froom/1990 | 0-12 months old | 5/39 (12.8%)
Froom/1990 | 13 30 months old | 7/69 (10.1%)
Froom/1990 | >31 months old | 28/311 (9.0%)
Tilyard/1997 | 1 month | 8/74 (10.8%)
Tilyard/1997 | <2 years old | 4/29 (14%)
Tilyard/1997 | 2 5 years old | 4/22 (18%)
Tilyard/1997 | 6-15 years old | 0/12 (0%)
Tilyard/1997 | >15 years old | 0/11 (0%)

1 See definition of success and failure in Table 21

2 AOM=acute otitis media

Balassanian, et al. (1968). Appelman, Claessen, Touw-Otten, et al. (1991) reported a failure rate of 18 percent measured after 3 days. Failure monitored at 7 days was reported as 8 percent by Thalin, Densert, Larsson, et al. (1986), 14 percent by Burke, Bain, Robinson, et al. (1991), and 38 percent by Laxdal, Merida, and Jones (1970). An unsatisfactory clinical course of the acute phase (7 days) was reported for 31 percent of the placebo group by Mygind, Meistrup-Larsen, Thomsen, et al. (1981). Thalin, Densert, Larsson, et al. (1986) reported 12 subjects in their placebo group failing therapy at 7 days but did not specify a denominator. According to the definition of failure by Howie and Ploussard (1972) as the presence of middle ear exudate at 2-7 days, that group reported a rate of failure of 79 percent in the placebo group and 57 percent in the antibiotic group. Failure in the placebo group at 14-18 days was 0 percent (Halsted, Lepow, Balassanian, et al. 1968) and failure for the placebo group at 1 year was 27.1 percent (Kaleida, Casselbrant, Rockette, et al. 1991). The cohort study (Tilyard, Dovey, and Walker 1997) reported a failure rate of 10.8 percent in their group not treated with antibiotics at 1-month measurement, (Froom, Culpepper, Grob, et al. 1990), a failure rate of 9.5 percent at 2-month measurement, and a failure rate of 5.8 percent at 1-year measurement (Townsend 1964).

Pooling the failure data at 1-7 days from the randomized controlled studies in cases where denominators were certain, we calculated a failure rate of 18.9 percent (five studies; 739 children; 95 percent CI, 9.9 percent and 28.0 percent) for those not initially receiving antibiotics (Appelman, Claessen, Touw-Otten, et al., 1991; Burke, Bain, Robinson, et al., 1991; Halsted, Lepow, Balassanian, et al., 1968; Kaleida, Casselbrant, Rockette, et al., 1991; Laxdal, Merida, and Jones, 1970). In other words, 81.1 percent of these children with AOM not initially treated with antibiotics would have clinical resolution within 1-7 days of presentation. The pooled estimate for the failure rate at 3-7 days was 22.2 percent (three studies; 220 children; 95 percent CI, 10.1 percent and 34.3 percent) (Appelman, Claessen, Touw-Otten, et al., 1991; Burke, Bain, Robinson, et al., 1991; Laxdal, Merida, and Jones, 1970). During this time, 77.8 percent of children would have clinical resolution. (See Evidence Table 1 for data on individual studies.) We did not pool the data at 1-3 days because only two studies were available (Halsted, Lepow, Balassanian, et al., 1968; Kaleida, Casselbrant, Rockette, et al., 1991).

The presence of pain or otalgia was a common outcome reported in the randomized controlled studies (Table 23). Twenty-eight percent of the placebo group had pain at 24 hours and 10 percent had pain at 7 days (Van Buchem, Dunk, van't Hof, et al. 1981). 48 percent had pain at 2 days and 25 percent had pain at 5-7 days (Burke, Bain, Robinson, et al. 1991). Initial treatment failure was based on presence of fever or pain (Kaleida, Casselbrant, Rockette, et al. 1991). This study found 7.7 percent of children with nonsevere AOM in their placebo group had fever or pain at 24-48 hours. Howie and Ploussard (1972) reported that none of the placebo group had fever at 2-7 days; Burke, Bain, Robinson, et al. (1991) reported that 20 percent of the placebo group had fever at 2 days and 11 percent had fever at 5-7 days. Mygind, Meistrup-Larsen, Thomsen, et al. (1981) reported that 38 percent of the placebo group had pain and fever at 2 days. Twenty-eight percent of the placebo group had pain and fever at 24 hours, and 10 percent had pain and fever at 7 days (van Buchem, Dunk and van't Hof 1981); 18 percent had pain and fever at 3 days (Appelman, Claessen, Touw-Otten, et al. 1991). Despite the variability of the studies, it appears that children with AOM not treated with antibiotics experience a significant decrease in pain and fever during the first week of the clinical condition.

Table 23. Key question 1: presence of pain and/or fever in the placebo or observational group

Author/Year | Time Measured/Influencing Factor | Number of patients with Symptom
Randomized Controlled Trials
Pain
van Buchem/1981 | >24 hours | 11/49 (28%)
van Buchem/1981 | >7 days | 4/38 (10%)
Burke/1991 | 2 days | 56/117 (48%)
Burke/1991 | 5-7 days | 29/114 (25%)
Fever
Howie/1972 | 2-7 days | 0/116 (0%)
Burke/1991 | 2 days | 19/93 (20%)
Burke/1991 | 5-7 days | 8/70 (11%)
Pain or Fever
Mygind/1981 | 2 days | 38% (denominator not reported)
van Buchem/1981 | >24 hours | 11/40 (28%)
van Buchem/1981 | >7 days | 4/38 (10%)
Thalin/1986 | 7 days | 12 (count only, denominator unknown)
Appelman/1991 | >3 days | 10/54 (18%)
Appelman/1991 | <2 years old | 7/12 (58%)
Appelman/1991 | >2 years old | 3/42 (7%)
Kaleida/1991 | 24-48 hours | 38/492 (7.7%)
Kaleida/1991 | <2 years old | 25/254 (9.8%)
Kaleida/1991 | >2 years old | 13/238 (5.5%)

The presence of middle ear effusion also was reported in many of the studies (Table 24). Asymptomatic middle ear effusion is an expected part of the clinical course of AOM (Rosenfeld, 1996). Persistence of middle ear effusion beyond 3 months, however, is not considered normal. Fifty percent of children in the placebo group had middle ear effusion at 1 week in the study of Mygind, Meistrup-Larsen, Thomsen, et al. 1981); at 1 month and 3 months, 32 percent and 24 percent of patients, respectively, had middle ear effusion. In Burke, Bain, Robinson, et al. (1991), middle ear effusion occurred in 35 percent of the placebo group at 1 month, and 28 percent of these patients at 3 months. In Kaleida, Casselbrant, Rockette, et al. (1991), 63 percent had a middle ear effusion at 2 weeks, and 52 percent at 6 weeks. A cohort study found 42 percent with chronic middle ear effusion at 24-month followup (Ostfeld, Segal, Kaufstein, et al. 1988). In general, these studies indicate that middle ear effusion is quite common after AOM.

Table 24. Key question 1: presence of middle ear effusion in the placebo or observational group

Author/Year | Time Measured/Influencing Factor | Number of Patientst with Symptom
Randomized Controlled Trials
Howie/1972 | 2-7 days | 92/116 (79%)
Mygind/1981 | 1 week | 50% (denominator not reported)
Mygind/1981 | 1 month | 32% (denominator not reported)
Mygind/1981 | 3 months | 24% (denominator not reported)
Thalin/1985 | 30 days | 41% (denominator not reported)
Burke/1991 | 1 month | 41/116 (35%)
Burke/1991 | 3 months | 31/111 (28%)
Kaleida/1991 | 2 weeks | 255/408 (63%)
Kaleida/1991 | <2 years old | 143/209 (68%)
Kaleida/1991 | >2 years old | 112/1 19 (56%)
Kaleida/1991 | 6 weeks | 169/328 (52%)
Kaleida/1991 | <2 years old | 99/175 (57%)
Kaleida/1991 | >2 years old | 70/153 (46%)
Cohort Study
Ostfeld/1987 | 24 months | 42% (denominator not reported)

Several of the studies reported estimates of these outcome measures by age group or otitis-prone state (Evidence Table 1, Tables 22, 23, and 24). Laxdal, Merida, and Jones (1970) reported that 46 percent of children 0-3 years of age failed to improve by 7 days in the observational group, while none of the children 9-14 years of age in the observational group failed to improve. In Burke, Bain, Robinson, et al. (1991), 15 percent of children 3-5 years of age had no improvement of symptoms by 1 week, while 13 percent of those 6-9 years of age had no symptomatic improvement. Kaleida, Casselbrant, Rockette, et al. (1991) reported that in patients in the placebo group, the initial failure rate was 9.8 percent in children younger than 2 years of age compared with 5.5 percent of children 2 years of age or older. Kaleida, Casselbrant, Rockette, et al. (1991) also found that at 1-year followup, 37 percent of those younger than 2 years of age in the placebo group and 18 percent of those 2 years of age or older met their criteria for failure. Burke, Bain, Robinson, et al. (1991) also found that children in the placebo group with one or two previous episodes of AOM had an 11 percent rate of symptomatic failure compared with 15 percent of children with more than two previous episodes of AOM. In the prospective questionnaire study, 12.8 percent of those aged 0-12 months who were not on antibiotics failed to recover by 2 months, whereas 10.1 percent of those 13-30 months of age and 9.0 percent of those older than 30 months failed to recover (Froom, Culpepper, Grob, et al. 1990). In the retrospective cohort study (Tilyard, Dovey, and Walker 1997), 14 percent of those younger than 2 years of age without antibiotic treatment failed to recover, as did 18 percent of those 2-5 years of age, and 0% of those 6 years of age and older (Table 22). A significant difference was seen for the resolution of pain and fever as reported by Appelman, Claessen, Touw-Otten, et al. (1991): 58 percent with pain or fever after 3 days in those younger than 2 years of age and 7 percent in those 2 years of age or older (Table 23). As shown in Table 24, 57 percent of children younger than 2 years of age in the placebo group of Kaleida, Casselbrant, Rockette, et al. (1991) had a middle ear effusion at 6 weeks, whereas that was true of 46 percent of those 2 years of age or older.

Mastoiditis and other suppurative complications are important outcomes to consider. Clinical failure based on signs and symptoms -- including pain, fever, and middle ear effusion -- are important, but serious complications would have greater weight in the treatment decision of AOM. Table 25 summarizes the information on mastoiditis and other suppurative complications found in the literature retrieved on natural history. Of the six cohort studies, two report specifically on the occurrence of suppurative complications in their study populations. Bollag and Bollag-Albrecht (1991) report no episodes of mastoiditis or meningitis in the two small cohorts that they followed. Ostfeld, Segal, Kaufstein, et al. (1988) noted two cases of mastoiditis in the 397 patients not treated with antibiotics and three cases of mastoiditis in the 296 patients treated with antibiotics; none of their patients had meningitis. In addition to these two cohort studies, van Buchem, Peeters, and van't Hof (1985) mention two cases of mastoiditis in a 17-month period for which they estimated a denominator of 4,860 children with AOM based on a 3-month convenience sample. Townsend (1964) mentions one case of mastoiditis in the symptomatic treatment plus myringotomy group of his study, which included two patients, but he does not comment explicitly on suppurative complications in the other treatment groups, including the 218 who were treated symptomatically.

Table 25. Mastoiditis/suppurative complications and AOM: no antibiotic and associated antibiotic arms from cohort and randomized controlled studies^1^

Article/Year | Time of Study; Locale | Antibiotic | Age | Otitis-Prone Status | Denominator | Mastoiditis | Other Suppurative Complication
Cohort Studies ^2^
Bollag/1991 | 2/86-2/88; Switzerland | none | mean 51.0 m ^3^ (SEM 35.9 m) | not addressed | 153 | 0 | 0 (meningitis)
Bollag/1991 | 3/88-2/89; Switzerland | none | mean 68.6 m ^3^ (SEM 38.9 m) | not addressed | 56 | 0 | 0(meningitis)
Ostfeld/1988 | 3/81-2/83; Locale not noted | none | <6 m=110 ^4^ pts 7-12 m=166pts 13-24m=75pts >24 m=46pts | not addressed | 397 | 2 | 0 (meningitis)
Ostfeld/1988 | 3/81-2/83; Locale not noted | antibiotics "for associated medical conditions" | <6 m=87 ^4^ pts 7-12 m=116pts 13-24 m=67pts >24 m=26pts | not addressed | 196 | 3 | 0 (meningitis)
Randomized Controlled Studies
Burke/1991 | 10/86-4/87, 10/87-4/88, 10/88-4/89; Southampton, Bristol, and Portsmouth, England | placebo | 3-5 y=66pts 6-9 y=52pts | previous AOM: 0-2 55 >2 48 | 111 ^5^ | 0 | 0 (meningitis)
Burke/1991 | 10/86-4/87, 10/87-4/88, 10/88-4/89; Southampton, Bristol, and Portsmouth, England | amoxicillin | >3 y < 10 y | not specified for this group ^6^ | 110 ^5^ | 0 | 0 (meningitis)
Kaleida/1991 | 5/81-8/85; Pittsburgh, U.S.A. | placebo | <2 y=136pts 2-5 y=107pts 6-12 y=30pts | previous AOM in last year: 0/98 1-2/120 >2/55 | 170 from the nonsevere group | 0 ^7^ | 0 ^7^
Kaleida/1991 | 5/81-8/85; Pittsburgh, U.S.A. | amoxicillin | <2 y=133pts 2-5 y=108pts 6-12 y=22pts | previous AOM in last year: 0 105 1-2 100 >2 58 | 169 from the nonsevere group | 1 ^7^ | 0 ^8^
Thalin/1986 | 7/84-6/85; Halstad, Sweden | placebo | 2-15 y ^9^ | not specified for this group ^10^ | 159 ^11^ | 0 | 0
Thalin/1986 | 7/84-6/85; Halstad, Sweden | penicillin VK | 2-15 y ^9^ | not specified for this roup ^10^ | 158 ^11^ | 0 | 0
van Buchem/1981 | 1/79-3/79; Tilburg, The Netherlands | placebo | 2-12 y ^12^ | not addressed | 40 ^13^ | 0 | 0
van Buchem/1981 | 1/79-3/79; Tilburg, The Netherlands | amoxicillin | 2-12 y ^12^ | not addressed | 47 ^13^ | 0 | 0
Mygind/1981 | 11/77-4/78; Copenhagen, Denmark | placebo | mean 4.1 y | not addressed | 77 | 0 | 0
Mygind/1981 | 11/77-4/78; Copenhagen, Denmark | penicillin VK | mean 3.7 y | not addressed | 72 ^14^ | 1 ^14^ | 0
Laxdal/1970 | 1/66-9/68; Saskatchewan, Canada | none | <14 y ^15^ | not addressed | 48 | 0 ^16^ | 0 ^16^
Laxdal/1970 | 1/66-9/68; Saskatchewan, Canada | penicillin G or ampicillin | <14 y ^15^ | not addressed | 94 | 0 ^16^ | 0 ^16^

1 Mixed-treatment arms are not reported in this table.

2 In addition to these two cohort studies, van Buchem, Peeters, van't Hof (1985) mention two cases of mastoiditis in a 17-month study period for which the authors estimate a denominator of 4,860 children with AOM based on a 3-month convenience sample.

3 Lower age limit was not specified.

4 Lower and upper age limits were not specified. Counts are estimated from Figure 1 in Ostfeld, Segal, Kaufstein, et al. (1987).

5 This is the denominator for the 3-month follow up.

6 Of the total group (placebo plus amoxicillin), 53 percent of patients had 0-2 previous episodes of AOM, and 47 percent had >2 previous episodes of AOM.

7 These counts are by implication because no episodes of mastoiditis were reported in the "Complications" section of "RESULTS" nor any other suppurative complications in the placebo group.

8 It is not clear from the article if this child with unilateral paresis of the marginal mandibular nerve was in the nonsevere or severe group. She was on antimicrobial treatment.

9 Of the total group (placebo and penicillin VK), 51 episodes of AOM involved children 2 years old, and 266 episodes of AOM involved older children.

10 Of the total group (placebo and penicillin VK), 23 percent of the children had their first episode of AOM and as many as 27 percent had suffered from AOM more than 10 times.

11 The article does not indicate the denominators for serious complications. These were the denominators at the start of the study.

12 Of the total group (placebo and amoxicillin), 18 were 2 years old, and 153 were older.

13 Reference to "Complications" is reported for an observation period of 2 years, but a 2-year denominator is not reported. These were the denominators at the start of the study.

14 Mastoiditis occurred sometime after the "immediate period after treatment", so the choice of denominator was unclear. The denominator "72" was at the start of study. Denominators at 1 month and 3 months were not reported by study group.

Lower-age limit was not specified. Of the total group (no antibiotic and antibiotic), 50 percent were < 3 years old, 25 percent were 3-6 years old, 18 percent were 6-9 years old, and 7 percent were > 9 years old.

16 These counts are by implication because authors report "no serious complications."

The following articles of no antibiotic treatment of AOM do not report mastoiditis or suppurative complications as outcomes:

1. Cohort studies: Froom, Culpepper, Grob, et al. (1990); Tilyard, Dovey, and Walker (1997); Townsend (1964) [The author mentions 1 case of mastoiditis in a child in the symptomatic treatment plus myringotomy group that included 2 cases but does not comment on the presence or absence of suppurative complications in the other treatment groups, including the 218 cases that were treated symptomatically.]

2. Randomized controlled studies: Appelman, Claessen, Touw-Otten, et al. (1991); Halsted, Lepow, Balassanian, et al. (1968); Howie and Ploussard (1972)

The six randomized controlled studies listed in Table 25 have smaller sample sizes. No cases of mastoiditis or other suppurative complications were reported in the placebo or antibiotic arms of these studies. Of interest, two of these studies (Kaleida, Casselbrant, Rockette, et al., 1991; Ostfeld, Segal, Kaufstein, et al., 1988) included large proportions of children younger than 2 years of age. The footnotes to Table 25 detail some of the problems with these studies in addition to their small sample sizes and nonpopulation-based sample selection.

Despite these cautions, it appears that placebo or no antibiotic treatment in the setting of studies with close followup of patients is not necessarily associated with a high risk of mastoiditis or suppurative complications.

The natural history results must be considered in light of the role of antibiotic intervention in the "no antibiotic" treatment groups. Although the placebo or observational groups in all the studies were not treated initially with antibiotics, all nine of the randomized controlled trials and two of the six cohort studies mention clinical circumstances that would allow the investigator to administer antibiotics to children in the placebo or observational groups. Persistent symptoms or complications were common reasons for giving antibiotics to children in the placebo or observational groups. The majority of these studies had close followup of children, which allowed for timely clinical assessment. Most of the studies did not state explicitly how many children received antibiotics from these groups; however, in view of the criteria given for administering antibiotics, the numbers were probably small. (The only exception would be the Howie and Ploussard (1972) study where the investigators decided arbitrarily to give a majority of children in the placebo group amoxicillin starting at 2-5 days.) In most cases, the children in the placebo or observational group who received antibiotics were not removed from the study; in any case, the administration of antibiotics would not have had an effect on the early outcomes. This discussion also applies to the results on antibiotics vs. no antibiotics.

## Antibiotics vs. No Antibiotics

We asked the following: Are antibiotics effective (in terms of statistical significance and magnitude of absolute clinical benefit above and beyond placebo/observational/no treatment/natural history) in the initial treatment of uncomplicated AOM with respect to the outcomes delineated in the Scope of the Evidence Report (Appendix E.4)? When antibiotics are used in the initial treatment of uncomplicated AOM, which of the influencing factors delineated in the Scope of the Evidence Report (Appendix E.4) are associated with better outcomes when compared with placebo/observational/no treatment/natural history?

Before asking which antibiotics are effective in treating AOM, we first ask if antibiotics have any marginal benefit in the treatment of AOM compared with natural history. In the scientific setting, the randomized controlled trial is the ideal method to answer this question by comparing the effect of antibiotics to that of placebo or observational treatment as proxies for natural history.

## Previous Meta-Analyses

Del Mar, Glasziou, and Hayem (1997); Rosenfeld, Vertrees, Carr, et al. (1994); and Rosenfeld (1999b) have conducted quantitative syntheses assessing the marginal benefit of antibiotics in the treatment of AOM compared with placebo or observational therapy. Del Mar, Glasziou, and Hayem (1997) and Rosenfeld, Vertrees, Carr, et al. (1994) meet the validity criteria for systematic reviews of Oxman, Cook, and Guyatt (1994). Rosenfeld's (1999b) methodology is not described in detail, but it follows the guidelines of Oxman, Cook, and Guyatt (1994). A quantitative synthesis by Damoiseaux, van Balen, Hoes, et al. (1998) attempted to evaluate the effectiveness of antibiotic treatment of AOM in children younger than 2 years old, but examination of the report reveals that data from one of the four studies (Halsted, Lepow, Balassanian, et al., 1968) included children older than 2 years; in another study (Englehard, Cohen, Strauss, et al., 1989), the placebo group is treated with myringotomy as well. For these reasons, the results of the Damoiseaux, van Balen, Hoes, et al. (1998) quantitative synthesis will not be reported.

Concerning the Del Mar, Glasziou, and Hayem (1997) meta-analysis, we comment on several issues (Table 26). Studies were quantitatively synthesized without regard to antibiotic type. Del Mar, Glasziou, and Hayem (1997) looked at the presence of specific signs and symptoms at various points in time. For this reason, the Howie and Ploussard (1972) study was excluded from the meta-analysis because it did not report on these signs and symptoms. The study by Laxdal, Merida, and Jones (1970) also was excluded because it reported only on recurrences. Laxdal, Merida, and Jones (1970), however, do not specify recurrence as a criteria for inclusion in the study. Based on the studies included in their meta-analysis, Del Mar, Glasziou, and Hayem (1997) concluded that for children who had pain at 24 hours, the rate difference in pain at 2-7 days was 41 percent favoring antibiotic therapy (95 percent CI, 14 percent and 60 percent). In this group of children, the risk difference of contralateral otitis media was 43 percent favoring antibiotic therapy (95 percent CI, 9 percent and 64 percent). Del Mar, Glasziou, and Hayem (1997) did not demonstrate an effect of antibiotics on pain at 24 hours, tympanic membrane perforation, vomiting/diarrhea/rash, tympanometry at 1 month, tympanometry at 3 months, or recurrent AOM. They report no significant heterogeneity within the comparisons. Age and otitis-prone status are addressed by the following sentence in their discussion referring to the study by Burke, Bain, Robinson, et al. (1991): "Although we found some evidence of prolonged symptoms with placebo treatment among young children, those with previous episodes of otitis media, and those with bilateral AOM, the differences were small" (Del Mar, Glasziou, and Hayem, 1997).

Table 26. Summary of Del Mar, Glasziou, and Hayem (1997) meta-analysis

Title | Literature Sources | Paper Trail | Questions | Results | Author Conclusions/Reviewer Comments
Title | Literature Sources | Paper Trail | Questions | Results | Author Conclusions/Reviewer Comments
Are antibiotics indicated as initial treatment for children with acute otitis media? A meta-analysis. | Index Medicus manual search, 1958- 1965; MEDLINE, 1966-8/94; Current Contents, 1966-8/94; References of all retrieved articles; Not noted if non-English language articles were included. | Does not explain in detail the process of article selection and does not provide much descriptive information about the articles | 1). Do antibiotics in the treatment of AOM affect the resolution of pain: (a) at 24 hours? (b) at 2-7 days? 2). Do antibiotics in the treatment of AOM affect the incidence of tympanic membrane perforation? 3). Do antibiotics in the treatment of AOM affect the incidence of vomiting, diarrhea, or rash? 4). Do antibiotics in the treatment of AOM affect the resolution of deafness: (a) at 1 month? (b) at 3 months? 5). Do antibiotics in the treatment of AOM affect the incidence of contralteral AOM? 6). Do antibiotics in the treatment of AOM affect the incidence of recurrent AOM? | 1. (a) no, 124/318 vs. 125/315 1. (b) yes, less pain, 90/929 vs. 131/914, RD 41% of who still had pain at 24 hours (14%-60%) 2) possibly fewer perforations but not statistically significant, 7/190 vs. 14/191 3) yes, more vomiting, diarrhea, or rash, 57/345 vs. 38/353, OR 1.97(1. 19-3.25) 4) a) no, 64/183 vs. 66/193 4) b) possibly fewer deaf but not statistically significant, 38/182 vs. 49/188 5) yes, less contralateral AOM, 35/329 vs. 56/337, RD 43% (9%-64%) 6) no, 187/864 vs. 175/804 | "Many doctors and their patients may be disinclined to use antibiotics at first presentation of otitis media for so little benefit. Others may regard any potential benefit as worth the inconvenience of purchasing and administering the drugs and the risk of their (usually) minor complications." "...17 children must be treated at first presentation to prevent one child experiencing pain after 2-7 days..." (Pain resolves spontaneously within 24 hours in 60% and within 2-7 days in 86% without antibiotics.)
Are antibiotics indicated as initial treatment for children with acute otitis media? A meta-analysis. | Index Medicus manual search, 1958- 1965; MEDLINE, 1966-8/94; Current Contents, 1966-8/94; References of all retrieved articles; Not noted if non-English language articles were included. | Does not explain in detail the process of article selection and does not provide much descriptive information about the articles | | (Results are graphically displayed as ORs and in tabular counts with associated statistics, but the actual Ors and confidence intervals are not all reported. Two results are reported as RDs.) | The authors acknowledge the results may not be generalizable to "Third World communities". The authors suggest research to identify subgroups of children who would benefit from antibiotics. Very little discussion of the study's weaknesses by the authors. The authors do not calculate the "file drawer" effect estimate.
Are antibiotics indicated as initial treatment for children with acute otitis media? A meta-analysis. | Index Medicus manual search, 1958- 1965; MEDLINE, 1966-8/94; Current Contents, 1966-8/94; References of all retrieved articles; Not noted if non-English language articles were included. | Does not explain in detail the process of article selection and does not provide much descriptive information about the articles | | RD-rate difference | Published criticisms: 1) incorrect use of OR to calculate number needed to treat; using RD, the NNT is 23 (15-56) 2) diagnostic criteria that were not reported varied widely among the studies
Are antibiotics indicated as initial treatment for children with acute otitis media? A meta-analysis. | Index Medicus manual search, 1958- 1965; MEDLINE, 1966-8/94; Current Contents, 1966-8/94; References of all retrieved articles; Not noted if non-English language articles were included. | Does not explain in detail the process of article selection and does not provide much descriptive information about the articles | | OR-odds ratio | Possible RCTs Published Since Analysis: 11?

Inclusion Criteria | Quality Control
RCTs, antimicrobial drugs vs. placebo control | Yes (per Chalmers, Adams, Dickersin, et al., 1990) scores of 11, 10,10, 9, 8, 5, 5, and 2 (0-11 possible)
Exclusion Criteria | Articles/Patients
none noted | 6/1833 (The number of articles used for each analysis ranged from two to six)

Rosenfeld, Vertrees, Carr, et al. (1994) compared placebo or no drug treatment to two specific antibiotic classes as well as to all antibiotics (Table 27). Clinical response was defined by "the absence of all presenting signs and symptoms of AOM at the evaluation point closest to 7-14 days after therapy was started." For this reason, studies by Howie and Ploussard (1972), van Buchem, Dunk, and van't Hof (1981), and Thalin, Densert, Larsson, et al. (1986) were excluded from this meta-analysis. Synthesizing the data for two studies, the rate difference between those on penicillins and those on no antibiotic was 15.7 percent (95 percent CI, 4.7 percent and 26.7 percent). One of the two penicillin arms in this meta-analysis was actually penicillin-sulfisoxazole, and the authors explain in the methods section that "some clinicians consider penicillin-sulfisoxazole to be a standard-spectrum agent." (Rosenfeld, Vertrees, Carr, et al., 1994) Synthesizing data from three studies, the rate difference was 12.9 percent (95 percent CI, 6.8 percent and 19 percent) for aminopenicillins vs. no antibiotic; synthesizing data from four studies, the rate difference was 13.7 percent (95 percent CI, 8.2 percent and 19.2 percent) for any antibiotic vs. no antiobiotic (Rosenfeld, Vertrees, Carr, et al., 1994). The comparison groups were statistically homogeneous. The investigators acknowledge that these results may not be applicable to the "otitis-prone condition," although age as a specific influencing factor is not addressed (Rosenfeld, Vertrees, Carr, et al., 1994).

Table 27. Summary of Rosenfeld, Vertrees, Carr, et al. (1994) meta-analysis

Title | Literature Sources | Paper Trail | Questions | Results | Author(s)'s Conclusions/Reviewer(s)'s Comments
Title | Literature Sources | Paper Trail | Questions | Results | Author(s)'s Conclusions/Reviewer(s)'s Comments
Clinical efficacy of antimicrobial drugs for acute otitis media: Meta-analysis of 5400 children from thirty-three randomized trials^1^ | MEDLINE, 1/66-6/92 inclusive (English and foreign); Current Contents/Life Sciences, 3 months through 6/29/92; bibliographies of textbooks, review articles, source articles, symposium publications; three trials included in the analysis were from non-English language reports | Includes details on numbers of articles at each stage of selection and some descriptive information on included articles | 1) Are antimicrobial drugs more efficacious than placebo or no drug for the clinical resolution of AOM? 2) What is the efficacy of various antimicrobials vs. amoxicillin or ampicillin for the same end point? 3) How does study design affect observed rates of AOM control? 4) How do patient characteristics affect observed rates of AOM control? | 1) Comparisons with placebo/no drug: vs. PCN RD 15.7(4.7-26.7) vs. aminoPCN RD 12.9(6.8-19.0) vs. any ABX RD 13.7(8.2-19.2) 2) a) Comparisons with aminopenicillins: AMP vs. PCN RD −6.8(−15.2-1.5) AMP vs. PCN/SSX RD 0.9(−7.6-9.4) AminoPCN vs. ERY RD 3.1(−3.9-10.2) AminoPCN vs. TMP-SMX 0.2(−8.8-9.2) AMX vs. CFC RD 6.4(−10.2-22.9) AMX vs. CFX RD −3.9 (−10.4-2.6) 2) b) Comparisons with cefaclor: vs. ERY/SSX RD 7.0(−6.5-20.4) vs. AMX/CLV RD 2.8(−1.3-6.8) vs. CFX RD 1.2(−2.4-4.7) 3) RD was unrelated to year, publication year, outcome assessment day, requirement of MEE resolution for primary control, duration of treatment, cointerventions, other antimicrobial drugs, blinding protocol, compliance check, or the quality score. Diagnostic certainty as an independent variable had no significant impact on the regression analysis of RD as the dependent variable. 4) RD was unrelated to bilateral AOM and days since prior antibiotics. | 1) "Should antibiotics be part of the initial empiric therapy for AOM in children? Our meta-analysis suggests that the answer is a qualified yes....Six of every seven children with AOM either do not need antibiotics for primary control or will not respond to antibiotic therapy..." (spontaneous 81% resolution of symptoms without antibiotics) 2) "We did not detect any significant differences in comparative clinical efficacy for standard- vs. extended-spectrum antibiotics..."
Clinical efficacy of antimicrobial drugs for acute otitis media: Meta-analysis of 5400 children from thirty-three randomized trials^1^ | | Includes details on numbers of articles at each stage of selection and some descriptive information on included articles | primary end point: clinical response to antimicrobial therapy defined by absence or presence of presenting signs and symptoms 7-14 days after initiation of therapy including improved TM appearance if reported (somewhat vague description) secondary end point: presence or absence of MEE after resolution of acute infection as close to 30 days after initiation of therapy | (ORs also reported for the primary end point.) (None of the RDs for the secondary end point were significant.) | The authors note that these results apply to children older than 4 weeks of age for initial treatment of uncomplicated AOM and not to other situations.
Clinical efficacy of antimicrobial drugs for acute otitis media: Meta-analysis of 5400 children from thirty-three randomized trials^1^ | | Includes details on numbers of articles at each stage of selection and some descriptive information on included articles | | (ORs also reported for the primary end point.) (None of the RDs for the secondary end point were significant.) | Good discussion of study weaknesses by the authors. The authors do not calculate the "file drawer" effect estimate.
Clinical efficacy of antimicrobial drugs for acute otitis media: Meta-analysis of 5400 children from thirty-three randomized trials^1^ | | Includes details on numbers of articles at each stage of selection and some descriptive information on included articles | | (ORs also reported for the primary end point.) (None of the RDs for the secondary end point were significant.) | Possible RCTs Published Since Analysis: 25?

Inclusion Criteria | Quality Control
RCT; assessment of antimicrobial drugs; initial treatment; simple AOM | Yes (per Marchant and Shurin, 1982) score of 0.62+/-0.20 (0-1 possible)
Exclusion Criteria | Articles/Patients
studies of specific pathogens; myringotomy; OM not described; unable to extract data for ages 4 weeks to 18 years; most patients had treatment failure; most patients otitis prone | 33/5400 (each meta-analysis utilized at most 5 studies) (47% did not describe randomization procedure; control group could be another antibiotic; only 4 study arms out of 69 were placebo/no drug; double-blind not required; primarily industry funded (61%); included studies with length of treatment 2 days.)

RD=rate difference, OR=odds ratio,ABX=antimicrobial, AMP=ampicillin, AMX= amoxicillin, CFC=cefaclor, CFX=cefixime,CLV=clavulanate,ERY=erythromycin, PCN=penicillin,TM=tympanic membrance, MEE=middle ear effusion,TMP=trimethoprim,SMX=sulfamethoxazole, SSX=sulfisoxazole

Rosenfeld (1999b) extended the approach taken by Rosenfeld, Vertrees, Carr, et al. (1994) (Table 28) and synthesized the data without regard to the individual antibiotic. The assumption was that Rosenfeld (1999b) used the same methodology as Rosenfeld, Vertrees, Carr, et al. (1994) and the quality of the methods was the same as for the 1994 study. The studies that were excluded from Rosenfeld, Vertrees, Carr, et al. (1994) (Howie and Ploussard, 1972; Thalin, Densert, Larsson, et al., 1986; and van Buchem, Dunk, and van't Hof, 1981) were included in this present study due to the difference in outcomes being assessed. The difference in relief of pain and fever at 24 hours was derived from three studies and was 0 percent (95 percent CI, 7 percent and 8 percent). Aggregating five studies, Rosenfeld (1999b) found a rate difference of 4 percent in pain and fever relief when comparing the antibiotic groups to the untreated groups at 2 days (95 percent CI, 2 percent and 7 percent). Comparing antibiotic with no treatment, the rate of difference was 5 percent for pain and fever relief at 4-7 days -- based on four studies (95 percent CI, 3 percent and 14 percent). Using four studies, the rate difference was 13 percent in complete clinical resolution at 7-14 days in favor of antibiotic therapy (95 percent CI, 8 percent and 19 percent). The Rosenfeld (1999b) meta-analysis demonstrated minimal relief of pain and fever at 2 days -- but not at 24 hours or 4-7 days -- and a modest favorable difference in clinical resolution at 7-14 days for those children on antibiotics compared with those not on antibiotics. Rosenfeld (1999b) found that antibiotics were not effective in the resolution of otitis media with effusion following AOM when measured 4-6 weeks and 3 months after treatment of AOM. It was noted that the prevalence of otitis media with effusion following AOM does decrease with time (Rosenfeld 1999b).

Table 28. Summary of Rosenfeld (1999b) meta-analysis

Title | Literature Sources | Paper Trail | Questions | Results | Author Conclusions/Reviewer Comments
Title | Literature Sources | Paper Trail | Questions | Results | Author Conclusions/Reviewer Comments
What to expect from medical therapy. (Only the acute otitis media meta-analyses will be summarized here.) | MEDLINE, 1996 through July 1998; manual search of symposium proceedings, published otitis media meta-analyses, book chapters, bibliographies of retrieved articles | Does not describe the number of articles initially retrieved from the literature search and the reasons for article rejection. | 1) Are antimicrobials efficacious in the symptomatic relief of AOM pain and fever at 24 hours? 2) Are antimicrobials efficacious in the symptomatic relief of AOM pain and fever at 2-3 days? 3) Are antimicrobials efficacious in the symptomatic relief of AOM pain and fever at 4-7 days? 4) Are antimicrobials efficacious in the complete clinical resolution of AOM within 7-14 days? 5) Are antimicrobials efficacious in the resolution of OME 4-6 weeks after AOM treatment? 6) Are antimicrobials efficacious in the resolution of OME 3 months after AOM treatment? | Antibiotics vs. placebo/no antibiotic RD 0 (−7-8) (three studies; 633 subjects) 2) Antibiotics vs. placebo/no antibiotic RD 4 (2-7) (five studies; 1,241 subjects) 3) Antibiotics vs. placebo/no antibiotic RD 5 (−3-14) (four studies; 785 subjects) 4) Antibiotics vs. placebo/no antibiotic RD 13 (8- 19) (four studies; 612 subjects) 5) Antibiotics vs placebo/no antibiotic RD 3(−2-8) (5 studies, 1,447 subjects) 6) Antibiotics vs placebo/no antibiotic RD 5(−6-16) (2 studies, 371 subjects) | The author mentions that the results might not be generalizable to children with immune deficiencies, cleft palate, craniofacial anomalies, preexisting OME, complicated AOM, and concurrent bacterial infections, and that the 24 hour findings may not be generalizable to very young children. The author also mentions that the subjects in these studies may have less severe disease.
What to expect from medical therapy. (Only the acute otitis media meta-analyses will be summarized here.) | MEDLINE, 1996 through July 1998; manual search of symposium proceedings, published otitis media meta-analyses, book chapters, bibliographies of retrieved articles | Does not describe the number of articles initially retrieved from the literature search and the reasons for article rejection. | | | Because the results are presented in a textbook, details of the methodology are not presented (e.g., as the number of articles retrieved from the initial literature search and actual quality scores). Also, no measure of heterogeneity is presented; the author assumes that the random effects model will adjust for any heterogeneity. The chapter does have a good discussion on the importance, validity, and generalizability of each result.

Inclusion Criteria | Quality Control
Randomized controlled trial | Quality scores are not reported. A statement is made that all of the studies in these meta-analyses were randomized and all but one were blinded.
Exclusion Criteria | Articles/Patients
Not mentioned | See "ANSWER(S)"

RD=rate difference

OME=otitis media effusion

## Comparisons

The general principle agreed upon was to compare individual antibiotics with placebo or observational treatment (Table 15). The project staff felt that practitioners choose an individual antibiotic, not an antibiotic class, when prescribing an antibiotic for treatment of AOM.

Individual antibiotics have unique characteristics whose marginal effects on treatment of AOM may be lost by grouping. These marginal effects may be due to antibacterial spectrum, pharmacokinetics, bioavailability, and minimum inhibitory concentrations to specific organisms. In addition, previous meta-analyses (described above) grouped all antibiotics together without regard to antibacterial spectrum or pharmacokinetic properties (Del Mar, Glasziou, and Hayem, 1997; Rosenfeld, 1999b; Rosenfeld, Vertrees, Carr, et al., 1994). The project staff decided that specific comparisons would not need to be repeated unless new studies had been subsequently published that may have had significant effect on the estimate.

### Ampicillin or Amoxicillin vs. Placebo or Observation

#### Study populations

The randomized controlled trials comparing ampicillin or amoxicillin with placebo or observational treatment include Halsted, Lepow, Balassanian, et al. (1967); Laxdal, Merida, and Jones (1970); Howie and Ploussard (1972); van Buchem, Dunk, and van't Hof (1981); Burke, Bain, Robinson, et al. (1991); and Kaleida, Casselbrant, Rockette, et al. (1991). The age and otitis-prone status of the study populations in these investigations are described in the Natural History section of this chapter.

#### Outcomes

The outcomes assessed in these studies are as described in the Natural History section. Rosenfeld (1999b) examined the issue of pain and fever resolution, middle ear effusion, and clinical resolution of symptoms at 7-14 days. An outcome common to three or more of the studies that has not been evaluated is clinical success or failure at 2-7 days. The difficulties with using success or failure as an outcome are detailed in the Natural History section. In particular, Howie and Ploussard (1972) defined failure as the presence of exudate at 2-7 days -- a definition which was unlike those of the other studies -- that included some measure of sign or symptom resolution. van Buchem, Dunk, and van't Hof (1981) did not measure clinical success or failure at 2-7 days, and it was not included in this meta-analysis. Another difficulty was that the data in Kaleida, Casselbrant, Rockette, et al., (1991) used the number of episodes as a denominator rather than the number of unique patients. Episodes are not independent of each other because a patient could have more than one episode of AOM within the study period. The failure of a patient to respond during one episode of AOM is not independent from that patient's response during a subsequent episode of AOM.

#### Results

A meta-analysis was performed to synthesize the data from Halsted, Lepow, Balassanian, et al. (1967); Laxdal, Merida, and Jones (1970); Howie and Ploussard (1972); Burke, Bain, Robinson, et al. (1991); and Kaleida, Casselbrant, Rockette, et al. (1991) with respect to failure at 2-7 days comparing placebo or observational treatment with ampicillin or amoxicillin (Table 29, and Figures 2 and 3). This collection of studies is statistically heterogeneous, suggesting the presence of differences in the populations studied and/or research methods employed. Therefore, caution is advised in interpreting overall summary measures. The random effects model calculates a rate difference of −12.3 (95 percent CI, 21.8 and −2.8). In other words, eight children with AOM would have to be treated with ampicillin or amoxicillin to avoid a case of clinical failure. Sensitivity analyses removing various studies did not materially effect the point estimate of −12.3. Subgroup analysis by age or otitis-prone status was not possible (Tables 30 and 31, Figures 4 and 5).

Table 30. Comparison 1: Meta-Analysis 1.2 -- Key question 3: ampicillin/amoxicillin vs. placebo; outcome indicator: failure rate at 2-7 days of treatment (excluded Howie studies)

Study (First Author) | Year | Risk Factor 1 Age <2yr | Risk Factor 2 Otitis Prone (Prior episodes) | Amoxicillin/Ampicillin Sample Size | Placebo Sample Size | Amoxicillin Failure Rate (%) | Placebo Failure Rate (%) | Rate Difference (%) | 95%CI of Rate Difference (%)
Halsted | 1967 | 75% <2yr | Not addressed | 30 | 27 | 33.3 | 25.9 | 7.4 | (−16.2, 31.0)
Laxdal | 1970 | 49% <3yr | Not addressed | 49 | 48 | 10.2 | 37.5 | −27.3 | (−43.4, −11.2)
Burke | 1991 | 0% <2yr | 47%>2 epi | 114 | 118 | 1.8 | 14.4 | −12.7 | (−19.4, −5.9)
Kaleida | 1991 | 50% <2yr | Not addressed | 488 | 492 | 3.9 | 7.7 | −3.8 | (−6.7, −0.9)
Random effects estimates | | | | 681 | 685 | 6.1 | 19.3 | −9.7 | (−19.2, −0.2)
Test of heterogeneity Chi-square test value | | | | | | 16.63 | 24.33 | 13.71
Test of heterogeneity Chi-square test p value | | | | | | 0.001 | <0.001 | 0.003 | NNT=−10 (−437, −5)

CI=confidence interval

NNT=number needed to treat

Table 31. Comparison 1: Meta-Analysis 1.3 -- Key question 3: ampicillin/amoxicillin vs. placebo; outcome indicator: failure rate at 2-7 days of treatment (excluded Howie, and Kaleida studies)

Study (First Author) | Year | Risk Factor 1 Age <2yr | Risk Factor 2 Otitis Prone (Prior episodes) | Amoxicillin/Ampicillin Sample Size | Placebo Sample Size | Amoxicillin Failure Rate (%) | Placebo Failure Rate (%) | Rate Difference (%) | 95%CI of Rate Difference (%)
Halsted | 1967 | 75%<2yr | Not addressed | 30 | 27 | 33.3 | 25.9 | 7.4 | (−16.2, 31.0)
Laxdal | 1970 | 49%<3yr | Not addressed | 49 | 48 | 10.2 | 37.5 | −27.3 | (−43.4, −11.2)
Burke | 1991 | 0%<2yr | 47%>2 epi | 114 | 118 | 1.8 | 14.4 | −12.7 | (−19.4, −5.9)
Random effects estimates | | | | 193 | 193 | 12.5 | 25.0 | −12.9 | (−27.5, 1.7)
Test of heterogeneity Chi-square test value | | | | | | 16.22 | 9.69 | 5.89
Test of heterogeneity Chi-square test p value | | | | | | <0.001 | 0.008 | 0.053

CI=confidence interval

Table 29. Comparison 1: Meta-Analysis 1.1 -- Key question 3: ampicillin/amoxicillin vs. placebo; outcome indicator: failure rate at 2-7 days of treatment

Study (First Author) | Year | Risk Factor 1 Age <2 yr | Risk Factor 2 Otitis Prone (Prior episodes) | Amoxicillin/Ampicillin Sample Size | Placebo Sample Size | Amoxicillin Failure Rate (%) | Placebo Failure Rate (%) | Rate Difference (%) | 95% CI of Rate Difference (%)
Halsted | 1967 | 75% <2 yr | Not addressed | 30 | 27 | 33.3 | 25.9 | 7.4 | (−16.2, 31.0)
Laxdal | 1970 | 49% <3 yr | Not addressed | 49 | 48 | 10.2 | 37.5 | −27.3 | (−43.4, −11.2)
Howie | 1972 | 100% <2.5 yr | Not addressed | 36 | 116 | 52.8 | 79.3 | −26.5 | (−44.4, −8.6)
Burke | 1991 | 0% <2 yr | 47%>2 episodes | 114 | 118 | 1.8 | 14.4 | −12.7 | (−19.4, −5.9)
Kaleida | 1991 | 50% <2 yr | Not addressed | 488 | 492 | 3.9 | 7.7 | −3.8 | (−6.7, −0.9)
Random effects estimates | | | | 717 | 801 | 13.6 | 32.9 | −12.3 | (−21.8, −2.8)
Test of heterogeneity Chi-square test value | | | | | | 51.37 | 341.00 | 18.83
Test of heterogeneity Chi-square test p value | | | | | | <0.001 | <0.001 | 0.002
NNT=−8 (−36, −5)

CI=confidence interval

NNT=number needed to treat

Figure 2. Shrinkage plot for outcome=failure rate at 2-7 days of treatment Comparison 1: Meta-analysis 1.1=ampicillin/amoxicillin vs. placebo

Figure 3. Funnel plot for outcome=failure rate at 2-7 days of treatment Comparison 1: Meta-analysis 1.1=ampicillin/amoxicillin vs. placebo

Figure 4. Shrinkage plot for outcome=failure rate at 2-7 days of treatment Comparison 1: Meta-analysis 1.2=ampicillin/amoxicillin vs. placebo (excluding Howie study)

Figure 5. Shrinkage plot for outcome=failure rate at 2-7 days of treatment Comparison 1: Meta-analysis 1.3=ampicillin/amoxicillin vs. placebo (excluding Howie and Kaleida studies)

### Other Antibiotics vs. No Antibiotics

Other treatment regimens that were compared were the following: amoxicillin-clavulanate, penicillin G plus sulfisoxazole, penicillin V, erythromycin estolate, triple-sulfonamide, and erythromycin estolate-triple sulfonamide vs. placebo or observation.

#### Study Populations

Appelman, Claessen, Touw-Otten, et al. (1991) compared amoxicillin-clavulanate with placebo or observational treatment; Halsted, Lepow, Balassanian, et al. (1967) compared penicillin G plus sulfisoxazole; Laxdal, Merida, and Jones (1970) and Mygind Meistrup-Larsen, Thomsen, et al. (1981), penicillin V; Howie and Ploussard (1972) compared erythromycin-estolate, triple sulfonamide, and erythromycin-estolate-triple-sulfonamide. The issues regarding the age of these populations and their otitis-prone state are discussed in the Natural History section of this chapter.

#### Outcomes

The issues regarding these outcomes are the same as those described in the Natural History section.

#### Results

Sixteen percent of patients on amoxicillin-clavulanate had pain or fever after 3 days compared with 18 percent of those on placebo; for children younger than 2 years of age, 58 percent in the placebo group had pain or fever after 3 days compared with 27 percent in the amoxicillin-clavulanate group (Appelman, Claessen, Touw-Otten, et al., 1991). Twenty-two percent of those taking penicillin G plus sulfisoxazole were not improved at 24-72 hours compared with 26 percent in the placebo group (Halsted, Lepow, Balassanian, et al., 1968). At 14-18 days, none of the placebo group had failed while 8 percent in the penicillin G plus sulfisoxazole had not resolved. However, the denominator was small in this study. In the Laxdal, Merida, and Jones (1970) study, 38 percent failed in the observational group and 24 percent failed in the penicillin V group. In the Mygind, Meistrup-Larsen, Thomsen, et al. (1981) study, 79 percent of those on penicillin V were symptom-free by 2 days, and 86 percent had satisfactory clinical course during the acute phase; in the placebo group, the proportions were 62 percent and 69 percent. Howie and Plousard (1972) looked exclusively at the presence of exudate at 2-7 days and found that exudate was present in 79 percent of the placebo group, 76 percent of those taking erythromycin-estolate, 70 percent of those taking triple-sulfonamide, and 49 percent of those taking erythromycin-estolate-triple-sulfonamide. In general, these studies showed a modest effect of antibiotics other than ampicillin or amoxicillin on clinical failure rates (Evidence Table 2).

## Antibiotic vs. Antibiotic

Having established that antibiotics have some marginal effect on treatment of AOM, it is valid to ask if certain antibiotic regimens have greater marginal effect than others. We asked: Does the specific antibiotic regimen make a difference in outcome? The possibilities for antibiotic comparisons are limitless. These possibilities depend, in part, on differences of antibiotic, dosage, schedule, duration, and other factors. The Technical Expert Panel chose five antibiotic treatments to evaluate.

## Previous Meta-Analyses

Rosenfeld, Vertrees, Carr, et al. (1994) conducted a meta-analysis that investigated the clinical efficacy of antibiotics in the treatment of AOM (Table 27). The meta-analysis had good internal validity based on the criteria of Oxman, Cook, and Guyatt (1994). The primary outcome evaluated was clinical response defined by the absence of all presenting signs and symptoms of AOM at the evaluation point closest to 7-14 days after therapy was started (Rosenfeld, Vertrees, Carr, et al., 1994). The primary control rate for standard spectrum antibiotics -- defined as penicillin, erythromycin, or any aminopenicillin -- was 76.6 percent (95 percent CI, 59.9 percent and 93.3 percent) based on 26 study arms. For extended-spectrum antibiotics -- defined as antibiotics resistant to most beta-lactamases such as amoxicillin-clavulanate, trimethoprim-sulfamethoxazole, erythromycin-sulfisoxazole, penicillin-sulfisoxazole, or any cephalopsorin -- the primary control rate was 85.9 percent (95 percent CI, 73.1 percent and 98.7 percent) based on 39 study arms. Rosenfeld, Vertrees, Carr, et al. (1994) also looked at several specific comparisons: ampicillin vs. penicillin, ampicillin vs. penicillin-sulfisoxazole, aminopenicillin vs. erythromycin, aminopenicillin vs. trimethoprim-sulfamethoxazole, amoxicillin vs. cefaclor, and amoxicillin vs. cefixime. The rate differences for all six of these comparisons was not significant (Table 27) and all but one comparison (amoxicillin vs. cefaclor) were statistically homogeneous (Rosenfeld, Vertrees, Carr, et al., 1994).

## Comparisons

The general principle agreed upon was to compare individual antibiotics with amoxicillin or trimethoprim-sulfamethoxazole (Table 16). (For the purposes of these comparisons, amoxicillin and ampicillin are grouped together.) The rationale for comparing individual antibiotics was the same as the one used for the analysis of antibiotics vs. no antibiotics (Key Question 3).

## Antibiotics Other than Amoxicillin or Trimethoprim-Sulfamethoxazole

Traditionally, the first-line antibiotics for treatment of AOM have been amoxicillin and trimethoprim-sulfamethoxazole (Rosenfeld, 1996). A question arose as to whether antibiotics other than these added any marginal benefit to the treatment of AOM. Many of the other antibiotics in question had theoretical benefits in terms of bacterial spectrum, pharmacokinetics, bioavailability, and minimum inhibitory concentrations to specific organisms; however, they also had greater costs and more possible side effects.

### Penicillin vs. Ampicillin or Amoxicillin

#### Study Populations

Three randomized controlled trials were evaluated that compared penicillin with ampicillin or amoxicillin (Bass, Cashman, Frostad, et al. 1973; Laxdal, Merida, and Jones, 1970; and Nilson, Poland, Thompson, et al. 1969). In one study (Milson, Poland, Thompson, et al., 1969), 79 percent of children were younger than 2 years of age; 49 percent of those children in the second study (Laxdal, Merida, and Jones, 1970) were younger than 3 years of age; and subjects in the third study (Bass, Cashman, Frostad, et al., 1973) ranged in age from 2 months to 12 years, but numbers for specific age strata were not reported. The otitis-prone status of the study patients was not addressed in any of these studies.

#### Outcomes

As seen in Evidence Table 3, the outcomes measured in these three studies were not uniform. The only outcome common to all three studies was failure at 7-14 days of treatment. The definitions of failure were not uniform across the studies (Table 32).

Table 32. Key Question 4a: meta-analysis comparisons (terms and definitions; success and failure)

Author/Year | Term(s) | Definition(s) | Time Measured
Penicillin vs. Ampicillin or Amoxicillin
SUCCESS
Laxdal/1970 | excellent | no evidence of middle ear inflammation | 7 days
Laxdal/1970 | good | signs of otitis media resolved | 14 days
Laxdal/1970 | fair | signs of otitis media resolved | 21 days
Bass/1973 | therapeutic effectiveness | no therapeutic failure, untoward reaction, or relapse | 4 weeks
FAILURE
Nilson/1969 | unsatisfactory | (1) marked injection >1/3 of TM or (2) marked decrease TM mobility on pneumatic otoscopy or (3) fluid level or bubbles or (4) otorrhea or (5) perforation or (6) marked distortion or obliteration of bony landmarks or (7) any degree of TM distension | 10-12 days
Laxdal/1970 | poor | persistent signs of minimal infection | 21 days
Laxdal/1970 | failure | no improvement or deterioration | 7 days
Bass/1973 | therapeutic failure | no improvement after 48 hours or exacerbation after initial improvement during 14 days of observation with repeat of therapy | <14 days
Cefaclor vs. Ampicillin or Amoxicillin
SUCCESS
Berman/1983 | satisfactory | total resolution of effusion with normal mobility or residual serous effusion | >5 days
Jacobson/1979 | cured | no fever, TM near normal appearance, no ear pain on exam | 1 week
McLinn/1980 | cure | disappearance or improvement of signs and symptoms during therapy and elimination or reduction to insignificant numbers of pathogen | 10-21 days
Giebink/1984 | satisfactory | absence of fever, irritability, otalgia, and TM erythema | 3 days after ending antibiotic
Ploussard/1984 | satisfactory | signs and symptoms had improved or disappeared | at end of therapy
FAILURE
Jacobson/1979 | improvement without cure | no fever, TM slowly resolving but some inflammation remaining | 1 week
Jacobson/1979 | no improvement | fever, pain, TM unaltered or worse | 1 week
McLinn/1980 | failure | no improvement of signs and symptoms of infection and persistence of pathogen on culture | 10-21 days
Berman/1983 | failure | otoscopic findings of persistent bacterial infections (e.g. yellow or red immobile, bulging TM) with symptoms such as irritability and fever | >5 days
Ploussard/1984 | unsatisfactory | no improvement of signs and symptoms at end of therapy | >3 days to end of therapy
Cefixime vs. Ampicillin or Amoxicillin
SUCCESS
McLinn/1987 | favorable=cure or improvement | absence of fever, irritability, otalgia, and TM erythema | 10 days
Leigh/1989 | cure | all symptoms resolved | 10-14 days
Leigh/1989 | improvement | significant improvement in symptomatology but without complete resolution | 10-14 days
Johnson/1991 | success | absence of fever, otorrhea, earache, and irritability | 3-5 days
Principi/1991 | cure, early outcome | normalization of clinical, otoscopic, and tympanometric findings | midtreatment and 15 days
Principi/1991 | improvement, early outcome | relief of acute signs and symptoms with ear effusion by otoscopy and tympanometry | midtreatment and 15 days
Principi/1991 | cure, late outcome | not failure at early outcome and resolution of otitis media with effusion per otoscopic tympanometric findings | 30, 60, and 90 days
Owen/1993 | improved | TM with dull appearance and decreased mobility or a dry perforation | 4-6 days, 10-13 days, 31-38 days
FAILURE
McLinn/1987 | failure | bacteriologic failure in those with repeat tympanocentesis or clinical failure including recurrence or inability to resolve fever and/or significant otalgia during therapy | 10 days
Leigh/1989 | failure | no response to therapy | 10-14 days
Johnson/1991 | failure | persistent fever, pain, irritability, or otorrhea | 3-5 days
Johnson/1991 | bacteriologic failure | pathogen not eradicated | 3-5 days
Principi/1991 | failure | persistence of signs and symptoms of AOM and/or need to discontinue treatment due to adverse effects | midtreatment and 15 days
Owen/1993 | bacterial failure | presence of bacterial pathogen in culture obtained while on or <24 hours after discontinuation of study medication | 4-6 days if without dry perforation, 10 days at discretion of investigator
Owen/1993 | clinical failure | continued or recurrent symptoms with red or yellow, bulging TM or purulent drainage with persistent perforation | 4-6 days, 10-13 days, 31-38 days
Cefaclor vs. Trimethoprim-sulfamethoxazole
SUCCESS
Blumer/1984 | satisfactory | absence of fever and otalgia and improved otologic exam | 9-10 days
Marchant/1984 | bacterial eradication | eradication of pathogens from the middle ear | 3-6 days
Marchant/1984 | symptomatic improvement | decreased irritability per parent or guardian or absence of fever | 3-6 days
FAILURE
Howie/1985 | unsatisfactory | bulging eardrum or middle-ear drainage | 14 days

#### Results

A meta-analysis was performed that synthesized the data on failure at 7-14 days from the three studies. The statistical test for heterogeneity was insignificant. The calculated rate difference was 4.5 percent (95 percent CI, −1.8 percent and 10.7 percent), which indicated no significant difference (Table 33 and Figure 6).

Table 33. Comparison 2: Meta-Analysis 2.1 -- Key question 4a: penicillin vs. ampicillin/amoxicillin; outcome indicator: failure rate at 7-14 days of treatment

Study (First Author) | Year | Risk Factor 1 Age <2yr | Risk Factor 2 Otitis Prone (Prior episodes) | Penicillin Sample Size | Amoxicillin or Ampicillin Sample Size | Penicillin Failure Rate (%) | Amoxicillin Failure Rate (%) | Rate Difference (%) | 95% CI of Rate Difference (%)
Nilson | 1969 | 79%<2yr | Not addressed | 96 | 101 | 28 | 25 | 3 | (−9, 16)
Laxdal | 1970 | 49%<3yr | Not addressed | 45 | 49 | 24 | 10 | 14 | (−1, 29)
Bass | 1973 | 2mo-12yr | Not addressed | 100 | 100 | 11 | 9 | 2 | (−6, 10)
Random effects estimates | | | | 241 | 250 | 20.6 | 14.4 | 4.5 | (−1.8, 10.7)
Test of heterogeneity Chi-square test value | | | | | | 10.85 | 9.86 | 1.97
Test of heterogeneity Chi-square test p value | | | | | | 0.004 | 0.007 | 0.374

CI=confidence interval

Figure 6. Shrinkage plot for outcome=failure rate at 7-14 days of treatment Comparison 2: Meta-analysis 2.1=penicillin vs. ampicillin/amoxicillin

The study by Laxdal, Merida, and Jones (1970) indicated that for children younger than age 3 years and those age 3-6 years, ampicillin might be more effective than penicillin in treating AOM. The authors reported a 15 percent failure rate for ampicillin vs. a 32 percent for penicillin in children younger than age 3, and 0 percent failure vs. 30 percent for children age 3-6 years, respectively. However, denominators were not provided for these estimates (Laxdal, Merida, and Jones, 1970) (Evidence Table 3). Nilson, Poland, Thompson, et al. (1969) provided estimates stratified by bacterial isolate, which suggested that ampicillin might be more effective than penicillin V in treating patients whose cultures yielded Haemophilus influenzae (29 percent failure vs. 67 percent, respectively) (Evidence Table 3). Due to lack of information reported in the studies, meta-analysis by subgroups was not performed.

### Cefaclor vs. Ampicillin or Amoxicillin

#### Study Populations

Five randomized controlled trials compared ampicillin or amoxicillin with cefaclor (Berman and Lauer, 1983; Giebink, Batalden, Russ, et al., 1984; Jacobson, Metcalf, Parkin, et al., 1979; McLinn, 1980; and Ploussard, 1984). The study by Berman and Lauer (1983) focused exclusively on infants age 1-3 months and in the study by Ploussard (1984), 84 percent of the subjects were younger than 2 years of age. McLinn (1980) reported that 45 percent of the subjects were younger than 2 years of age, and Giebink, Batalden, Russ, et al. (1984) reported 44 percent. Jacobson, Metcalf, Parkin, et al. (1979) listed an age range of 1-12 years and a mean age of 3.9 years. Giebink, Batalden, Russ, et al. (1984) reported that 41 percent of their study subjects had more than five previous episodes of AOM. The other studies did not address the otitis-prone state of their subjects.

#### Outcomes

As seen in Evidence Table 3, the outcomes had some commonalities and several differences. Two outcome indicators that were common to more than two studies in this group were failure rate at 3-7 days and failure rate at 5-21 days. As seen in Table 33, the definition of failure or its equivalent term was somewhat different among studies.

#### Results

The meta-analysis synthesized data from four studies for the outcome on failure at 3-7 days of treatment (Table 34 and Figure 7). Although the four studies appeared to be quite different with regard to the age of the study populations, the test for heterogeneity was insignificant. The rate difference was −5.4 percent for cefaclor vs. ampicillin or amoxicillin (95 percent CI, −15.2 percent and −4.4 percent), which indicates lack of statistical significance.

Table 34. Comparison 3: Meta-Analysis 3.1. Key question 4a: cefaclor vs. ampicillin/amoxicillin; outcome indicator: failure rate at 3-7 days of treatment

Study (First Author) | Year | Risk Factor 1 Age <2 yr | Risk Factor 2 Otitis Prone (Prior episodes) | Cefaclor Sample Size | Amoxicillin or Ampicillin Sample Size | Cefaclor Failure Rate (%) | Amoxicillin Failure Rate (%) | Rate Difference (%) | 95%CI of Rate Difference (%)
Jacobson | 1979 | 1-12 yr | Not addressed | 13 | 15 | 15 | 13 | 2 | (−24, 28)
Berman | 1983 | 1-3 mo | Not addressed | 19 | 21 | 26 | 29 | −2 | (−30, 25)
Giebink | 1984 | 44% <2 yr | 41%>5 episodes | 31 | 30 | 23 | 17 | 6 | (−14, 26)
Ploussard | 1984 | 84% <2 yr | Not addressed | 27 | 29 | 0 | 14 | −14 | (−26, −1)
Random effects estimates | | | | 90 | 95 | 14.6 | 16.8 | −5.4 | (−15.2, 4.4)
Test of heterogeneity Chi-square test value | | | | | | 14.85 | 1.79 | 3.05
Test of heterogeneity Chi-square test p value | | | | | | 0.002 | 0.616 | 0.383

CI=confidence intervals

Figure 7. Shrinkage plot for outcome=failure rate at 3-7 days of treatment Comparison 3: Meta-analysis 3.1=cefaclor vs. ampicillin/amoxicillin

Five studies were eligible for the meta-analysis that evaluated failure at 5-21 days (Table 35 and Figures 8 and 9). The studies were not statistically heterogeneous. The rate difference was 0.5 percent (95 percent CI; −5.7 percent and −6.8 percent), indicating no significant differences.

Table 35. Comparison 3: Meta-Analysis 3.2. Key question 4a: cefaclor vs. ampicillin/amoxicillin; outcome indicator: failure rate at 5-21 days of treatment

Study (First Author) | Year | Risk Factor 1 Age <2yr | Risk Factor 2 Otitis Prone (Prior episodes) | Cefaclor Sample Size | Amoxicillin or Ampicillin Sample Size | Cefaclor Failure Rate (%) | Amoxicillin Failure Rate (%) | Rate Difference (%) | 95% CI of Rate Difference (%)
Jacobson | 1969 | 1-12yr | Not addressed | 13 | 15 | 15 | 13 | 2 | (−24, 28)
McLinn | 1980 | 45% <2yr | Not addressed | 64 | 66 | 5 | 9 | 4 | (−13, 4)
Berman | 1983 | 1-3mo | Not addressed | 19 | 21 | 26 | 29 | −2 | (−30, 25)
Giebink | 1984 | 44% <2yr | 41%>5 episodes | 31 | 30 | 23 | 17 | 6 | (−14, 26)
Ploussard | 1984 | 84% <2yr | Not addressed | 27 | 29 | 0 | 14 | −14 | (−26, −1)
Random effects estimates | | | | 154 | 161 | 15.8 | 13.0 | 0.5 | (−5.7, 6.8)
Test of heterogeneity Chi-square test value | | | | | | 15.56 | 19.70 | 3.16
Test of heterogeneity Chi-square test p value | | | | | | 0.004 | 0.001 | 0.531

CI=confidence intervals

Figure 8. Shrinkage plot for outcome=failure rate at 5-21 days of treatment Comparison 3: Meta-analysis 3.2=cefaclor vs. ampicillin/amoxicillin

Figure 9. Funnel plot for outcome=failure rate at 5-21 days of treatment Comparison 3: Meta-analysis 3.2=cefaclor vs. ampicillin/amoxicillin

The Berman and Lauer (1983) study, which evaluated infants 1-3 months of age, also showed no difference in terms of treatment failure after 5 days of treatment (Evidence Table 3). Subgroup analysis by quantitative synthesis could not be performed by age or otitis-prone status due to lack of information reported in this group of studies.

### Cefixime vs. Ampicillin or Amoxicillin

#### Study populations

Five randomized controlled trials were evaluated for the comparison of cefixime with ampicillin or amoxicillin (Johnson, Carlin, Super, et al., 1991; Leigh, Robinson, and Millar, 1989; McLinn, 1987; Owen, Anwar, Nguyen, et al., 1993; and Principi and Marchisio, 1991). The study by McLinn (1987) included 61 percent of subjects younger than 2 years of age, and the Principi and Marchisio (1991) study included 40 percent in that age group. The subjects in the Johnson, Carlin, Super, et al. (1991) study had a mean age of 1.5 years and in the Owen, Anwar, Nguyen, et al. (1993) study, a mean age of 1.8 years. The mean age of subjects in the Leigh, Robinson, and Millar (1989) study was 4.9 years. Twenty-seven percent of children in the Johnson, Carlin, Super, et al. (1991) study had more than three prior episodes of AOM, and 26 percent in the Owen, Anwar, Nguyen, et al. (1993) study had more than two episodes. In the Principi and Marchisio (1991) study, 38 percent had one or more episodes of AOM; in the McLinn (1987) study, that number was 62.5 percent. Leigh, Robinson, and Millar (1989) did not address the otitis-prone status of their patients.

#### Outcomes

As seen in Evidence Table 3, a wide range of outcomes was measured in these five studies, and they were not always overlapping. Common outcomes included failure at 10-15 days, recurrence at 3-5 weeks, diarrhea, vomiting, and rash. Table 33 shows the differences in definition of failure.

#### Results

Four studies were used for the meta-analysis on failure at 10-15 days of treatment (Table 36 and Figure 10). The studies were statistically homogeneous. The calculated rate difference was −0.1 percent (95 percent CI, −4.2 percent and 3.9 percent), indicating that the rate difference was not statistically different from 0.

Table 36. Comparison 4: Meta-Analysis 4.1. Key question 4a: cefixime vs. ampicillin/amoxicillin; outcome indicator: failure rate at 10-15 days of treatment

Study (First Author) | Year | Risk Factor 1 Age <2yr | Risk Factor 2 Otitis Prone (Prior episodes) | Cefixime Sample Size | Amoxicillin or Ampicillin Sample Size | Cefixime Failure Rate (%) | Amoxicillin Failure Rate (%) | Rate Difference (%) | 95% CI of Rate Difference (%)
McLinn | 1987 | 61%<2yr | 62.5%>1 episodes | 30 | 34 | 3 | 3 | 0 | (−8, 9)
Leigh | 1989 | 6m-16yr | Not addressed | 150 | 150 | 5 | 5 | −1 | (−6, 4)
Principi | 1991 | 40%<2yr | 38%>1 episodes | 20 | 20 | 10 | 10 | 0 | (−19, 19)
Owen | 1993 | 2m-6yr | 26%>3 episodes | 74 | 61 | 26 | 23 | 3 | (−12, 17)
Random effects estimates | | | | 274 | 265 | 10.0 | 8.9 | −0.1 | (−4.2, 3.9)
Test of heterogeneity Chi-square test value | | | | | | 16.58 | 11.49 | 0.21
Test of heterogeneity Chi-square test p-value | | | | | | 0.001 | 0.009 | 0.976

CI=confidence interval

Figure 10. Shrinkage plot for outcome=failure rate at 10-15 days of treatment Comparison 4: Meta-analysis 4.1=cefixime vs. ampicillin/amoxicillin Comparison 4: Meta-analysis 4.1=cefixime vs. ampicillin/amoxicillin

Three studies were synthesized for the analysis on recurrence at 3-5 weeks (Table 37 and Figure 11). The studies were not heterogeneous. The rate difference (1.6 percent) was insignificant (95 percent CI, −5.1 percent and 8.4 percent).

Table 37. Comparison 4: Meta-Analysis 4.2. Key question 4a: cefixime vs. ampicillin/amoxicillin; outcome indicator: recurrence at 3-5 weeks of treatment

Study (First Author) | Year | Risk Factor 1 Age <2 yr | Risk Factor 2 Otitis Prone (Prior episodes) | Cefixime Sample Size | Amoxicillin or Ampicillin Sample Size | Cefixime Failure Rate (%) | Amoxicillin Failure Rate (%) | Rate Difference (%) | 95% CI of Rate Difference (%)
McLinn | 1987 | 61% <2 yr | 62.5% >1 episodes | 30 | 34 | 3 | 3 | 0 | (−8, 9)
Johnson | 1991 | 2m-13 yr | 27% >3 episodes | 20 | 20 | 15 | 15 | 0 | (−22, 22)
Principi | 1991 | 40% <2 yr | 38% >1 episodes | 20 | 20 | 5 | 0 | 5 | (−5, 15)
Random effects estimates | | | | 70 | 74 | 5.0 | 3.1 | 1.6 | (−5.1, 8.4)
Test of heterogeneity Chi-square test value | | | | | | 1.83 | 3.04 | 0.37
Test of heterogeneity Chi-square test p-value | | | | | | 0.401 | 0.291 | 0.832

CI=confidence intervals

Figure 11. Shrinkage plot for outcome=recurrence at 3-5 weeks of treatment Comparison 4: Meta-analysis 4.2=cefixime vs. ampicillin/amoxicillin

The five studies in this comparison group were included in three meta-analyses that looked at adverse effects presumably secondary to the antibiotics (Tables 38-40 and Figures 12-15). For diarrhea as the outcome, there was no heterogeneity in the rate difference; however, the heterogeneity of the incidence rates within antibiotic groups was significant. The rate difference was 8.4 percent (95 percent CI, 3.8 percent and 13.1 percent), favoring ampicillin or amoxicillin when compared with cefixime. Twelve children would need to be treated with ampicillin or amoxicillin rather than cefixime to avoid one case of diarrhea. For vomiting as the outcome, there was no heterogeneity statistically. The rate difference between cefixime and ampicillin or amoxicillin was 2 percent (95 percent CI, 0 percent and 4 percent), indicating no significant differences. For rash as the outcome, statistical heterogeneity existed in the incidence rates and rate difference. However, the rate difference of 5.8 percent (95 percent CI, −2.4 percent and 13.9 percent) was not significant.

Table 38. Comparison 4: Meta-Analysis 4.3. Key question 4a: cefixime vs. ampicillin/amoxicillin; outcome indicator: diarrhea as an adverse event

Study (First Author) | Year | Risk Factor 1 Age <2yr | Risk Factor 2 Otitis Prone (Prior episodes) | Cefixime Sample Size | Amoxicillin or Ampicillin Sample Size | Cefixime Failure Rate (%) | Amoxicillin Failure Rate (%) | Rate Difference (%) | 95% CI of Rate Difference (%)
McLinn | 1987 | 61% <2yr | 62.5% >1 episodes | 60 | 60 | 17 | 15 | 2 | (−11,15)
Leigh | 1989 | 6m-16yr | Not addressed | 150 | 150 | 13 | 3 | 9 | (3, 15)
Johnson | 1991 | 2m-13yr | 27% >3 episodes | 59 | 51 | 34 | 29 | 4 | (−13, 22)
Principi | 1991 | 40% <2yr | 38% >1 episodes | 20 | 20 | 15 | 15 | 0 | (−22, 22)
Owen | 1993 | 2m-6yr | 26% >3 episodes | 91 | 93 | 29 | 14 | 15 | (3, 26)
Random effects estimates | | | | 380 | 374 | 21.0 | 14.3 | 8.4 | (3.8, 13.1)
Test of heterogeneity Chi-square test value | | | | | | 15.70 | 26.36 | 2.95
Test of heterogeneity Chi-square test p value | | | | | | 0.003 | <0.001 | 0.567
NNT=12 (8, 27)

CI=confidence intervals

NNT=number needed to treat

Table 39. Comparison 4: Meta-Analysis 4.4. Key question 4a: cefixime vs. ampicillin/amoxicillin; outcome indicator: vomiting as an adverse event

Study (First Author) | Year | Risk Factor 1 Age <2yr | Risk Factor 2 Otitis Prone (Prior episodes) | Cefixime Sample Size | Amoxicillin or Ampicillin Sample Size | Cefixime Failure Rate (%) | Amoxicillin Failure Rate (%) | Rate Difference (%) | 95% CI of Rate Difference (%)
McLinn | 1987 | 61% <2yr | 62.5% >1 episodes | 60 | 60 | 12 | 2 | 10 | (1, 19)
Leigh | 1989 | 6m-16yr | Not addressed | 150 | 150 | 1 | 0 | 1 | (−1, 3)
Johnson | 1991 | 2m-13yr | 27% >3 episodes | 59 | 51 | 8 | 6 | 3 | (−7, 12)
Principi | 1991 | 40% <2yr | 38% >1 episodes | 20 | 20 | 5 | 0 | 5 | (−5, 15)
Owen | 1993 | 2m-6yr | 26% >3 episodes | 91 | 93 | 7 | 4 | 2 | (−4, 9)
Random effects estimates | | | | 380 | 374 | 5.8 | 1.6 | 2 | (0, 4)
Test of heterogeneity Chi-square test value | | | | | | 11.26 | 7.54 | 3.79
Test of heterogeneity Chi-square test p value | | | | | | 0.024 | 0.110 | 0.435

CI=confidence interval

Table 40. Comparison 4: Meta-Analysis 4.5. Key question 4a: cefixime vs. ampicillin/amoxicillin; outcome indicator: rash as an adverse event

Study (First Author) | Year | Risk Factor 1 Age <2yr | Risk Factor 2 Otitis Prone (Prior episodes) | Cefixime Sample Size | Amoxicillin or Ampicillin Sample Size | Cefixime Failure Rate (%) | Amoxicillin Failure Rate (%) | Rate Difference (%) | 95% CI of Rate Difference (%)
McLinn | 1987 | 61% <2 yr | 62.5% >1 episodes | 60 | 60 | 15 | 2 | 13 | (4, 23)
Leigh | 1989 | 6m-16 yr | Not addressed | 150 | 150 | 1 | 2 | −1 | (−4, 1)
Johnson | 1991 | 2m-13 yr | 27% >3 episodes | 59 | 51 | 22 | 10 | 12 | (−1, 26)
Owen | 1993 | 2m-6 yr | 26% >3 episodes | 91 | 93 | 14 | 10 | 4 | (−6, 13)
Random effects estimates | | | | 360 | 354 | 12.4 | 4.7 | 5.8 | (−2.4, 13.9)
Test of heterogeneity Chi-square test value | | | | | | 36.71 | 9.90 | 12.11
Test of heterogeneity Chi-square test p value | | | | | | <0.001 | 0.019 | 0.007

CI=confidence limits

Figure 12. Shrinkage plot for outcome=diarrhea as an adverse effect Comparison 4: Meta-analysis 4.3=cefixime vs. ampicillin/amoxicillin

Figure 13. Funnel plot for Outcome=diarrhea as an adverse effect Comparison 4: Meta-analysis 4.3=cefixime vs. ampicillin/amoxicillin

Figure 14. Shrinkage plot for outcome=vomiting as an adverse effect Comparison 4: Meta-analysis 4.4=cefixime vs. ampicillin/amoxicillin

Figure 15. Shrinkage plot for outcome=rash as an adverse event Comparison 4: Meta-analysis 4.5=cefixime vs. ampicillin/amoxicillin

The persistence of Haemophilus influenzae was reported as 0 of 10 in the cefixime group and 5 of 13 in the amoxicillin group in the Johnson, Carlin, Super, et al. (1991) study and 3 of 34 and 9 of 35, respectively, in the Owen, Anwar, Nguyen, et al. (1993) study. Subgroup analysis based on age or otitis-prone status was not reported in any of the studies and was not performed.

### Other Antibiotics vs. Ampicillin or Amoxicillin

Other treatment regimens we compared with ampicillin or amoxicillin included: cephalexin, cephradine, cefuroxime-axetil, ceftriaxone, loracarbef, erythromycin-estolate, erythromycin-ethylsuccinate, clarithromycin, clindamycin, triple sulfonamide, penicillin G plus sulfisoxazole, penicillin V plus sulfisoxazole, penicillin V plus triple sulfonamide, procaine-penicillin-benthazine-penicillin-G plus sulfisoxazole, erythromycin-ethylsuccinate-sulfisoxazole, erythromycin-ethylsuccinate-acetyl-sulfafurazole, and erythromycin-sulfisoxazole.

#### Study populations

The studies varied in age of subjects. Four studies were very clear in what proportion of subjects were younger than 2 years of age (Brodie, Griggs, and Cunningham, 1990; Halsted, Lepow, Balassanian, et al., 1967; Nilson, Poland, Thompson, et al., 1969; and Scholz and Noack, 1998). The majority of the remaining studies reported the mean age or age range.

#### Outcomes

Various outcomes were measured in these studies. The definitions for success and failure were not uniform (Evidence Table 3).

#### Results

All comparisons in this group showed no difference in various failure rates measured at various points in time. A few looked at age-stratified outcomes. No difference was found between cefuroxime-axetil and ampicillin when stratified by age (Brodie, Griggs, and Cunningham, 1990). Lenoski, Wingert, and Wehrle (1968), who compared erythromycin-ethylsuccinate with ampicillin, presented the failure at day 14, stratified by age. No difference was noted for subjects younger than 3 years of age, but the number of patients in the study was small. For those 3 years or older, none of the children on erythromycin-ethylsuccinate failed therapy, while 36 percent of those on ampicillin failed; again, the number of patients in the study was small. None of these studies stratified the findings by otitis-prone status (Evidence Table 3 and Table 41).

Table 41. Key Question 4a. Studies not in meta-analytic comparisons: age and otitis prone status

Brodie/1990 | Cefuroxime axetil | <2 years (36%) | Not addressed | No difference for failure 1-4 days; no difference stratified by age
Foshee/1992 | Loracarbef | Mean loracarbef 3.36 years and amoxicillin 3.59 years | Not addressed | No difference in failure at 7-10 days
Coles/1993 | Clarithromycin | Mean clarithromycin 5.8 years and amoxicillin 5.3 years | Not reported | No difference in failure at 6-9 days
Pukander/1993 | Clarithromycin | Range 1-12 years | Not addressed | No difference in failure at 48 hours
Kara/1998 | Cefuroxime-axetil (also ceftriaxone) | Range 6 months-6 years | Not addressed | No difference in failure at 5 days
Lenoski/1968 | EES; Triple sulfonamide (also EES+triple sulfonamide) | <3 years (58%) | Not addressed | No difference in failure at 14 days but numbers small; no difference stratified by age but numbers small
Scholz/1998 | Erythromycin estolate | <2 years (14%) | Not addressed | No difference in failure at 9-11 days nor recurrence up to 41 days
Feldman/1990 | Amoxicillin-clavulanate | Mean 60 months | Not addressed | Failure at 12-16 days was 7 of 101 in the TMP-SMX and 18 of 101 for amoxicillin-clavulanate, p=0.03

PCN=penicillin

EES=erythromycin ethylsuccinate

TMP-SMX=trimethoprim-sulfamethoxazole

Table 41. Key Question 4a. Studies not in meta-analytic comparisons: synopsis

Author/Year | Comparator Antibiotic | Age | Otitis Prone | Result
| Ampicillin or Amoxicillin vs.:
Bass/1967 | Procaine PCN+Bicillin+sulfisoxazole PCN V+sulfisoxazole Oxytetracycline | <5 years (70%); mean 3.6 years | Not addressed | No difference for failure <14 days for any comparator antibiotic
Halsted/1967, 1968 | PCN G+sulfisoxazole | <2 years (75%) | Not addressed | No difference for failure at 24-72 hours
Nilson/1969 | PCN V+sulfonamide (also PCN V) | <6 months (15%); 6-12 months (27%); 1-<2 years (36%); 2-3 years (21%) | Not addressed | No difference in unsatisfactory outcome at 10-12 days
Bass/1973 | PCN V+sulfisoxazole Erythromycin estolate (also PCN V) | <3 years ("half") | Not addressed | No difference in failure at <14 days or relapses
Feigin/1973 | Clindamycin | Mean 1.6 years | Not addressed | No difference in response at 3-4 days
Nassar/1974 | Cephalexin | Mean 4.9 years | Otitis prone (52%) | No difference in failure at 14 days
Stechenberg/1976 | Cephalexin | Mean 1.5 years | Not addressed | No difference in clinical response by 10 days
McLinn/1979 | Cephradine | Mean cephradine 1.9 years and amoxicillin 2.4 years | Not addressed | No difference in initial improvement or in overall outcome at 10 days or recurrence through 12 months
Rodriguez/1985 | Erythromycin sulfisoxazole | Mean 3.2 years | Not addresssed | No difference in failure at 10-14 days, recurrence at 30 days, or persistent middle ear effusion at 10-14 or 28 days

### Cefaclor vs. Trimethoprim-Sulfamethoxazole

#### Study populations

Three studies were eligible for this comparison (Blumer, Bertino, and Husak, 1984; Howie, Dillard, and Lawrence, 1985; and Marchant, Shurin, Turcyzk, et al., 1984). All children in the Marchant, Shurin, Turcyzk, et al. (1984) study were younger than 2 years of age. The subjects in the Blumer, Bertino, and Husak (1984) study ranged from 3 months to 7 years of age. Howie, Dillard, and Lawrence (1985) did not report on the ages of their patients. In the Blumer, Bertino, and Husak (1984) study, 38 percent of the patients were described as having recurrent otitis. In the other two studies, the issue of otitis-prone status was not addressed.

#### Outcomes

Some of the outcomes for each study are listed in Evidence Table 4. Of note, the Marchant, Shurin, Turcyzk, et al. (1984) study looked at bacterial persistence. The common outcome among these three studies was failure rate at less than 14 days of treatment. The definitions of failure are found in Table 33.

#### Results

Meta-analysis of the data from the three studies on the failure rate at less than 14 days of treatment comparing cefaclor with trimethoprim-sulfamethoxazole yielded a pooled rate difference of 5.5 percent (95 percent CI, −1.6 percent and 12.6 percent), a rate that was not statistically significant. Although the studies showed significant heterogeneity among failure rates, their rate differences were not significantly heterogeneous.

Data from the Marchant, Shurin, Turcyzk, et al. (1984) study showed that cefaclor had an overall bacterial persistence rate of 30 percent while that for trimethoprim-sulfamethoxazole was 5 percent; however, the number of subjects was small (Evidence Table 3).

### Amoxicillin-Clavulanate and Ceftriaxone vs. Trimethoprim-Sulfamethoxazole

#### Study populations

Two studies compared trimethoprim-sulfamethoxazole with amoxicillin-clavulanate or ceftriaxone (Barnett, Teele, Klein, et al., 1997 and Feldman, Sutcliffe, and Dulberg, 1990). One study (Barnett, Teele, Klein, et al., 1997) accounted for the otitis-prone status of their patients in the analysis.

#### Outcomes

As with the studies in the meta-analytic comparisons, the outcomes in this group also were diverse and nonuniform in the selection and definition of success and failure.

#### Results

No trend was observed favoring amoxicillin-clavulanate or ceftriaxone over trimethoprim-sulfamethoxazole or vice versa. In the Barnett, Teele, Klein, et al. (1997) study, those identified as otitis prone had a failure rate of 24 percent in the ceftriaxone group and 23 percent in the trimethoprim-sulfamethoxazole group. The respective numbers for the patients who were not otitis prone were 26 percent and 19 percent. The Barnett, Teele, Klein, et al. (1997) data suggested that the otitis-prone status of the child did not have an effect on the outcome of failure at 14 days.

### Utility of Oral Fluoroquinolones

No studies were found that compared oral fluoroquinolones with another antibiotic in the initial treatment of uncomplicated AOM in childhood.

## High Dose vs. Standard Dose of Amoxicillin-Clavulanate

As the incidence of bacterial resistance to antibiotics increases, modifications in treatment of AOM must be considered. These modifications may include use of different or new antibiotics or the use of familiar antibiotics in new ways. One proposal has been to increase the dosage of amoxicillin or amoxicillin-clavulanate. The question we posed was: What is the value of using > 60 mg/kg/day of amoxicillin or amoxicillin-clavulanate vs. the standard 40 mg/kg/day in the initial treatment of uncomplicated AOM?

### Study Populations

One study compared high-dose amoxicillin-clavulanate with standard-dose amoxicillin-clavulanate in the treatment of AOM in children, 43 percent of whom were younger than 2 years of age. The issue of otitis-prone status was not addressed (Bottenfield, Burch, Hedrick, et al., 1998).

### Outcomes

The study assessed clinical response at the end of therapy, recurrence at 22-28 days, and adverse effects (Bottenfield, Burch, Hedrick, et al., 1998).

### Results

The children on high-dose amoxicillin-clavulanate had a failure rate of 31 percent at the end of therapy, while those on standard dose had a 32 percent failure rate. Sixteen percent of the high-dose group had recurrence at 22-28 days, while 21 percent of the standard-dose group had recurrence. In the high-dose group, 50 percent experienced an adverse effect compared with 47 percent of those on the standard dose; this was true for vomiting specifically, 6 percent vs. 8 percent, respectively. Results were not reported by age (Evidence Table 4).

## Amoxicillin Therapy Twice a Day vs. Three Times a Day

Compliance with antibiotic treatment of AOM has been an issue. One proposal to increase compliance is to decrease the daily dosages of antibiotics from three to two.

### Study Populations

One study was identified that addressed the issue of high-dose amoxicillin two times a day vs. three times a day (Principi, Marchisio, Bigalli, et al., 1986). Fourteen percent of the patients were younger than 1 year old, and 67 percent were 1-5 years of age. Six percent had had three or more prior episodes of AOM, and 29 percent had had one or two prior episodes.

### Outcomes

Principi, Marchisio, Bigalli, et al. (1986) looked at clinical cure or failure and presence of unilateral or bilateral effusion at 15 days and clinical cure, presence of unilateral or bilateral effusion, and recurrence at 30 days, 60 days, and 90 days.

### Results

Reported outcomes were stratified by laterality of disease (Evidence Table 4). The only statistically significant difference between twice-daily amoxicillin and thrice-daily amoxicillin was the presence of bilateral effusion at 30 days followup in the group with initial unilateral disease. At 60-day and 90-day followup, this difference was not observed. The authors (Principi, Marchisio, Bigalli, et al. 1986) also noted that the persistence of middle ear effusion at 90 days "was independent of the number of previous episodes of the disease and of the age of the child at entry," although the data were not reported.

## Short-Term Vs. Long-Term Antibiotic Therapy

As already noted, compliance with antibiotic treatment of AOM has been an important issue to the practitioner and patient. Another proposal to increase compliance is to decrease the duration of therapy. The question we posed was: What is the comparative effectiveness of short-term vs. long-term antibiotic therapy in children younger than 2 years of age and those older than 2 years of age in the initial treatment of uncomplicated AOM?

### Previous Meta-Analyses

A meta-analysis was conducted that compared short-duration with long-duration antibiotic therapy for the treatment of AOM (Kozyrskyj, Hildes-Ripstein, Longstaffe, et al. 1998) (Table 42). The meta-analysis met the validity requirements listed in Oxman, Cook, and Guyatt (1994). The primary outcome evaluated was treatment failure, which was defined as the lack of clinical resolution or relapse or recurrence of AOM, during a 31-day period following the initiation of therapy. Clinical resolution meant that the presenting signs or symptoms of AOM had improved or resolved. The meta-analysis also looked at "the cumulative number of treatment failures, relapses, and recurrences reported from time of diagnosis until a final evaluation point between 1 to 3 months." Antibiotics in the short-duration arms of the comparison were grouped by "pharmacokinetic behavior" into short-acting oral antibiotics (i.e., penicillin V potassium, amoxicillin, cefaclor, cefuroxime), oral azithromycin, and intramuscular ceftriaxone. Duration of the short-acting oral antibiotics also was stratified into 48 hours or less and greater than 48 hours. Subgroup analyses that were based on two age groups (younger than and older than age 2 years) could not be conducted because the number of subjects was too small (Kozyrskyj, Hildes-Ripstein, Longstaffe, et al., 1998).

Table 42. Summary of Kozyrskyj, Hildes-Ripstein, Longstaffe, et al. (1998) meta-analysis

Title | Literature Sources | Paper Trail | Questions | Results | Author Conclusions/Reviewer Comments | Source | Inclusion Criteria | Quality Control | Authors | Exclusion Criteria | Articles/Patients
Treatment of Acute Otitis Media With a Shortened Course of Antibiotics: A Meta-analysis. | MEDLINE, 1/66-7/97; EMBASE, 1/74-7/97; Current Contents, 1/97-7/97; Science Citation Index searches; reference lists of relevant publications; no language restrictions and two trials included in the analysis were from non-English language reports | includes details on numbers of articles at each stage of selection and detailed descriptive information on included articles. | 1) Are short-acting antibiotics given for 48 hours or less as effective as antibiotics given for at least 7 days in treatment of AOM? 2) Are short-acting antibiotics given for more than 48 hours but < 5 days as effective as antibiotics given for at least 7 days of treatment of AOM? 3) Is ceftriaxone as effective as antibiotics given for 10 days treatment of AOM? 4) Is 3-5 days of azithromycin as effective as 10 days of another antibiotic in treatment of AOM? stratifications: older and younger than 2 years; perforated and nonperforated tympanic membranes primary outcome: treatment failure noted by lack of clinical resolution or relapse or recurrence of AOM during a 31-day period following therapy initiation as defined by improvement or resolution of presenting signs and symptoms secondary outcome: cumulative number of treatment failures, relapses, and recurrences from diagnosis until final evaluation at 1-3 months (MEE was not counted a treatment failure.) | 1) OR for treatment failure at less than one month 2.99(1.04-8.54) 2) a) OR for treatment failure at 8-10 days 1.38(1.15-1.66) 2) b) OR for treatment failure at 20-30 days 1.22(0.98-1.54) (Results 2) a) did not change with quality of study, adequacy of concealment of treatment allocation, exclusion of children with chronic or recurrent OM. 2) b) results for the most part were also not affected.) 3) OR for treatment failure at one month or less and at 3 months or less 1.25 (0.90-1.72) and 0.91 (0.57-1.47) respectively 4) OR for treatment failure 1.09 (0.86-1.38) OR for gastrointestinal side effects for short course versus long course short-acting antibiotics 0.54 (0.43-0.66) when amoxicillin-clavulanate was included in the analysis. Children on azithromyicin also had less likelihood of gastrointestinal side effects OR 0.26 (0.19-0.37) | 1) Short-acting antibiotics for < 48 hours is not as effective. 2) "Our meta-analysis results indicate that at an early evaluation point (8 to 19 days) a reduction in treatment from 10 to 5 days of short-acting antibiotics may slightly increase the risk of a child experiencing signs and symptoms or relapse or reinfection...However, by 30 days following initiation of therapy, a longer course of short-acting antibiotics was comparable to a 5-day course in terms of these outcomes...13 children would require treatment with a long course of antibiotics to prevent 1 excess failure following treatment with a shorter course....the risk difference at 1 month following treatment dropped to 2.3%...44 children requiring treatment with a longer course of antibiotics to prevent 1 failure following treatment." 3) Ceftriaxone was comparable. 4) Azithromycin was comparable. The authors state that subgroup samples were too small to assess the proposed stratifications. Good discussion of plausibility of results and weaknesses of the study by the authors. Possible RCTs published since analysis: 4? | JAMA | randomized controlled trials; treatment of AOM; comparing different durations of antibiotic treatment, fewer than 7 days vs at least 7 days; patients 4 weeks to 18 years age; no antimicrobial therapy at time of diagnosis; an assessment of clinical resolution of AOM | Yes (per Moher, Jadad, Nichol, et al., 1995) average score 2.66(SD,0.97) (0-5 possible) Also rated for concealment of treatment allocation. 9 trials in 8 articles reported adequate concealment | Kozyrskyj, Hildes-Ripstein, Longstaffe, et al., 1998 | planned surgical cointervention except myringotomy subsequent to treatment failure or tympanocentesis (use of a second antibiotic was deemed a treatment failure and not excluded) | 29 with 32 trials/9073 (each meta-analysis utilized at most 5 studies) (only 31% of studies on short-acting antiiotics excluded children with chronic or recurrent OM)

AOM=acute otitis media

MEE=middle ear effusion

OM=otitis media

OR=odds ration

RCT=randomized controlled trial

Synthesizing two studies on short-acting antibiotics given for 48 hours or less vs. long-duration therapy, the odds ratio was 2.99 (95 percent CI, 1.04 percent and 8.54 percent), which indicates a significant difference in risk when looking at treatment failure at less than 1 month followup; however, only two studies were quantitatively synthesized in this comparison. Comparing short-acting antibiotics given for more than 48 hours and less than 5 days vs. therapy of at least 7 days with treatment failure at 8-10 days as the outcome, the odds ratio was 1.38 (95 percent CI, 1.15 percent and 1.66 percent), which indicates a significant difference in risk. In the previous comparison, if the outcome was treatment failure at 20-30 days, the odds ratio was reduced to 1.22 (95 percent CI, 0.98 percent and 1.54 percent), indicating no significant difference in risk. These last two results were not affected by study quality, adequacy of treatment allocation concealment, or exclusion of subjects with chronic or recurrent otitis media.

The comparison of ceftriaxone to antibiotic duration of 10 days yielded an odds ratio for treatment failure at less than 1 month followup of 1.25 (95 percent CI, 0.90 percent and 1.72 percent), indicating no significant difference in risk. For treatment failure at less than 3 months followup, the odds ratio was 0.91 (95 percent CI, 0.57 percent and 1.47 percent), indicating no significant difference in risk. The meta-analysis on treatment for 3-5 days with azithromycin vs. 10-day therapy with another antibiotic yielded an odds ratio of 1.09 (95 percent CI, 0.86 percent and 1.38 percent), indicating no significant difference in risk.

It was concluded that treatment with short-acting antibiotics given for less than 48 hours was not as effective as antibiotic therapy given for at least 7 days (Kozyrskyj, Hildes-Ripstein, Longstaffe, et al., 1998), and that decreasing the duration of therapy from 10 days to 5 days might slightly increase the risk of treatment failure at 8-10 days (although by 30 days that difference would no longer exist). The latter conclusion is invalid because the difference in risk between 5-day and 10-day therapies at 20-30 days was not significant. In other terms, for the previous comparison, 13 children would need to be treated with the longer-duration therapy to prevent one excess failure that would occur with the 5-day treatment relative to 8-10 day treatment failure. Ceftriaxone and 3- to 5-day azithromycin seemed comparable to 10-day antibiotic treatment.

### Comparisons

Our analysis compared short-duration with long-duration antibiotic therapy of AOM. The short-duration arm was stratified into those regimens of less than 5-day duration and those with 5-day duration (Table 17). (For these comparisons, amoxicillin and ampicillin were grouped together.) The rationale for comparing individual antibiotics was the same as that provided for other parts of the analysis.

### Ceftriaxone (1 dose) vs. Amoxicillin (7-10 days)

#### Study populations

Three randomized controlled trials compared ceftriaxone single-injection therapy to 7- to 10-days of amoxicillin therapy (Green and Rothrock, 1993; Kara, Ozuer, Kilic, et al. 1998; and Varsano, Frydman, Amir, et al., 1988) (Table 43 and Figure 16). In the Varsano, Frydman, Amir, et al. (1988) study, the mean age was 2 years. The mean age of patients in the Green and Rothrock (1993) study was 1.8 years. The patients in the Kara, Ozuer, Kilic, et al. (1998) study ranged in age from 6 months to 6 years, but the mean age or age distribution was not reported. Fifty-eight percent of patients in the Varsano, Frydman, Amir, et al. (1988) study had more than two previous episodes of AOM, compared to 18 percent in the Green and Rothrock (1993) study. The Kara, Ozuer, Kilic, et al. (1998) study did not address the issue of the otitis-prone state.

Table 43. Comparison 9: Meta-Analysis 9.1. Key Question 4e: Ceftriaxone (1 dose) with amoxicillin (7-10d) outcome indicator: failure rate at 5-10 days of treatment

Study (First Author) | Year | Risk Factor 1 Age <2yr | Risk Factor 2 Otitis Prone (Prior episodes) | Ceftriaxone Sample Size | Amoxicillin Sample Size | Ceftriaxone Failure Rate (%) | Amoxicillin Failure Rate (%) | Rate Difference (%) | 95% CI of Rate Difference (%)
Varsano | 1988 | 6 mo-8 yr | 58% >2 epidoes | 22 | 22 | 18 | 14 | 5 | (−17, 26)
Green | 1993 | 5 mo-5 yr | 18% >2 episodes | 105 | 107 | 6 | 3 | 3 | (−3, 8)
Kara | 1998 | 6 mo-6 yr | Not addressed | 25 | 25 | 16 | 8 | 8 | (−10, 26)
Random effects estimates | | | | 152 | 154 | 10.5 | 5.1 | 3.4 | (−1.6, 8.5)
Test of heterogeneity Chi-square test value | | | | | | 3.65 | 2.79 | 0.30
Test of heterogeneity Chi-square test p value | | | | | | 0.161 | 0.248 | 0.862

CI=confidence intervals

Figure 16. Shrinkage plot for outcome=failure rate at 5-10 days of treatment Comparison 9: Meta-analysis 9.1=ceftriaxone (1 Dose) vs. ampicillin/amoxicillin (7-10 days)

#### Outcomes

The studies looked at different types of outcomes (Evidence Table 5). The outcome common to all three studies was failure rate at 5-10 days, but the definitions of failure were different. In particular, one study (Green and Rothrock, 1993) defined two terms, one failure and the other unsuccessful. Unsuccessful included both failed cases and cases with complications (Table 45).

Table 45. Key Question 4e. Meta-analysis comparisons: terms and definitions; success and failure

Author/Year | Term(s) | Definition(s) | Time Measured
Ceftriaxone (1 injection) vs. Amoxicillin (7-10 days)
SUCCESS
Varsano/1988 | satisfactory | resolution of middle ear fluid and of signs and symptoms of AOM or persistence of some degree of effusion but without erythema or bulging and with no fever or pain | 7 days, 30 days
Green/1993 | Successful | resolution of AOM symptoms and no return of symptoms within 10 days of emergency department visit | 10 days, measured at 90 days
FAILURE
Varsano/1988 | failure, early | persistence or recurrence of fever and/or pain with otoscopic signs of acute ear infection or spontaneous otorrhea during the first 10 days | 7 days
Green/1993 | unsuccessful | not successful | 10 days, measured at 90 days
Green/1993 | failure | persistence or recurrence of symptoms within 10 days of initiating treatment | 10 days, measured at 90 days
Kara/1998 | no improvement or treatment failure | based on "resolution of symptoms and clinical and tympanometric appearance of the tympanic membrane" | 5 days
Azithromycin (<5 days) ves. Amoxicillin-Clavulanate (7-10 days)
SUCCESS
Pestalozza/1992 | cured | normalization of clinical, otoscopic, and tympanometric findings | 3-5 days, 12-14 days, 30 days
Pestalozza/1992 | improved | relief of acute signs and symptoms with persistent middle ear effusion | 3-5 days, 12-14 days, 30 days
Daniel/1993 | cured | resolution of signs and symptoms of primary infection | 3-5 days, 10-12 days
Daniel/1993 | improvement | signs and symptoms subsided but with incomplete resolution | 3-5 days, 10-12 days
Schaad/1993 | cure | disappearance of baseline symptoms of infection | 7-20 days
Principi/1995 | bacterial eradication | baseline pathogen not isolated upon repeat sampling or no culturable material obtainable because of clinical cure | 10-14 days, aspirate only if no improvement
Principi/1995 | cured | all pretreatment signs and symptoms disappeared | 10-14 days
Principi/1995 | Improved | Improvement or partial disappearance of pretreatment signs and symptoms | 10-14 days
Arguesdas/1996 | satisfactory | complete resolution of initial symptoms regardless of middle ear fluid | 10-11 days
FAILURE
Pestalozza/1992 | failed | no change or worsening of pretreatment signs | 3-5 days, 12-14 days, 30 days
Daniel/1993 | failure | no apparent clinical response | 3-5 days, 10-12 days
Schaad/1993 | failure | no change in or worsening of symptoms from baseline | 7-20 days
Principi/1995 | bacterial persistence | baseline pathogen present in post therapy sample | 10-14 days, aspirate only if no improvement
Principi/1995 | failed | no change or worsening of pretreatment signs and symptoms | 10-14 days
Arguesdas/1996 | failure | bacteriologic or clinical failure | 10-11 days
Arguesdas/1996 | bacteriologic failure | inability to sterilize the middle ear fluid in patients with persistent ear drainage or who had repeated tympanocentesis | at discretion of investigator

#### Results

The meta-analysis on failure at 5-10 days synthesized data from three of the eligible studies. The studies were statistically homogeneous. Using "failure" rather than "unsuccessful" as the outcome in one study (Green and Rothrock, 1993), the estimated combined rate difference was 3.4 percent (95 percent CI, −1.6 percent and 8.5 percent) (Table 43 and Figure 16). Also, the results were not sensitive to the choice of outcome in that study (Green and Rothrock, 1993). Subgroup analysis by age or otitis-prone status was not possible (Table 44 and Figure 17).

Table 44. Comparison 9: Meta-analysis 9.2. Key Question 4e: Ceftriaxone (1 dose) vs. amoxicillin (7-10d) outcome indicator: failure rate at 5-10 days of treatment (criterion of failure relaxed to include complications in Green study)

Study (First Author) | Year | Risk Factor 1 Age <2yr | Risk Factor 2 Otitis Prone (Prior episodes) | Ceftriaxone Sample Size | Amoxicillin Sample Size | Ceftriaxone Failure Rate (%) | Amoxicillin Failure Rate (%) | Rate Difference (%) | 95% CI of Rate Difference (%)
Varsano | 1988 | 6 mo-8 yr | 58% >2 episodes | 22 | 22 | 18 | 14 | 5 | (−17, 26)
Green | 1993 | 5 mo-5 yr | 18% >2 episodes | 105 | 107 | 10 | 9 | 1 | (−7, 9)
Kara | 1998 | 6 mo-6 yr | Not addressed | 25 | 25 | 16 | 8 | 8 | (−10, 26)
Random effects estimates | | | | 152 | 154 | 12.0 | 9.5 | 2.5 | (−4.4, 9.5)
Test of heterogeneity Chi-square test value | | | | | 1.12 | 0.40 | 0.51
Test of heterogeneity Chi-square test p value | | | | | 0.570 | 0.819 | 0.775

CI=confidence intervals

Figure 17. Shrinkage plot for outcome=failure rate at 5-10 days of treatment Comparison 9: Meta-analysis 9.2=ceftriaxone (1 Dose) vs. ampicillin/amoxicillin (7-10 days) (criterion of failure relaxed to include complications in Green study)

### Azithromycin (<5 days) vs. Amoxicillin-Clavulanate (7-10 days)

#### Study populations

Five randomized controlled trials were eligible for the comparison of less than 5-day azithromycin therapy vs. 7- to 10-day amoxicillin-clavulanate therapy (Arguedas, Loaiza, Herrera, et al., 1996; Daniel, 1993; Pestalozza, Cioce, and Facchini, 1992; Principi, 1995; and Schaad, 1993). In the Pestalozza, Cioce, and Facchini (1992) study, patients had a mean age of 3 years. The proportion of patients younger than 2 years of age was 1 percent in the Daniel (1993) study, 7.5 percent in the Schaad (1993) study, and 25 percent in the Principi (1995) study. Arguedas, Loaiza, Herrera, et al. (1996) reported an age range of 6 months to 12 years. In the Principi (1995) study, 10 percent of the subjects had recurrent otitis media. The other studies did not report on the otitis-prone status of their subjects.

#### Outcomes

The outcomes measured in these studies are somewhat similar in terms of the global clinical outcome (Evidence Table 5). The common outcome in this comparison was failure at 10-14 days. (The definitions are found in Table 45).

#### Results

Synthesizing data on failure at 10-14 days for all five of these studies using a random effects model, the pooled rate difference is 2.1 percent (95 percent CI, 0.6 percent and 4.8 percent), indicating no significant differences (Table 46 and Figures 18 and 19). Although the failure rates were heterogeneous among studies, no statistical heterogeneity existed for rate differences.

Table 46. Comparison 10: Meta-analysis 10.1. Key question 4e: azithromycin (<5d) vs. amoxicillin-clavulanate (7-10d) outcome indicator: failure rate at 10-14 days of treatment

Study (First Author) | Year | Risk Factor 1 Age <2yr | Risk Factor 2 Otitis Prone (Prior episodes) | Azithromycin Sample Size | Amox-Clav Sample Size | Azithromycin Failure Rate (%) | Amox-Clav Failure Rate (%) | Rate Difference (%) | 95%CI of Rate Difference (%)
Pestalozza | 1992 | 11 mo-9 yr | Not addressed | 15 | 15 | 0 | 0 | 0 | (−, −)
Daniel | 1993 | 1% <2 yr | Not addressed | 103 | 54 | 6 | 0 | 6 | (1, 10)
Schaad | 1993 | 7.5% <2 yr | Not addressed | 192 | 189 | 3 | 1 | 3 | (−0, 5)
Principi | 1995 | 25% <2 yr | 10% recurrent | 203 | 182 | 8 | 6 | 2 | (−3, 7)
Arguedas | 1996 | 6 mo-12 yr | Not addressed | 47 | 45 | 0 | 4 | −4 | (−10, 2)
Random effects estimates | | | | 560 | 485 | 3.6 | 1.9 | 2.1 | (−0.6, 4.8)
Test of heterogeneity Chi-square test value | | | | | | 12.66 | 10.64 | 5.34
Test of heterogeneity Chi-square test p value | | | | | | 0.013 | 0.031 | 0.254

Amox-Clav=amoxicillin-clavulanate

Cl=confidence interval

Figure 18. Shrinkage plot for outcome=failure rate at 10-14 days of treatment Comparison 10: Meta-analysis 10.1=Azithromycin (<5d) vs. amoxicillin-clavulanate (7-10d)

Figure 19. Funnel plot for outcome=failure rate at 10-14 days of treatment Comparison 10: Meta-analysis 10.1=azithromycin (<5d) vs. amoxicillin-clavulanate (7-10d)

Principi (1995) stratified some of their results by age (Evidence Table 4). For those younger than 2 years of age, the 10- to 14-day failure rate was 18 percent (11 of 61 subjects) for the short-duration group and 10 percent (5 of 49 subjects) for the long-duration group. For children 2 years and older, the respective findings were 3 percent (5 of 154) and 5 percent (7 of 149). The differences were not statistically significant. Similar calculations were done for "not cured" at 10-14 days and for adverse effects. The numbers were small in those subjects younger than 2 years of age. Schaad (1993) showed that age stratification did not reveal any significant differences between age groups or between therapeutic groups. Here again, the numbers of patients younger than 2 years of age were small.

### Azithromycin (5 days) vs. Amoxicillin-Clavulanate (7-10 days)

#### Study populations

Three randomized controlled trials compared 5-day azithromycin therapy to 7-10 day amoxicillin-clavulanate therapy (Aronovitz, 1996; Khurana, 1996; McLinn, 1996). The Aronovitz (1996) study population was 2 years of age or older. The mean age of the patients in the Khurana (1996) study was 5.6 years and 53 percent were 5 years old or younger. The age range for the McLinn (1996) study population was 1-15 years. Fifteen percent of the Khurana (1996) population had more than two prior episodes of AOM. The other two studies did not address the otitis-prone status.

#### Outcomes

Some of the outcomes found in these three studies are listed in Evidence Table 5. Common outcomes included any type of adverse effects and gastrointestinal adverse effects.

#### Results

In terms of adverse effects, the meta-analysis calculated a pooled rate difference of −19.2 percent (95 percent CI, −29.2 percent and −9.2 percent). Five children with AOM would need to be treated with azithromycin rather than amoxicillin-clavulanate to avoid an adverse event. However, the outcomes reported in the studies in this comparison were heterogeneous statistically for the rate differences and for incidence rates within the amoxicillin-clavulanate group (Table 47 and Figure 20).

Table 47. Comparison 11: Meta-Analysis 11.1. Key question 4e: azithromycin (5d) vs. amoxicillin-clavulanate (7-10d) outcome indicator: any mention of adverse events

Study (First Author) | Year | Risk Factor 1 Age <2yr | Risk Factor 2 Otitis Prone (Prior episodes) | Azithromycin Sample Size | Amox-Clav Sample Size | Azithromycin Failure Rate (%) | Amox-Clav Failure Rate (%) | Rate Difference (%) | 95%CI of Rate Difference (%)
Aronovitz | 1996 | 0% <2 yr | Not addressed | 85 | 84 | 4 | 31 | −27 | (−38, −17)
Khurana | 1996 | 6 mo-12 yr | 15% >2 episodes | 263 | 260 | 7 | 17 | −10 | (−16, −5)
McLinn | 1996 | 1-15 yr | Not addressed | 340 | 334 | 9 | 31 | −22 | (−28, −16)
Random effects estimates | | | | 688 | 678 | 6.8 | 26.0 | −19.2 | (−29.2, −9.2)
Test of heterogeneity Chi-square test value | | | | | | 4.43 | 17.32 | 12.49
Test of heterogeneity Chi-square test p-value | | | | | | 0.109 | <0.001 | 0.002
NNT=−5 (−11, −3)

NNT=number needed to treat

CI=confidence interval

Amox-Clav=amoxicillin-clavulanate

Figure 20. Shrinkage plot for outcome=any mention of adverse events Comparison 11: Meta-analysis 11.1=Azithromycin (5 d) vs. amoxicillin-clavulanate (7-10 d)

The next comparison examined the gastrointestinal adverse effects, which also showed highly heterogeneous results for both the rate differences and within the amoxicillin-clavulanate group. The random effects estimate of the pooled rate difference was −18.0 percent (95 percent CI, −28.0 percent and −8.0 percent). In other words, six children would need to be treated with azithromycin rather than amoxicillin-clavulanate to avoid a gastrointestinal adverse event. (Although not reported in the studies, the clavulanate concentration was most likely 31.25 mg per 125 mg of amoxicillin.) Subgroup analysis by age and otitis-prone status was not possible. (Table 48 and Figure 21).

Table 48. Comparison 11: Meta-Analysis 11.2. Key question 4e: azithromycin (5d) vs. amoxicillin-clavulanate (7-10d) outcome indicator: GI-related adverse events

Study (First Author) | Year | Risk Factor 1 Age <2yr | Risk Factor 2 Otitis Prone (Prior episodes) | Azithromycin Sample Size | Amox-Clav Sample Size | Azithromycin Failure Rate (%) | Amox-Clav Failure Rate (%) | Rate Difference (%) | 95%CI of Rate Difference (%)
Aronovitz | 1996 | 0% <2 yr | Not addressed | 85 | 84 | 4 | 30 | −26 | (−37, −16)
Khurana | 1996 | 6 mo-12 yr | 15% >2 epi | 263 | 260 | 6 | 15 | −9 | (−14, −4)
McLinn | 1996 | 1-15 yr | Not addressed | 340 | 334 | 8 | 29 | −21 | (−26, −15)
Random effects estimates | | | | 688 | 678 | 6.1 | 18.7 | −18.0 | (−28.0, −8.0)
Test of heterogeneity Chi-square test value | | | | | | 3.19 | 19.83 | 13.48
Test of heterogeneity Chi-square test p-value | | | | | | 0.203 | <0.001 | 0.001
NNT=−6 (−13, −4)

NNT=number needed to treat

CI=confidence interval

Amox-Clav=amoxicillin-clavulanate

Figure 21 Shrinkage plot for outcome=gastrointestinal (GI) related adverse events Comparison 11: Meta-analysis 11.2=Azithromycin (5 d) vs. amoxicillin-clavulanate (7-10 d)

In addition, individual studies (Aronovitz, 1996; McLinn, 1996) showed no differences in 11-day and 30-day failure rates between azithromycin (5 days) and amoxicillin-clavulanate (10 days).

### Other Short-Duration vs. Long-Duration Comparisons

The treatment regimens we compared were the following: amoxicillin (<5 days) vs. amoxicillin (7-10 days), penicillin V (<5 days) vs. penicillin V (7-10 days), penicillin V (5 days) vs. penicillin V (7-10 days), benthazine penicillin G (1 dose) vs. tetracycline (7-10 days), benthazine penicillin G (1 dose) vs benthazine penicillin G (1 dose) plus triple-sulfonamide (7 days), amoxicillin-clavulanate (5 days) vs. amoxicillin-clavulanate (7-10 days), cefaclor (<5 days) vs. cefaclor (7-10 days), cefaclor (5 days) vs. amoxicillin (7-10 days), cefaclor (5 days) vs. cefaclor (7-10 days), cefuroxime-axetil (5 days) vs. amoxicillin-clavulanate (7-10 days), cefpodoxime-proxetil (5 days) vs. amoxicillin-clavulanate (7-10 days), cefpodoxime-proxetil (5 days) vs. cefaclor (7-10 days), cefpodoxime-proxetil (5 days) vs. cefixime (7-10 days), cefprozil (5 days) vs. cefprozil (7-10 days), ceftibuten (5 days) vs. ceftibuten (10 days), ceftriaxone (1 dose) vs. amoxicillin-clavulanate (7-10 days), ceftriaxone (1 dose) vs. cefaclor (7-10 days), ceftriaxone (1 dose) vs. cefuroxime-axetil (7-10 days), azithromycin (<5 days) vs. cefaclor (7-10 days), and azithromycin (<5 days) vs. clarithromycin (7-10 days) (Table 49).

Table 49. Key question 4e. Studies not in meta-analytic comparisons: synopsis

Author | Age | Otitis Prone | Result ^1^
Amoxicillin (<5 days) vs. Amoxicillin (7-10 days)
Chaput de Saintonge/1982 | >2 years (100%) | >1 episode in previous excluded from study | No difference in sign and symptom resolution days 3 and 15, failure at 15 days, recurrences, complications
Bain/1985 | >2 years (100%) | History of otitis media 75% | No difference in earache at 1 day, of 5 days, or 10 days; resolution of eardrum findings at 7 days or recurrence at 1 year
Puczynski/1987 | >2 years (100%) | Not addressed | Significantly greater failure in the single dose group 3 of 7 vs. 0 of 10
Penicillin V (<5 day) vs. Penicillin V (7-10 day)
Meistrup-Larsen/1983 | Mean 4.5 years | Not addresssed | No difference in unsatisfactory course at 14 days, but small numbers
Penicillin V (5 day) vs. Penicillin V (7-10 day)
Ingvarsson/1982 | <2 years (24%) | Not addressed | No difference in not healed, which includes serous otitis media or relapses or therapeutic failure at 28-30 days nor in the individual components; higher percentage not healed if <2 years
Benthazine Penicillin G (1 dose) vs. tetracycline (7-10 day) or Benthazine Penicillin (1 dose) plus Triple-sulfonamide (7 day)
Rubenstein/1965 | <2 years (48%) | Not addressed | Failure 4 of 79 (5%) vs. 10 of 78 (13%); no difference between bicillin and bicillin+triple-sulfonamide
Benthazine Pencillin G (1 dose) vs. Benthazine Pencillin (1 dose) plus Triple-sulfonamide (7 day)
Stickler/1967 | <2 years (45%) | Not addressed | No difference in 2 week clinical failure
Amoxicillin-clavulanate (5 day) vs. Amoxicillin-clavulanate (7-10 day, either twice-a-day or three-times-a-day)
Hoberman/1997 | <2 years (39%) | Not addressed | No difference in failure at 12-14 days or 32-38 days
Cohen/1998 | <2.5 years (100%) mean 1.1 years | >3 episodes (9%), 2 episodes (11%), 1 episode (23%) | Greater failure at 12-14 days in shorter duration group (23% vs. 12 %)
Cefaclor (<5 day) vs. cefaclor (7-10 day)
Jones/1986 | >2 years (100%) mean 5.7 years | History of otitis media (77%) | No difference in earache > 4 days or resolution of ear signs or recurrence within 6 weeks
Cefaclor (5 day) vs. Amoxicillin (7-10 day)
Ploussard/1984 | <2 years (84%) | Not addressed | No difference in unsatisfactory outcome or recurrence but numbers small; all unsatisfactory outcomes and recurrences occurred in <2 year old patients
Cefaclor (5 day) vs. Cefaclor (7-10 day)
Hendrickse/1988 | <2 years (53%) | Otitis prone (20% ^2^ ) | With intact TM no difference in failure at <5 days or 6-10 days; reinfection at 14-30 days, or 31-60 days, or 61-90 days; persistent middle ear effusion rate at 10-15 days 30 days, 60 days, 90 days; with perforated TM no difference in reinfection or middle ear effusion rate but 46% to 8% difference in 6-10 day failure rate
Cefuroxime-axetil (5 day) vs. Cefuroxime-axetil (10 day) vs. Amoxicillin-clavulanate (7-10 day)
Gooch/1996 | Mean 3.5 years | Prior episode (84%) Prior episode within 1 year (84%) | No difference in clinical failure after 3 days, recurrence 14-18 days after treatment end, or bacteriologic failure
Cefpodoxime-proxetil (5 day) vs. Amoxicillin-clavulanate (7-10 day)
Cohen/1997 (article 426 and 2325) | Mean 1.5 years <2 years (75%) | Not addressed Recurrent acute otitis media (25%) | Difference in nasopharyngeal pneumococcus persistence of (59% vs. 36%, p=0.01); no difference in nasopharyngeal H. influenzae persistence; both 2-6 days after treatment end No difference in failure 4 days after treatment end and at 17 days nor in serous otitis media at 1 month after treatment 24% vs. 18% with new acute otitis media at 1 month after treatment end
Cefpodoxime-proxetil (5 day) vs. Cefaclor (7-10 day)
Adams/1995 | Mean 3.5 years | Not addresed | No difference in failure at 11-13 days or relapse at 3 weeks
Cefpodoxime-proxetil (5 day) vs. Cefixime (7-10 day)
Boulesteix/1995 | Range 6 months-6 years | Otitis prone excluded | No difference in unsatisfactory course at 8-10 days and 30-40 days or relapse at 30-40 days
Cefprozil (5 day) vs. Cefprozil (7-10 day)
Kafetzis/1997 | Mean 4.1 years | >2 episodes (3%) 2 episodes (6%) 1 episode (24%) | No difference in failure at 28-32 days or relapse after end of treatment
Ceftibuten (5 day) vs. Ceftibuten (10 day)
Simon/1997 | Mean 3.7 years | Not addressed | More failure with the short-duration group (22% vs. 2%) and more recurrence at 14 days (14% versus 8%)
Ceftriaxone (1 dose) vs. Amoxicillin-clavulanate (7-10 day)
Bauchner/1996 | <1.5 years (34%) | >2 prior episodes (11%) 1 prior episode (25%) | Unimproved or worse in 50 of 267 (19%) vs. 28 of 271 (10%); parents dissatisfacton with antibiotic significant with 8% vs. 11%
Varsano/1997 | Mean 2.7 years | Otitis prone ^2^ (13%) | No difference failure at 11 days or relapses at 12-30 days; higher recurrence at 31-90 days in amoxicillin-clavulanate group; more diarrhea and vomiting with amoxicillin-clavulanate
Ceftriaxone (1 dose) vs. Cefaclor (7-10 day)
Chamberlain/1994 | >1.5 years (100%) mean 3 years | <4 AOM per year (100% by exclusion of others) mean 1.4 episodes/year | No difference in failure at 14 days, recurrence at <14 days or 90 days, or persistent effusion 90 days
Ceftriaxone (1 dose) vs. Cefuroxime-axetil (7-10 day)
Kara/1988 (also vs. amoxicillin) | Range 6 months-6 years | Not addressed | No difference in failure at day 5 but very small numbers
Ceftriaxone (1 dose) vs. Trimethoprim-sulfamethoxazole (7-10 day)
Barnett/1997 | Mean ceftriaxone 17.3 months and TMP-SMX 18 months | >3 prior episodes (41%) | Equivalent noncured rates at 14 days and 28 days but not at 3 days; otitis-prone status did not have an effect; those who failed appeared to be of younger mean age
Azithromycin (<5 day) vs. Cefaclor (7-10 day)
Rodriguez/1996 | Mean 4 years | Not addressed | No difference in failure at 10-14 days; less failure in azithromycin at 25-30 days
Azithromycin (<5 day) vs. Clarithromycin (7-10 day)
Arguedas/1997 | Mean 4.2 years | Not addressed | No difference in clinical failure by end of therapy
Azithromycin (5 day) vs. Amoxicillin-clavulanate (7-10 day)
Aronovitz/1996 | <2 years (0%) | Not addressed | No difference in failure rate at 11 days or 30 days. Relapse assessed at 15-35 days was higher in the amoxicillin-clavulanate group, (21 %), compared to the azithromycin group, (5 %).
Khurana/1996 | Range 6 months-12 years | >2 episodes (15%) | No difference in failure rate at 3 days or relapse before 14 days, recurrence after 14 days, or total unsatisfactory response.
McLinn/1996 | Range 1-15 years | Not addressed | No difference in failure rate at 11 days or 30 days.

1 comparative results report short-duration result then long-duration result

2 meets technical expert panel of otitis prone

#### Study populations

Fourteen of these studies reviewed indicated that the proportion of subjects were younger or older 2 years of age. Nine studies reported a mean age alone. Two studies only reported an age range. In nine studies, at least 20 percent of the subjects appeared to have been younger than 2 years of age (Bauchner, Adams, Barnett, et al., 1996; Cohen, de La Rocque, Boucherat, et al., 1997; Cohen, Levy, Boucherat, et al., 1998; Hendrickse, Kusmiesz, Shelton, et al., 1988; Hoberman, Paradise, Burch, et al., 1997; Ingvarsson and Lundgren, 1982; Ploussard, 1984; Rubenstein, McBean, Hedgecock, et al., 1965; Stickler, Rubenstein, McBean, et al., 1967). Thirteen studies indicated the proportion of subjects who had previous episodes of AOM, and three studies excluded patients with varying degrees of previous episodes (Bain, Murphy, and Ross, 1985; Boulesteix, Durbreuil, Moutot, et al., 1995; Chamberlain, Boenning, Waisman, et al., 1994). Twelve studies did not address the issue of otitis-prone status.

#### Outcomes

Many different outcomes were measured in these studies (Evidence Table 5).

#### Results

Nineteen of these 24 studies did not demonstrate any difference in effectiveness between the short-duration and long-duration therapy in the outcomes measured. Puczynski, Stankiewicz, and O'Keefe (1987) found, however, a significantly greater failure rate in the single-dose amoxicillin group compared with the 10-day amoxicillin group. Rubenstein, McBean, Hedgecock, et al. (1965) found a higher failure rate in those treated with long-duration tetracycline compared with a single dose of benthazine penicillin G. Cohen, Levy, Boucherat, et al. (1998) found a greater failure rate at 12-14 days in the 5-day duration of the amoxicillin-clavulanate group vs. the long-duration group. Henrickse, Kusmiesz, Shelton, et al. (1988) found a higher failure rate among those with a perforated tympanic membrane who were on short-duration cefaclor therapy at 6-10 days. Simon (1997) found a higher failure rate with short-duration ceftibuten therapy compared with long-duration ceftibuten therapy.

Only three studies looked specifically at the effect of age or otitis-prone status on any of the outcomes. Paradise (1997) reports in an editorial on age-stratified results from the Hoberman, Paradise, Burch, et al. (1997) study that, compared with 5-day treatment, 10-day treatment had significantly improved outcomes at days 12-14 and 32-38 for children younger than 2 years and at days 12-14 for children 2-5 years old. Paradise (1997) only reports on the twice-a-day amoxicillin-clavulanate regimen for 10 days and not the three-times-a-day amoxicillin-clavulanate regimen for 10 days. Ingvarsson and Lundgren (1982) stratified the "not healed" results by age. For treatment with the 5-day penicillin V, 25 percent of the children younger than 2 years were not healed and 20 percent of those 2 years and older were not healed. For treatment with the 10-day penicillin V, the respective findings were 33 percent for children younger than 2 years and 20 percent for those 2 years or older. In the Barnett, Teele, Klein, et al. (1997) study, those identified as otitis prone had a failure rate of 24 percent in the ceftriaxone group and a 23 percent failure rate in the trimethoprim-sulfamethoxazole group. The respective numbers for the patients who were not otitis prone were 26 percent and 19 percent. The data suggests that the otitis-prone status of the child did not have an effect on the outcome of failure at 14 days (Barnett, Teele, Klein, et al., 1997).