# Methodology

## Establishment of Conceptual Framework

The project team prepared a conceptual framework (Appendix B) for the management of AOM for the purpose of discussion and future development of the evidence report. It outlined 11 steps for the management of AOM: steps 1 through 6 related to initial evaluation and treatment and steps 7 through 11 related to followup care. Factors influencing outcomes, outcome measures, and decisions were noted as footnotes to the framework. The framework formed the basis on which key questions and the scope of the evidence report were developed. It was understood that not all steps could be addressed in this evidence report.

## Nomination of Technical Experts

A total of 11 organizations were identified by the project team from whom nominations of technical experts and peer reviewers were solicited. The 11 organizations included: 3 topic-nominating partner -- the American Academy of Family Physicians, the American Academy of Pediatrics, and the American Academy of Otolaryngology-Head and Neck Surgery Foundation; 2 hearing and speech organizations -- the American Academy of Audiology (AAA) and the American Speech-Language-Hearing Association (ASHA); 1 multidisciplinary organization -- the Society for Ear Nose Throat Advances in Children (SENTAC); 2 managed care organizations -- PacifiCare Health Systems and Prudential HealthCare; 1 nurse practitioner organization -- the National Association of Pediatric Nurse Associates and Practitioners (NAPNAP); and 2 consumer groups -- Family Voices and Foundation for Accountability (FACCT). A letter of invitation to nominate technical experts and peer reviewers was faxed to each organization, together with a description of the tasks and commitments of each panel member.

Upon receiving nominations from the agencies, 11 technical experts were identified to serve on the panel consisting of two family physicians, two otolaryngologists, two pediatricians (one specializing in ambulatory care and the other in pediatric infectious disease), one audiologist, one speech pathologist, one managed-care representative, one nurse practitioner, and one consumer. Table 1 lists the membership of the Technical Expert Panel.

Table 1. Technical expert panel

Technical Expert | Area of Expertise | Affiliation/Location
Theodore G. Ganiats, M.D. | Family medicine | University of California San Diego, CA
Martin C. Mahoney, M.D., Ph.D. | Family medicine | State University of New York Buffalo, NY
Margaretha Casselbrant, M.D., Ph.D. | Otolaryngology | Children's Hospital Pittsburgh, PA
Richard M. Rosenfeld, M.D., M.P.H. | Otolaryngology | SUNY Health Science Center Brooklyn, NY
Leonard B. Weiner, M.D. | Pediatrics, infectious diseases | SUNY Health Science Center Syracuse, NY
F. Lane France, M.D. | Pediatrics practice & ambulatory medicine | Tampa Bay Pediatrics Tampa, FL
Judith S. Gravel, Ph.D. | Audiology | Albert Einstein College of Medicine Bronx, NY
Joanne Roberts, Ph.D. | Speech-language and audiology | Frank Porter Graham Child Development Center Chapel Hill, NC
Tony Arboleda, M.D. | Health plan | MedPartners Medical Group Burbank, CA
Janice Goertz, R.N.,CPNP | Nurse practitioner | Portage, MI
Jennifer Postley, B.A. | Consumer | Family Voice Los Angeles, CA

## Topic Assessment and Refinement

A draft workplan for the topic assessment and refinement phase was mailed to the technical experts and partners for review and comments. Two conference calls among all technical experts, partner liaisons, project staff, and the Task Order Officer were held to review data on existing literature, refine the causal pathway, specify patient populations and practice settings, and refine the key questions to be addressed in the evidence report. The conference calls were chaired by the Principal Investigator and were attended by all principal project staff, the technical experts, and the AHRQ Task Order Officer. Reference materials -- including a review of the existing literature, causal pathways, conceptual framework, and a list of potential questions -- were mailed to all participants prior to the calls.

The project staff compiled a summary of information on:

- The incidence and prevalence of AOM, treatment and management alternatives, characteristics and size of the affected populations, and the most affected practice settings and providers.
- The burden of illness associated with AOM, including morbidity, mortality, impact on developmental milestones, quality of life, loss of productivity, medical costs to treat the condition, and other economic costs or burdens associated with the condition.
- The extent to which there is variation in practice associated with the prevention, diagnosis, treatment, or management of AOM.

Further, we reviewed and compiled a summary of six meta-analyses on otitis media that already had been conducted. Both summaries were distributed to the technical experts between the first and second conference call. The project staff also examined in detail the OME Guideline Panel's report Managing Otitis Media with Effusion in Young Children. Quick Reference Guide for Clicians (Stool, Berg, Berman, et al., 1994b) for parallel issues in AOM.

## Identification of Key Questions

About 2 weeks before the first conference call, the following documents were distributed to the technical experts: (1) the preliminary conceptual framework for management of AOM,(2) the two-page letter nominating AOM as a topic for evidence analysis that was submitted to AHRQ by the three nominating agencies, (3) a list of the key questions included in the Request for Task Order by AHRQ, and (4) the draft workplan for topic assessment and refinement. Each technical expert was asked to submit a list of key questions within a week using the conceptual framework as a guide and to provide comments and any suggestions for revision of the conceptual framework and the draft workplan for topic assessment and refinement. The letter to the technical experts emphasized that not all steps in the framework would be addressed in the evidence report and that only three to five key questions would be selected.

The project staff compiled a master list of proposed key questions that incorporated the key questions submitted by the technical experts. The master list was forwarded to all technical experts and conference call participants and was used as the basis for discussion during the first conference call.

During the first conference call, many suggestions for revisions, additions, and deletions were made. The taped conference call was reviewed by the Task Order Manager during revision of the key questions. The project staff incorporated the suggestions and compiled a new set of seven key questions for ranking by the technical experts (Table 2).

Table 2. Initial seven key questions for ranking by technical experts

Question 1: On the Natural History of AOM. What clinical characteristics (history, symptoms, physical findings) of children are associated with rapid improvement and with prolonged duration of morbidity during an episode of (uncomplicated) acute otitis media (AOM) that is initially managed WITHOUT antibiotics in terms of:; 1. Resolution of pain and/or fever at 24 hours, 2-3 days, and 4-7 days?; 2. Complete clinical resolution, excluding middle ear effusion (MEE), at 7-14 days?; 3. Prevalence of asymptomatic MEE at 2 weeks, 1 month, and 3 months?; 4. Incidence of acute suppurative complications (e.g., mastoiditis)?

Question 2: On Definition and Physician Diagnosis of AOM. How accurate is physician/health care provider diagnosis of acute otitis media?; 1. What is the definition of AOM or the criteria by which AOM is diagnosed?; 1. Is middle ear effusion a diagnostic standard for the diagnosis of AOM?; 2. Is inflammation of the tympanic membrane a diagnostic standard for the diagnosis of AOM?; 3. Is the presence of acute local or systemic symptoms a diagnostic standard for the diagnosis of AOM?; 2. What is the gold standard for establishing the diagnosis of AOM?; 3. Is it possible to improve the diagnostic accuracy of physicians and other health care providers in identifying AOM? Reduce false-positive diagnoses?; 4. What is the value or utility of parental involvement in diagnosis, for example, with home diagnostics such as acoustic reflectometry or otoscopy, compared with diagnosis without such parental involvement?

Question 3: On Antibiotic Treatment of AOM. Are antibiotics (compared to placebo) effective (in terms of statistical significance and magnitude of absolute clinical benefit above and beyond natural history) in treatment of AOM with respect to the following outcome indicators:; 1. Resolution of pain and/or fever at 24 hours, 2-3 days, and 4-7 days?; 2. Complete clinical resolution, excluding middle ear effusion (MEE), at 7-14 days?; 3. Prevalence of asymptomatic MEE at 2 weeks, 1 month, and 3 months?; 4. Incidence of acute suppurative complications (e.g., mastoiditis)?; To what degree is selective initial use of antibiotics for (uncomplicated) AOM attributable to:; 1. Clinical characteristics, including hearing and/or speech delay?; 2. Age of the child?; 3. Provider degree of diagnostic uncertainty for true AOM?; 4. Parent reliability (low vs. high) to report symptom resolution or progression at 48-72 hours if antibiotics are initially withheld?; 5. Parent preference concerning antibiotic therapy?; 6. Parent education?

Question 4: On Antibiotic Regimen for AOM. Does the specific antibiotic regimen make a difference?; 1. (Antibiotic class) Are antibiotics with broader coverage than amoxicillin or trimethoprim sulfa more cost-effective or cost-beneficial in the initial treatment of AOM?; 2. (Antibiotic class) Should antibiotic selection be determined on the basis of local or regional bacterial resistance pattern?; 3. (Antibiotic class) What is the utility of fluoroquinolones in treatment of AOM in childhood? What are the side effects?; 4. (Dose of antibiotic) What is the value of using 60-80 mg/kg/d of amoxicillin or amoxicillin-clavulanate vs. the standard 40 mg/kg/d? (Schedule of antibiotic) Is twice-a-day high-dose amoxicillin therapy as effective as three times a day amoxicillin therapy in the initial treatment of AOM?; 5. (Schedule of antibiotic) Is twice-a-day high-dose amoxicillin therapy as effective as three times a day amoxicillin therapy in the initial treatment of AOM?; 6. (Length of treatment) What is the comparative efficacy of short- vs. long-term antibiotic therapy in children younger than 2 years of age and those older than 2 years of age?; 7. Is the use of a single injection of ceftriaxone or the use of other cephalosporin for treatment of AOM more or less likely than 7-10 days of oral amoxicillin to predispose to creation of a penicillin/cephalosporin-resistant pneumococcal nasopharyngeal flora? Does the risk-benefit justify the use of a single injection of ceftriaxone?; 8. How long after an antibiotic is used is it reasonable for it to be used again to treat AOM in terms of reducing the likelihood of developing resistance to antibiotics?

Question 5: On Non-Antibiotic Pharmaceutical Treatment of AOM. What is the effectiveness (or cost-effectiveness) of non-antibiotic treatments of AOM?; 1. Do any of the new nonsteroidal anti-inflammatory drugs hasten the resolution of AOM or decrease the incidence or duration of subsequent otitis media with effusion?; 2. Do oral and/or topical analgesics reduce the duration of pain in AOM?; 3. Do anti-inflammatory nasal sprays, such as cromolyn or beclomethasone, for relief of allergic rhinitis reduce the incidence of AOM?

Question 6: On Followup Strategies. What are the appropriate (and/or cost-effective) clinical followup strategies (including type, schedule, and frequency of strategies) for children with AOM?; 1. Is the effectiveness of followup dependent on age group?; 2. Is the effectiveness of followup dependent on clinical severity (single episode of AOM, recurrent AOM, persistent AOM)?; 3. Is the effectiveness of followup dependent on clinical characteristics (e. g., do children with speech-language delay or developmental delay have better outcomes with more intense followup)?; 4. Is the effectiveness of followup dependent on parent characteristics (including compliance)?; What are the indications for change in therapy at followup if followup is effective in improving outcomes in children with AOM?; 1. Does tympanocentesis in children with AOM who are still symptomatic after 48 or 96 hours of treatment lead to a change in therapy that improves outcomes?; 2. Does audiometry during followup lead to a change in therapy that improves outcomes?

Question 7: On Prevention of AOM. What is the role of each of the following preventive strategies in managing sporadic or recurrent AOM?; 1. Do vaccines reduce the occurrence of AOM?; 2. Do risk-factor modification measures (interruption of secondhand smoke exposure, hygienic measures) reduce the occurrence of AOM?; 3. Do prophylactic antibiotics reduce the occurrence of AOM?; 4. Do surgical procedures such as tympanostomy tube insertion and adenoidectomy reduce the occurrence of AOM?; 5. Do anti-inflammatory nasal sprays, such as cromolyn or beclomethasone, for relief of allergic rhinitis reduce the incidence of AOM?

AOM=acute otitis media; MEE=middle ear effusion.

The new set of seven key questions -- together with a form to record rankings, the summary of information on the incidence, alternatives for treatment, and impact/costs of AOM; the summary of published meta-analyses; and preliminary counts of citations by key questions -- was sent to the technical experts about 1 week before the second conference call. The technical experts were advised to use the background materials as references to rank five of the seven key questions, using "5" as the most important and "1" as the least important. The main criteria to be used in ranking were importance and feasibility. Importance was to be determined by the potential impact on the outcomes associated with the management of AOM. The importance of a question might be diminished if a recent evidence analysis of high quality already existed. Feasibility was determined by the availability of published studies and the time required to complete the evidence analysis for that question. Technical experts were asked to submit the ranking to the Task Order Coordinator before the second conference call.

A summary of the rankings by the technical experts is presented in Table 3. The top-ranked question was Question 3 on antibiotic treatment with 34 rank points, followed closely by Question 1 on natural history with 33 points, and by Question 4 on antibiotic regimen with 27 points. The next two questions were Question 6 on followup strategy and Question 2 on definition and diagnosis with 24 and 23 points, respectively. The last two questions were Question 7 on prevention and Question 5 on non-antibiotic treatment with 18 and 6 points, respectively. An analysis of the rankings showed significantly diverse opinions of the experts on the importance of the key questions (Kendall coefficient of concordance is 0.21, p=0.03). A review of the ranking pattern of the experts revealed that the experts strongly agreed on the importance of Questions 3 (antibiotic treatment) and 1 (natural history) and on the least importance of Question 5 (non-antibiotic treatment), but their opinions varied with respect to the other questions. The scoring of Question 2 on definition and diagnosis was particularly polarized with four technical experts ranking it 4 or 5 and four technical experts not ranking it at all.

Table 3. Rankings of initial key questions by technical experts

Technical Expert | Key Question for Ranking
Technical Expert | Q1 Natural History | Q2 Definition and Diagnosis | Q3 Antibiotic vs. No Antibiotic | Q4 Antibiotic Regimen | Q5 Non-Antibiotic Treatment | Q6 Followup Strategy | Q7 Prevention
T1 | 5 | 4 | 3 | 0 | 0 | 1 | 2
T2 | 4 | 3 | 2 | 5 | 1 | 0 | 0
T3 | 1 | 0 | 5 | 4 | 0 | 3 | 2
T4 | 5 | 0 | 1 | 2 | 0 | 3 | 4
T5 | 5 | 0 | 1 | 2 | 0 | 3 | 4
T6 | 5 | 4 | 2 | 3 | 0 | 1 | 0
T7 | 3 | 0 | 4 | 1 | 0 | 5 | 2
T8 | 2 | 1 | 5 | 4 | 0 | 3 | 0
T9 | 0 | 5 | 4 | 0 | 1 | 2 | 3
T10 | 3 | 1 | 5 | 2 | 4 | 0 | 0
T11 | 0 | 5 | 2 | 4 | 0 | 3 | 1
Total Rank | 33 | 23 | 34 | 27 | 6 | 24 | 18

Note: The technical expert numbers were assigned randomly and do not correspond to the listing order.

During the second conference call, the ranking of the key questions was discussed. The project team proposed to work on the first three ranked questions for this evidence report as they were related to a single theme. Some discussions took place regarding the importance of the other questions, especially those on prevention and diagnosis. Due to the time limit of the study, the group decided to focus only on the set of three questions dealing with antibiotic treatment: Key Questions 1, 3, and 4 (Table 4).

Table 4. Final version of the three key questions

Question 1: On the Observational or No Treatment or Natural History of AOM.; 1. During an episode of uncomplicated acute otitis media (AOM) that is initially managed WITHOUT any active intervention (pharmacologic or surgical) other than topical or systemic medications (that do not contain antibiotics) given for symptomatic relief (e.g., analgesics, antipyretics, antihistamines, decongestants, ear or nose drops), what proportion of children have the outcomes delineated in the Scope of the Evidence Report?; 2. To what degree are the above outcomes attributable to the influencing factors delineated in the Scope of the Evidence Report?
Question 3: On Antibiotic Treatment of AOM.; 1. Are antibiotics effective (in terms of statistical significance and magnitude of absolute clinical benefit above and beyond placebo/observational/no treatment/natural history) in the initial ^1^ treatment of uncomplicated AOM with respect to the outcomes delineated in the Scope of the Evidence Report?; 2. When antibiotics are used in the initial ^1^ treatment of uncomplicated AOM, which of the influencing factors delineated in the Scope of the Evidence Report are associated with better outcomes compared with placebo/observational/no treatment/natural history?
Question 4: On Antibiotic Regimen for AOM. Does the specific antibiotic regimen make a difference?; 1. (Antibiotic class) Is treatment with antibiotics other than amoxicillin or trimethoprim sulfa more effective or result in lower total cost in the initial ^1^ treatment of uncomplicated AOM?; 2. (Antibiotic class) What is the utility of oral fluoroquinolones in the initial ^1^ treatment of uncomplicated AOM in childhood? What are the side effects?; 3. (Dose of antibiotic) What is the value of using > 60 mg/kg/d of amoxicillin or amoxicillin-clavulanate vs. the standard 40 mg/kg/d in the initial ^1^ treatment of uncomplicated AOM?; 4. (Schedule of antibiotic) Is twice a day high-dose amoxicillin therapy as effective as three times a day amoxicillin therapy in the initial ^1^ treatment of uncomplicated AOM?; 5. (Length of treatment) What is the comparative effectiveness of short- vs. long-term antibiotic therapy in children younger than two years of age and those older than two years of age in the initial ^1^ treatment of uncomplicated AOM?

1 An episode of uncomplicated AOM may be considered distinct from a previous episode of AOM and eligible for "initial" treatment if the most recent course of antibiotic ended 4 weeks prior to the episode of AOM in question or if there is documentation by an examiner that a prior episode of AOM has been cleared.

Several issues were brought up during the discussion and were addressed during the revision of the key questions and the drafting of the causal pathways:

- One issue related to the difference between "natural history of acute otitis media when nothing is done, including not seeking care from the health care provider" and "observational treatment prescribed by the health care provider." It was decided that the issue brought up an important point, and Question 1 was retitled to reflect this fact.
- Another issue concerned the real objective of Question 3b. The technical experts discussed whether it was more important to address the amount of influence of the listed factors on the "selective initial use of antibiotics" or to address the "effectiveness of the initial use of antibiotics." The former is an analysis of the prescribing pattern (which is a process variable), and the latter is an analysis of the effectiveness of initial use of antibiotics (which is an outcome variable). Question 3b was thus reworded to address the impact of these factors on outcome.
- On the issue of defining uncomplicated AOM, there were several suggestions, including "inflammation of the middle ear cleft" to "one sign and one symptom" to "definitions used by the different studies." The project team decided that a definition and diagnostic criteria had to be established before the study could continue because it would affect the search strategy. The experts were polled to establish the best definition to use for this evidence report. Several of the technical experts felt that we might have to accept whatever definition of AOM was found in any given study because they would be quite disparate; however, the project staff felt it important to establish a standard definition for comparison.
- Subquestions in Question 4 that addressed complicated AOM rather than uncomplicated AOM were discussed: (4b) Would antibiotic selection based on local or regional bacterial resistance pattern improve the outcome of antibiotic treatment of AOM? and (4h) How long after an antibiotic is used is it reasonable for it to be used again to treat AOM in terms of reducing the likelihood of developing resistance to antibiotics? They were not included because this evidence report was limited to uncomplicated otitis media.
- The definition of endpoints for the study was discussed. The group decided to leave them open to definitions used by different studies. However, it was decided that it would be important to define the most appropriate endpoints before the literature search and then compare the definitions with those found and/or used in the literature.
- The next discussion topic was on the age of the child to be included in the evidence report. It was decided to exclude the neonate. Epidemiologically, a neonate is a newborn up to 28 days old. For this evidence report, studies on children between age 28 days and 18 years were included.
- The following factors that might affect outcomes were added: gender, ethnicity, presence of ear infection in sibling, craniofacial problems, and cost. In addition, based on information from review of literature, project staff added race, sibling(s) in day care, pacifier use, presence of sibling(s), and atopy or allergy. In this report, the term "influencing factors" included both risk factors and effect modifiers that might actually or potentially affect the outcomes.

## Identification of Causal Pathways, Study Populations, Practice Settings, and Target Audience

In preparation of the second conference call with the technical experts and partners, a draft of the contents necessary to develop causal pathways for the key questions was distributed. Based on the discussion with the technical experts and the common theme of the three key questions, the project staff proposed a definition for AOM, developed a causal pathway for the key questions (Table 5), and specified the scope of each domain to be addressed in the evidence report. A preliminary search of MEDLINE also was conducted and summarized (Table 6) according to the initial seven proposed key questions. The information was provided to the technical experts to assist them with their ranking of the key questions.

Table 5. Causal pathways for key questions

[image]

Table 6. Preliminary literature search on seven initial key questions

Key Question | Search Topic | MEDLINE (1966- 1998)
Natural History | AOM and natural history or untreated | 7
Natural History | AOM and outcome & process assessment | 95
Natural History | AOM and persistent | 110
Natural History | AOM and recurrent | 284
Natural History | AOM and complications | 322
Definition & Diagnosis | AOM and blood, microbiology, csf, classification, cytology, parasitology, diagnosis, radiography, radionuclide imaging, urine, virology | 525
Definition & Diagnosis | AOM and sensitivity/specificity/false-negative/false-positive/predictive/likelihood/randomized controlled trial/blinded methods | 468
Definition & Diagnosis | AOM and diagnosis/diagnostic techniques and procedures/laboratory techniques | 498
Definition & Diagnosis | AOM and sensitivity/specificity/predictive value/likelihood | 63
Definition & Diagnosis | AOM and medical history taking | 5
Definition & Diagnosis | AOM and physical exam | 39
Definition & Diagnosis | AOM and tympanogram | 29
Definition & Diagnosis | AOM and tympanocentesis | 93
Definition & Diagnosis | AOM and acoustic reflectometry | 9
Definition & Diagnosis | AOM and diagnostic techniques otological | 124
Definition & Diagnosis | AOM and otoscopes/otolaryngology (MeSH 1998+) | 5
Definition & Diagnosis | AOM and decisionmaking/judgment/problem solving/decision support techniques/physician's practice patterns/referral and consultation/evidence-based medicine | 45
Antibiotic Therapy | AOM and antibiotics | 790
Non-Antibiotic Therapy | AOM and steroids | 22
Non-Antibiotic Therapy | AOM and analgesics | 29
Non-Antibiotic Therapy | AOM and antihistamines/decongestants | 44
Non-Antibiotic Therapy | AOM and tympanostomy/middle ear ventilation/tympanostomy/tube insertion | 111
Followup Strategy | AOM and combination of therapies and followup studies | 77
Prevention | AOM and antibiotic prophylaxis/preventive medicine/immunoprophylaxis | 136
Review Articles
General | AOM and review articles and human and English | 172
Cost ^1^ | AOM and cost ^1^ | 52
Meta-analysis | AOM and meta-analysis | 27
Meta-analysis | AOM and information synthesis (meta-analysis, decision analysis, cost effectiveness analysis, cost-benefit analysis) | 29
Incidence/Prevalence | AOM and incidence/prevalence | 251 (1966- 1998)
Incidence/Prevalence | AOM and incidence/prevalence | 148 (1987- 1998)
Randomized Control Trials (RCTs)
RCT | AOM and RCT as publication type | 198 (1966- 1998)
RCT | AOM and RCT as publication type | 129 (1987- 1998)
RCT | AOM and RCT (very broad strategy) | 617 (1966- 1998)
RCT | AOM and RCT (very broad strategy) | 441 (1987- 1998)

1 From HealthSTAR, 59 citations from 1966- 1998.

The three key questions, definition of AOM, and the scope of the evidence report have gone through several revisions as a result of conference discussions and polling. The initial and revised versions of these three documents are included in Appendices C, D, and E, respectively.

During the second conference call, the technical experts provided input regarding the patient populations, practice settings, and target audience for the evidence report. The study population included all children between 28 days and 18 years with uncomplicated AOM. The interventions of interest included placebo or observation with no treatment or antibiotic treatment. Influencing factors included demographic, environmental, clinical, pharmaceutical, and cost factors. All health care settings and types of providers were included. The endpoints of the study included four short-term and four long-term indicators. Short-term indicators at 48 hours included disappearance of signs (discharge, inflammation of the tympanic membrane), symptomatic relief of pain and/or fever, resolution of acute suppurative complications, and complete clinical resolution (except middle ear effusion). Long-term indicators at 3 months included absence of asymptomatic middle ear effusion, resolution of suppurative complications (e.g., mastoiditis), absence of speech and/or hearing problems, and absence of recurrence of AOM.

## Refinement of Key Questions, Definition of AOM, and Scope

Each technical expert was mailed a revised proposed definition, revised key questions with rationale, scope of project, and causal pathways and was asked to submit any comments within 2 weeks. The technical experts were polled specifically on four issues related to the definition of AOM that were still unsettled.Table 7 provides a summary of their responses to the four questions, including their specific comments. Based on the comments received, the key questions, definition, and scope were revised further. The next set of their revisions and the reasons for changes are provided in Appendices C.2, D.2, and E.2. These three revised documents were mailed again to the panel of experts for review and further comments, together with a questionnaire (Table 8) polling them on four more issues that were still unresolved. Their responses are summarized in Table 9.

More Comments on Definition of Acute Otitis Media

Comment 1: I continue to be troubled by the AOM definition as it seems to confuse the terms "symptom" & "sign."
  To clarify: | Symptom - change in normal function
  | Sign - physical finding, evidence
Specifically, the current AOM definition (12/23) seems to mix signs & symptoms in items #2 & 3. Symptoms would include ear pulling, irritability, otalgia (subjectively) & hearing loss (subjectively), while signs include otalgia, otorrhea, fever, and hearing loss (objectively). Also, the basic elements which define inflammation (e.g., redness, pain, fever, swelling) are not consistently addressed in the present definition.
Comment 2: Revised proposed AOM definition. I still have some problems with the wording. As noted in a prior e-mail, I recommend the following definition:
"Acute otitis media is defined as: 1) signs of middle-ear effusion (new onset or pre-existing) accompanied by 2) rapid and short onset (within 48 hours) of clinical findings including one or more of the following: otalgia (ear pulling in an infant), otorrhea, fever, irritability, anorexia, vomiting, or diarrhea."
In contrast to your proposed definition, the one above puts emphasis on middle-ear effusion (by placing it first) and eliminates ambiguity about middle-ear effusion duration (your definition implies recent onset, yet AOM can develop on a pre-existing effusion of long duration).

Table 7. Technical expert's responses to four issues related to definition of acute otitis media January 7, 1999

| Expert Number
| 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11
1. Definition of Rapid Onset:
(a) Within 48 hours | x | x | . | x | x | x | x | . | x | x | x
(b) Within 7 days | . | . | . | . | . | . | . | x | . | . | .
(c) Other (72 hours) | . | . | x | . | . | . | . | . | . | . | .
2. GI symptoms to be included?
(a) Yes | . | . | x | x ^2^ | . | . | . | . | . | . | .
(b) No | x ^1^ | x | . | . | x | x | x | x | x | x | x
3. Hearing loss included?
(a) Yes | x | . | x | . | . | x | . | x | x ^5^ | x ^5^ | x
(b) No | . | x | . | x ^3^ | x | . | x ^4^ | . | x ^5^ | x ^5^ | .
4. The two signs for MEE
(a) Agree | x ^6^ | x | x ^7^ | . | x | x | . | x | x ^10^ | x ^10^ | x
(b) Disagree | . | . | . | x ^8^ | . | . | x ^9^ | . | . | . | .

Notes:

x Answer checked by expert.

1 GI findings can occur, but to have rapid onset of GI findings and an abnormally colored ear doesn't make it for me.

2 GI symptoms should be included on the list because they may be the only manifestation of acute illness in an infant or young child. Anorexia (secondary to nausea) and vomiting may be direct vestibular manifestations of middle ear infection or fluid. Diarrhea is not as easy to justify, and if the panel feels strongly about removing diarrhea from the symptom list I have no objection. Be aware, however, that "traditional" AOM definitions have always included diarrhea as a qualifying symptom.

3 Hearing loss is a manifestation of middle ear effusion, not acute infection. Further, not all middle ear fluid is accompanied by hearing loss, and not all hearing loss caused by middle ear fluid is readily perceptible to parents or clinicians. Traditional AOM definitions have never included hearing loss as a qualifying symptom.

4 Anyone with AOM will have hearing loss at diagnosis.

5 We are concerned about including hearing loss as a clinical finding. First, it is highly unlikely that a formal audiologic evaluation would be administered when a child presents to the physician with acute OME. Clinical symptoms (fever, irritability, otorrhea, otologia) could prevent a reliable hearing test (audiogram and tympanogram) from being obtained. During the course of the episode when the acute clinical symptoms had subsided, an audiologic evaluation would be more appropriate. Second, without a direct measure of hearing (that is, obtaining an audiogram) there is no way to determine if hearing loss exists. Parent report has been demonstrated to be a highly inaccurate means of detecting hearing loss (Rosenfeld et al.). Further, we are not uncertain if studies examining hearing loss and OM have specifically examined hearing loss during AOM. However, if hearing loss stays in as a clinical finding, please delete "older children." Hearing loss, when present, occurs in both young children as well as older children, and can be reliably assessed in infants and young children. Therefore, hearing loss would be a clinical finding regardless of the age of the child.

6 Need to clarify one or both signs.

7 Change 3(b) to full or bulging with red or white opacification.

8 Middle ear fluid with AOM generally manifests as a full or bulging tympanic membrane, which is opaque and has limited or absent mobility to pneumatic otoscopy. Changes in tympanic membrane color are NOT indicative of effusion. Changes in lucency are also NOT indicative, unless accompanied by reduced mobility.

9 Suggest that OME and inflammation with changes go under part two.

10 We agree with the addition with of the two clinical signs, but suggest that position of the TM (e.g., bulging, retracted) be included as a third clinical sign (Karma Penttila, Sipila, et al., 1989).

Table 8. Questionnaire to poll technical experts on four unresolved issues related to definition of AOM, key questions and scope

1. In the definition of AOM, should we add "excluding retracted tympanic membrane" to statement (1)? That is, would you prefer to state AOM is defined as (1) presence of middle ear effusion as indicated by limited or absent mobility of the tympanic membrane, excluding retracted tympanic membrane, with or without....?"
  Yes___ | No___ | No preference___
Comments:
2 In the definition of AOM, the majority of you defined rapid onset as "within 48 hours." Now we need to define the beginning and end points of the 48-hour period. Please write down the beginning and end points to define rapid onset. (e.g., Rapid onset is defined as less than or equal to 48 hours from the time the acute signs or symptoms -- otalgia, otorrhea, irritability, or fever -- were first noticed by the parent to the time the parent first contacted the physician's office, whether by phone or in person.); 3 In the key questions, we need to define "initial treatment" or "initially managed." We are proposing the following options: [circle (a), (b), and/or (c)]
  a) | An episode of uncomplicated AOM may be considered distinct from a previous episode of acute otitis media and eligible for "initial treatment" if the most recent course of antibiotic ended 2 weeks prior to the episode of AOM in question.
  b) | An episode of uncomplicated AOM may be considered distinct from a previous episode of AOM and eligible for "initial treatment" if the most recent course of antibiotic ended 4 weeks prior to the episode of AOM in question.
  c) | An episode of uncomplicated AOM may be considered distinct from a previous episode of AOM and eligible for "initial treatment" if there is documentation by an examiner that a prior AOM has been cleared.
Comments:
4 One of the influencing factors in the scope is "otitis prone," which is used to replace "prior history of recurrent AOM" and "multiple previous episodes." How would you define "otitis prone"? [circle one]
  a) | > three episodes in 6 months or > four episodes in 12 months
  b) | Other (please specify and write rationale)

Table 9. Technical expert's responses to four unresolved issues^1^ related to definition, key questions, and scope

Expert | Issue 1 | Issue 2 | Issue 3 | Issue 4
1 | Yes | <=48 hours from point signs/symptoms noted by parent and health system contacted ^4^ | b | a
2 | Yes | <=48 hours from point of initial signs/symptoms | c | four episodes in 12 months
3 | Yes | <=48 hours from point signs/symptoms noted by parent and health system contacted | a and c | a ^7^
4 | No | <=48 hours from point signs/symptoms noted by parent and health system contacted | b ^6^ and c | a ^8^
5 | No preference ^2^ | <=48 hours from onset of acute signs or symptoms until diagnosis confirmed by practitioner | b and c | a
6 | Yes | <=48 hours from point signs/symptoms noted by parent and health system contacted | b and c | a
7 | No ^3^ | <=48 hours from point signs/symptoms noted by parent and health system contacted5 | b | a
8 | No | <=48 hours from point signs/symptoms noted by parent and health system contacted | a | a
9 | No preference | <=48 hours from point signs/symptoms noted by parent and health system contacted | c | a
10 | Yes | <=48 hours from point signs/symptoms noted by parent and health system contacted | c | a

1 Issues: Issue 1: In the definition of AOM, should we add "excluding retracted tympanic membrane" to statement (1)? Issue 2: In the definition of AOM, the majority of you defined rapid onset as "within 48 hours..." Please write down the beginning and end points to define rapid onset. Issue 3: In the key questions, we need to define "initial treatment" or "initially managed." We are proposing the following options [circle (a), (b), and/or (c)]: (a) An episode of uncomplicated AOM may be considered distinct from a previous episode of AOM and eligible for "initial treatment" if the most recent course of antibiotic ended 2 weeks prior to the episode of AOM in question. (b) An episode of uncomplicated AOM may be considered distinct from a previous episode of AOM and eligible for "initial treatment" if the most recent course of antibiotic ended 4 weeks prior to the episode of AOM in question. (c) An episode of uncomplicated AOM may be considered distinct from a previous episode of AOM and eligible for "initial treatment" if there is documentation by an examiner that a prior AOM has been cleared. Issue 4: One of the influencing factors in the scope is "otitis prone," which is used to replace "prior history of recurrent AOM" and "multiple previous episodes." How would you define "otitis prone?" [circle one]: (a) three episodes in 6 months or four episodes in 12 months; (b) other (please specify and write rationale).

2 "I remain troubled by the definition. For example, a child with stable OME who develops febrile rotavirus diarrhea meets the definition (whether they have any of the 1) a, b, or c findings). I'm not sure how that can work."

3 "Unless there is evidence to support its use in diagnosis, remove acoustic "reflectometry" from Definition as well as in Scope of the Evidence Report: Monitoring during episode. (See section on acoustic reflectometry in Clin. Pract. Guideline 12 on OME, Stool, et al., 1994, p. 34-35.)

4 "I always thought 'within 48 hours' referred to the speed of onset, not the duration. If we go with duration, I think your example is fine. If we go with speed, I have a hard time coming up with the right words."

5 "I Agree with above, but change 'physician' to 'examiner' (to include family physician, otolaryngologist, pediatrician, nurse practitioner, PA, etc.)."

6 "AOM within 4 weeks of a prior episode would classify as recurrence."

7 "Patient should also be asymptomatic."

8 "In the context of an 'influencing factor' you may wish to expand this definition to include episodes of OME, not just AOM." "Episodes should also be 'well documented and separate.'"

OME=otitis media effusion.

Based on the responses to the unresolved issues, the three documents were revised further. The next set of revisions of the key questions, definition, and scope (Appendices C.3, D.3, and E.3) were distributed to the panel of experts for review and for discussion at the third conference call and resulted in more changes. The final revisions of the three documents are included in Appendices C.4, D.4, and E.4.

The short version of the final definition of AOM is as follows: Acute otitis media is the presence of middle ear effusion in conjunction with the rapid onset of one or more signs or symptoms of inflammation of the middle ear.

The long version of the final definition is as follows:

- Presence of middle ear effusion as demonstrated by the actual presence of fluid in the middle ear as diagnosed by tympanocentesis or the physical presence of liquid in the external ear canal as a result of tympanic membrane perforation or indicated by limited or absent mobility of the tympanic membrane as diagnosed by pneumatic otoscopy, tympanogram, or acoustic reflectometry with or without the following: (a) opacification, not including erythema, (b) a full or bulging tympanic membrane, or (c) hearing loss, and rapid onset (i.e., up to 48 hours from the onset of acute signs or symptoms first noted by the parent or guardian to the time of contact with the health system) of one or more of the following signs or symptoms, with or without anorexia, nausea, or vomiting: (a) otalgia (or pulling of ear in an infant), (b) otorrhea, (c) irritability in the infant or toddler, or (d) fever.

## Literature Search

We conducted the literature search on seven databases: MEDLINE, the Cochrane Library, HealthSTAR, International Pharmaceutical Abstracts (IPA), Cumulative Index to Nursing and Allied Health Literature (CINAHL), BIOSIS, and EMBASE. We also searched for relevant articles in symposiums and reference lists of published articles, reports, and guidelines.

The MEDLINE database is produced by the U.S. National Library of Medicine and is widely recognized as the premier source for bibliographic coverage of biomedical literature. It encompasses information from Index Medicus, Index to Dental Literature, and International Nursing, as well as other sources of coverage in the areas of allied health, biological and physical sciences, humanities and information science as they relate to medicine and health care, communication disorders, population biology, and reproductive biology. The MEDLINE database includes citations and abstracts since 1966.

The Cochrane Library contains several databases: (1) The Cochrane Database of Systematic Reviews containing Cochrane reviews published by the Cochrane Collaboration, an international organization dedicated to applying evidence-based medicine principles to the review of important clinical topics; (2) The Cochrane Controlled Trials Register, which is a bibliographic database of controlled trials; (3) The Database of Abstracts of Reviews of Effectiveness (DARE), which includes structured abstracts of systematic reviews that have been critically appraised by reviewers at the NHS Centre for Reviews and Dissemination in York and by other reviewers (e.g., the American College of Physicians' Journal Club and the journal Evidence-Based Medicine); and (4) The Cochrane Review Methodology Database, which is a bibliography of articles on the science of research synthesis.

The HealthSTAR database contains citations and abstracts (when available) of journal articles, monographs, technical reports, meeting abstracts and papers, book chapters, government documents, and newspaper articles on health services, technology, administration, and research. It focuses on both the clinical and nonclinical aspects of health care delivery. Topics covered include evaluation of patient outcomes; effectiveness of procedures, programs, products, services and processes; and health services research. It is produced cooperatively by the U.S. National Library of Medicine and the American Hospital Association. HealthSTAR replaces the former Health Planning and Administration database. The database includes citations and abstracts since 1975.

The IPA is produced by the American Society of Health System Pharmacists. It provides worldwide coverage of pharmaceutical science and health-related literature. Coverage includes drug therapy, toxicity, and pharmacy practice, as well as legislation, regulation, technology, utilization, biopharmaceutics, information processing, education, economics, and ethics as related to pharmaceutical science and practice. The database currently contains over 300,000 records and includes citations since 1970.

The CINAHL database is produced by CINAHL Information Systems. It provides comprehensive coverage of the English-language journal Literature for Nursing and Allied Health Disciplines. Material from more than 950 journals is included in CINAHL. Also included are health care books, nursing dissertations, selected conference proceedings, standards of professional practice, and educational software. There is selective coverage of journals in biomedicine, the behavioral sciences, management, and education. The database currently contains over 250,000 records. In total, more than 500 journals are regularly indexed; online abstracts are available for more than 150 of these titles. The database includes citations since 1982.

BIOSIS Previews, produced by BIOSIS, is the world's most comprehensive reference database in the life sciences. It covers original research reports and reviews in biological and biomedical areas. Nearly 7,000 serials are monitored for inclusion. In addition, the database covers content summaries, books (including software from 1992 to present), and information from meetings. Content summaries include notes and letters, technical data reports, reviews, U.S. patents from 1986 to 1989, translation journals, meeting reports from 1980 to present, bibliographies, nomenclature rules, and taxonomic keys. The BIOSIS Previews database includes the contents of Biological Abstracts (1969 to present), Biological Abstracts/RRM (1980 to present), and BioResearch Index (1969 to 1979). The BIOSIS database includes citations since 1970.

EMBASE, the Excerpta Medica database produced by Elsevier Science, is a major biomedical and pharmaceutical database indexing more than 3,800 international journals. EMBASE is one of the most widely used biomedical and pharmaceutical databases. The database currently contains more than 6 million records, with more than 400,000 citations and abstracts added yearly. The EMBASE database contains citations since 1980.

The project librarian developed an overall search strategy incorporating the input from the technical experts and following the scope of the project. The initial search strategy was developed for MEDLINE and then customized for the other databases. The MEDLINE search strategy used both controlled vocabulary terms and keywords. The strategy was organized into modules or clusters of search statements. The initial module (called om with sh dt or otitis media with subheading drug therapy) included using what is referred to as an "explode" of om, which includes the controlled vocabulary headings om, mastoiditis, om w/effusion, om, suppurative with the subheading drug therapy. The next module (called om) included the explode of om as well as om as a text word. The anti-infectives module used explode of the mesh heading for anti-infective agents, which includes antibiotics and other drug groups as well as the text words antibiotic, antimicrobial, and antibacterial. The antibiotics module included the names of specific antibiotics previously identified, which were entered as text words. The search involved a combination of the om module with the anti-infectives module and another combination of the om module with the antibiotics module. We also used either the om with dt set or the om with anti-infectives set or the om with antibiotics as a keyword set in the search. From this set editorials, letters, reviews, practice guidelines, consensus development conferences, and case reports were excluded, except when the case report was also a randomized controlled trial or clinical trial. This set was then limited to human or undesignated. In other words, animal studies were excluded. The final set was limited to infant, child, preschool, adolescence, or undesignated. Newborn, adult, middle age, and aged were excluded.

For the search for natural history, natural history, natural course, and untreated were added as keywords. During the third telephone conference with the technical experts, an expert advised adding "spontaneous" and "self-limited" as keywords to the search. Adding these terms, however, uncovered no additional articles.

The first MEDLINE search resulted in 2,284 titles/abstracts. Two subsequent MEDLINE alerts (additions of new articles after the last update) added another 27 titles/abstracts. Additional titles/abstracts included 217 from the Cochrane Library search, 11 from the HealthSTAR search, 88 from the CINAHL search, 248 from the IPA search, 745 from the BIOSIS search, and 2,418 from the EMBASE search. Further screening of and removal of duplicates from BIOSIS and EMBASE resulted in retaining 154 titles/abstracts from BIOSIS and 421 from EMBASE. The search strategy included the following criteria: publication years after 1966, all languages, keywords, human or non-human study, and search hierarchy. The ending date of all searches was March 31, 1999. All databases were searched using the Ovid search system through the World Wide Web with the exception of the Cochrane Library. The files searched included the Cochrane Database of Systematic Reviews, DARE, and The Cochrane Controlled Trials Register.

EndNote software (EndNote Windows Version 3.0, 1st Edition. Niles Software Inc., Berkeley, CA) was used to keep a complete record of all titles/abstracts and to identify duplications. It was able to store, organize, and track references by source (e.g., identified in MEDLINE), search strategy (date of search, index code specifying search criteria used), and a unique identification (UI) code for each article (assigned by source used to find article). Electronic removal of duplicate citations was supplemented by manual cross-checking. In the event an article was identified through an expert panel member or reference checking, the title and author of the reference were entered into MEDLINE through the Ovid search system (Ovid Technologies, Inc. 1998, Version: 7.8 Millennium source ID 1.3932.1.156.1.7, Revision: 1.303.2.8) to determine the UI. If a UI could not be found for the article, an alternate identification code was assigned.

EndNote assigned a record number to each new reference added to the master file. This number would not change once an article was added to the list and was used, in addition to the UI, to sort references for article retrieval and review.

Upon completion of the literature search and duplicate checking, the master list generated from EndNote was exported to a Microsoft Excel spreadsheet for data export for analysis. Codes including status of article retrieval, reviewer, and the results of the review were added.

## Review of Retrieved Abstracts Against Screening Criteria

After retrieval of titles and abstracts from the literature search, two physician reviewers reviewed the abstracts against the inclusion/exclusion criteria to determine eligibility for inclusion in the evidence synthesis as defined in the scope and key questions. Titles/abstracts were not masked prior to review. A predesigned screening form (Appendix F) was used to record the reviews. Instructions for screening also were provided (Appendix F). The screening results for each title/abstract were matched between the two reviewers by the Task Order Coordinator. Discrepancies on inclusion or exclusion were resolved in conference among the two reviewers and the coordinator. The data were entered into a Microsoft Excel database from which interrater reliability statistics of agreement and agreement adjusted for chance (kappa statistic) were calculated. Summary reports indicated those abstracts that passed the screening criteria and those that failed, along with the reasons for failure.

The results of the screening of titles/abstracts before and after resolution of discrepancies regarding inclusion/exclusion for the seven databases are presented in Table 10. A total of 3,461 titles/abstracts were screened; 2,500 (72 percent) were excluded; 510 (15 percent) were identified for further review; and 451 (13 percent) required resolution. After resolution, 2,701 (78 percent) were excluded and 760 (22 percent) required pulling articles for further review.

Table 10. Preliminary screening results of titles and abstracts from seven databases

Source | Total Title/Abstract | Before Resolution | | | After Resolution
Source | Total Title/Abstract | Reject | Accept | Unsure | Reject | Accept
MEDLINE | 2,322 | 1,800 (78%) | 259 (11%) | 263 (11%) | 1,931 (83%) | 391 (17%)
Cochrane Library | 217 | 161 (74%) | 46 (21%) | 10 (5%) | 163 (75%) | 54 (25%)
HealthSTAR | 11 | 5 (46%) | 1 (9%) | 5 (46%) | 9 (82%) | 2 (18%)
CINAHL | 88 | 79 (90%) | 1 (1%) | 8 (9%) | 83 (94%) | 5 (6%)
IPA | 248 | 210 (85%) | 27 (11%) | 11 (4%) | 239 (96%) | 9 (4%)
BIOSIS | 154 | 41 (27%) | 75 (49%) | 38 (25%) | 53 (34%) | 101 (66%)
EMBASE | 421 | 204 (48%) | 101 (24%) | 116 (28%) | 223 (53%) | 198 (47%)
All Sources ^1^ | 3,461 | 2,500 (72%) | 510 (15%) | 451 (13%) | 2,701 (78%) | 760 (22%)

1Citations from each source are not independent.

CINAHL=Cumulative Index to Nursing and Allied Health Literature; IPA=International Pharmaceutical Abstracts.

## Retrieval and Review of Full Articles

The titles/abstracts identified as requiring further review were forwarded to the library for full article retrieval. Libraries at both the Los Angeles County - University of Southern California Medical Center and at the University of Southern California Health Sciences Campus were the primary sources of the articles. Those not found were retrieved through the Inter-Library Loan Program.

Because a large number of titles/abstracts had inadequate information for full evaluation, a second screening with the full articles was conducted. Like the first screening, two physician reviewers independently reviewed each article and filled out a screening form. Articles were not masked prior to review. Discrepancies on inclusion/exclusion were resolved through conference calls.

Table 11 presents the results of secondary screening of the 760 articles that were pulled for review. The 760 articles consisted of 487 in English and 273 in non-English languages. Of the 487 English articles, 415 (85 percent) were further excluded with 72 articles (15 percent) included for quality review and data abstraction. Of the 415 exclusions, 56 (13 percent) were rejected because they were not research studies (R1), 2 (0.5 percent) were nonhuman studies (R2), 41 (10 percent) did not address the problem of AOM (R3), 1 was not in the study age range (R4), 25 (6 percent) did not use the appropriate study design (R6), 228 (55 percent) did not address any of the key questions (R7), 28 (7 percent) were duplicate studies, and 34 (8 percent) required contact with the investigators for further data breakdown or for abstracts (R9).

Table 11. Results of secondary screening of 760 articles

| English | Non-English
Total Number of Articles Number of Articles obtained, not reviewed Number reviewed Number rejected Number accepted | 487 0 487 415/487 (85%) 72/487 (15%) | 273 176 97 95/97 (98%) 2/97 (2%)
For Rejected Articles: Reason of Rejection R1=Not a study R2=Nonhuman subjects R3=Not on acute otitis media R4=Not in age range of study R5=Study population not in scope R6=Study design not appropriate R7=Not addressing any key questions ^1^ R8=Duplicate of other studies R9=Data not abstractable, require contacting author | 415 56 (13%) 2 (0%) 41 (10%) 1 (0%) 0 (0%) 25 (6%) 228 (55%) 28 (7%) 34 (8%) | 95 19 (21%) 2 (2%) 16 (17%) 11 (12%) 0 (0%) 1 (0%) 37 (39%) 9 (9%) 0 (0%)
For Accepted Articles: Key Questions Addressed (n=74) Key Question 1: Natural History of AOM ^2^ Key Question 3. Use of Antibiotics ^3^ Key Question 4a: Amoxicillin or TMP-SMZ ^4^ vs. others Key Question 4b: Oral fluoroquinolones vs others Key Question 4c: High-dose vs. standard-dose amoxicillin Key Question 4d: Bid vs. tid high-dose amoxicillin Key Question 4e: Short- vs. long-term antibiotic therapy | 72 10 8 34 0 1 1 35 | 2 0 0 0 0 0 0 2

1 163 of the 228 addressed potential key questions.

2 Four articles were added to Key Question 1 after review of references of other articles.

3 One article was added to Key Question 3 after review of references of other articles.

4 TMP-SMZ: trimethoprim-sulfamethoxazole

Of the 72 English articles eligible from the electronic search, 10 addressed the natural history question (Key Question 1), 8 addressed the use of antibiotic question (Key Question 3), 34 addressed the comparison of amoxicillin or ampicillin with other antibiotics (Key Question 4a), none addressed the comparison of oral fluoroquinolones with other antibiotics, 1 addressed the comparison of high dose vs. standard dose of amoxicillin, 1 compared twice a day vs. three times a day of amoxicillin, and 35 compared short-term versus long-term antibiotic therapy.

The distribution of the 273 non-English articles by language is presented in Table 12. It should be noted that of the 273 non-English articles, 120 were from the first batch of articles retrieved from MEDLINE, Cochrane, IPA, CINAHL, and HealthSTAR. The other 153 articles were from the second batch retrieved from BIOSIS and EMBASE. The first batch of non-English articles were reviewed to determine the yield of eligible articles. Non-English articles were reviewed by a project member with the assistance of a translator. The results of the review of 97 non-English articles are presented in Table 13. Twenty-three non-English articles were not reviewed from the first batch because 3 were not retrievable, 14 lacked a language designation, and 6 lacked translators.

Table 12. Distribution of 273 non-English articles by language

Language | First Batch ^1^ N=2,875 | Second Batch ^2^ N=585 | Total
Japanese | 22 | 79 | 101
French | 17 | 12 | 29
German | 14 | 10 | 24
Russian | 13 | 3 | 16
Italian | 6 | 16 | 22
Spanish | 4 | 17 | 21
Danish | 7 | 3 | 10
Portuguese | 1 | 9 | 10
Polish | 8 | 0 | 8
Dutch | 4 | 2 | 6
Swedish | 3 | 0 | 3
Norwegian | 2 | 0 | 2
Romanian | 2 | 0 | 2
Czech | 0 | 1 | 1
Finnish | 1 | 0 | 1
Hebrew | 1 | 0 | 1
Turkish | 0 | 1 | 1
Ukrainian | 1 | 0 | 1
Unknown | 14 | 0 | 14
Total | 120 | 153 | 273

1 First batch included MEDLINE, Cochrane, IPA, CINAHL, and HealthSTAR.

2 Second batch included BIOSIS and EMBASE.

Table 13. Results of reviewing 97 non-English articles

Language | Number Articles Reviewed | Reject | Accept | R1 | R2 | R3 | R4 | R5 | R6 | R7 | R8 | R9
Japanese | 20 | 20 | 0 | 4 | 1 | 2 | 7 | | | 6
French | 17 | 15 | 2 | 2 | 1 | | 1 | | | 10 | 1
German | 13 | 13 | 0 | 5 | | 4 | | | | 4
Italian | 5 | 5 | 0 | 1 | | 1 | 1 | | | 2
Spanish | 4 | 4 | 0 | 1 | | 1 | | | | 2
Russian | 13 | 13 | 0 | 2 | | 5 | 2 | | | 4
Danish | 7 | 7 | 0 | 1 | | 1 | | | | | 5
Polish | 8 | 8 | 0 | 1 | | 1 | | | | 6
Dutch | 3 | 3 | 0 | 1 | | | | | | | 2
Swedish | 3 | 3 | 0 | 1 | | | | | | 1 | 1
Norwegian | 2 | 2 | 0 | 1 | | | | | | 1
Romanian | 1 | 1 | 0 | | | 1
Hebrew | 1 | 1 | 0 | | | | | | | 1
Total | 97 | 95 | 2 | 20 | 2 | 16 | 11 | | | 37 | 9

Reason for Rejection:

R1=Case report/editorial/letter/clinical practice/overview/practice guidelines/consensus statements

R2=Nonhuman subjects

R3=Study condition NOT acute otitis media

R4=Not within age range of study

R5=Study population is on immunodeficiencies or craniofacial deficiencies

R6=Study design not appropriate

R7=Not addressing any key questions

R8=Duplicate of other studies in the database

R9=Data not abstractable from article, required contacting author

The screening and review of the 97 non-English articles resulted in the use of 2 articles for one of the key questions, a yield rate of two percent. The results were presented to the Technical Expert Panel during the last conference call and it was decided unanimously that the yield was too low to warrant further screening and review of the second batch of non-English articles.

## Finalization of Articles for Inclusion

The last activity in searching for articles was the identification and review of potential articles from references of studies and/or articles. The tables of contents from the second to sixth Proceedings of the International Symposium on Recent Advances in Otitis Media were screened by the literature reviewer, and a total of seven articles were retrieved for review of potential inclusion. This process yielded the inclusion of one additional article (Ostfeld, Segal, Kaufstein, et al., 1988) for Key Question 1. The screening of references of other articles, also by the literature reviewer, resulted in the retrieval and review of another 23 articles, 5 of which addressed the key questions. Among the five, articles by Townsend (1964), Thalin, Densert, Larsson, et al. (1986), and Bollag and Bollag-Albrecht (1991) were added to the articles for Key Question 1. The Thalin, Densert, Larsson, et al. (1986) article also was added to the articles for Key Question 3. The Howie and Owen (1987) study was added to the list of articles for Key Question 4a, and the article by Stickler, Rubenstein, McBean, et al. (1967) was added to the list for Key Question 4e.

Further review of articles found that the article by Cohen, de La Rocque, Boucherat, et al. (1997) in French reported results of the same study as the article by Cohen, Bingen, Varon, et al. (1997) in English except that different outcomes were reported. Based on the peer reviewers' comments on the draft evidence report, the study by van Buchem, Peeters, and van't Hof (1985) was added to the list of studies addressing the natural history question. Three Dutch and three Danish articles were reviewed with the assistance of translators; no additional articles were found for inclusion. Three of the six articles were duplicates of the English-language articles that already had been reviewed. Two of these were review articles and one was not retrievable.

Combining all the sources, including the electronic databases, searches of reference lists, and peer reviewers' comments, a total of 80 studies in 85 articles were included in answering the key questions. Of the 80 studies, 74 were randomized controlled trials and 6 were observational cohort studies; 15 addressed Key Question 1, 8 addressed Key Question 3, 35 addressed Key Question 4a, none addressed Key Question 4b, 1 each addressed Key Questions 4c and 4d, and 36 addressed Key Question 4e.

The remaining 680 articles that were not included in addressing the key questions in this evidence report are listed in the bibliography.

## Review and Assessment of Study Quality

The criteria for the assessment of study quality were established prior to the review of articles. The criteria developed by Jadad, Moore, Carroll, et al. (1996) were used to evaluate the quality of randomized controlled trials. The Jadad score had a range of 0 to 5. For a given study, 1 point was awarded if it was randomized, 1 point if it was double-blind, and 1 point if it described withdrawals and dropouts. An extra point was awarded if the method of randomization and/or double-blinding was appropriate; conversely, one point was subtracted if the method was inappropriate. The criteria used to evaluate the quality of cohort studies and case-control studies were based on the work by the McMaster University Group (Sackett, 1981; Trout, 1981; Tugwell, 1981). The quality of cohort studies was evaluated against eight components, which included presence or absence of a clear definition of the study cohort, an early inception point, a clear pathway of patient entry, complete followup, description of dropouts, objective outcome criteria, "blind" outcome assessment, and adjustment for extraneous factors. An Article Quality Review Form (Appendix G.1) was developed. The quality of definition of AOM was evaluated using the three components of the proposed definition established by the Technical Expert Panel: middle-ear effusion, rapid onset, and signs/symptoms of inflammation. The form collected data on the study design, the key questions and subquestions being addressed, quality of definition of AOM, and quality of study. Instructions also were prepared for reviewing the quality of articles and completing the quality review form (Appendix G.2).

Quality reviews were carried out in the same manner as the screening of articles for inclusion/exclusion. Articles were not masked prior to review. Two physician reviewers independently evaluated the quality of the articles and filled out the quality review forms. The Task Order Coordinator matched the reviews of the two reviewers and resolved minor discrepancies. Conferences were held to resolve discrepancies whenever needed. During these meetings, participants determined the disposition of each article in terms of eligibility for inclusion into analysis and finalized resolutions for all items.

## Data Abstraction

Of the articles eligible for inclusion in the Evidence Report, data abstraction was carried out by two physician reviewers. Data abstracted included parameters necessary to define study groups, inclusion/exclusion criteria, influencing factors, and outcome measures to be used in analysis. A sequential resolution strategy was used to match and resolve the screening and review results of the two reviewers. Telephone conferences were held among the two reviewers and the Task Order Coordinator, who was a health services researcher, to resolve discrepancies and refine instructions. The data abstraction form used is included in Appendix H.

## Procedures to Reduce Bias, Enhance Consistency, and Check Accuracy

The following procedures were used to minimize biases:

- Two physician reviewers screened and reviewed titles/abstracts and full articles in every stage of the selection process to reduce selection bias. Their percentage of agreement on inclusion/exclusion was 90 percent.
- Completeness of the retrieved articles was assessed by cross-checking with studies used in other meta-analyses and references listed in review articles. EndNote was used to check batches of articles added to the master list for duplication. The software checked for duplicate references by comparing author, year, title, and reference type. Following the importation of the first literature search, subsequent references were examined for duplication using this EndNote feature prior to their addition to the master list. After the master list was completed, a second check was performed to ensure there were no duplicate entries. This was done manually by scanning the master list after sorting by author and title.
- Multiple sources and unpublished material identified by the expert panel and internal content experts were searched. Funnel plots -- scatter plots of sample size vs. the estimated effect size from each study -- were studied to assess the extent of publication bias. When publication bias existed, a "bite" would be taken out of the funnel plot, typically at the null effect level.
- To reduce bias in the assessment of study quality, explicit preset criteria by Jadad, Moore, Carroll, et al. (1996) were used for study quality. Inter-rater reliability was used to assess the extent of bias in assessing study quality. Because of time and resource constraints, original authors were not contacted for additional information regarding study quality and reporting.

The mechanisms used to enhance consistency include the use of predesigned forms with explicit instructions and continuous and prompt resolution of discrepancies. After data collection, each of the variables collected on the data abstraction forms was entered into a Microsoft Excel spreadsheet. Cross-checking of variables for individual studies abstracted by each data collector identified discrepancies, which were then resolved by rechecking the article or consensus. The accuracy of study reviews was checked by using two data extractors who independently collected data from each article, cross-checked data entry by random sampling, and resolved any inconsistencies.

Figure 1 displays the trend of consistent improvement in the decrease in the percent of the 23 screened batches of titles/abstracts requiring resolution over time. Twenty-two batches contained 100 abstracts; the last batch contained 84.

Figure 1. Percent of titles/abstracts requiring resolution over time

## Review of Results of Literature Review

Project staff provided the Technical Expert Panel with a summary report from the literature review that included the number of abstracts reviewed, articles retrieved, eligible studies identified, and reasons for exclusion. Their comments on the search strategy and analysis, which were discussed in the third conference call, aided in planning supplemental analyses.

## Ranking of Influencing Factors

In preparation for the supplemental analysis, another poll was taken among the technical experts to prioritize the 41 influencing factors identified in the analytical framework. The Technical Expert Panel was asked to rank the top 10 influencing factors using the scale of 1 to 10, 10 being the most important influencing factor that should be used to further stratify supplemental analysis. Based on the total score of the 11 experts, the two most important risk factors were the age of the child (defined as younger or older than 2 years) and otitis-proneness or otitis-prone state (defined as having had three or more documented episodes of AOM in a6-month period or four or more documented episodes of AOM in a 12-month period). The results of the polling are presented in Table 14.

Table 14. Ranking of 41 influencing factors for analysis by technical experts

Factor ID# | Influencing Factor | Total Rank
1 | Age of child | 79.0
23 | Otitis prone | 73.0
5 | Attendance at day care center | 54.5
9 | Tobacco smoke exposure | 48.0
25 | Prior antibiotic use and when used | 36.0
30 | Presence of tube | 35.5
7 | Feeding mode -- bottle vs. breast | 25.0
22 | Middle ear effusion | 24.0
21 | Purulent otorrhea | 21.0
12 | Otalgia and severity | 19.5
41 | Cost of treatment | 15.0
36 | Setting (public, private, PPO, HMO, etc.) | 15.0
24 | Underlying viral infection | 14.0
11 | Season of the year | 14.0
29 | Atopy or allergy | 13.0
19 | Tympanic membrane inflammation | 12.0
10 | Ear infections in parents or siblings | 12.0
18 | Hearing loss | 11.0
20 | Retracted TM | 10.0
14 | Pulling of ear in an infant | 9.0
16 | Irritability | 9.0
32 | Parent/caretaker preference | 9.0
17 | Fever | 8.5
3 | Ethnicity/race | 8.0
26 | Concurrent use of non-antibiotics | 6.0
15 | Otorrhea | 5.0
2 | Gender | 4.0
4 | Presence of sibling(s) | 4.0
8 | Pacifier use | 3.0
6 | Sibling(s) in day care center | 2.0
40 | Type of method to monitor episode | 1.0
35 | Skill to diagnose | 1.0
38 | Frequency of monitoring of episode | 1.0
39 | Primary person monitoring episode | 0.0
37 | When monitoring is done during episode | 0.0
13 | Hearing deficit and severity | 0.0
33 | Parent/caretaker education | 0.0
27 | Prior hearing deficit | 0.0
34 | Type of examiner | 0.0
28 | Inability to express symptoms | 0.0
31 | Parent/caretaker availability | 0.0

HMO=health maintenance organization; PPO=preferred provider organization; TM=tympanic membrane.

## Preparation of Evidence Tables

An evidence table was prepared for each key question. Each evidence table provides a comprehensive tabular display of data abstracted from the literature, including the name of the first author, year of publication, language of study (if other than English), study design and its quality score, number of components addressed in the definition of AOM (according to the three preestablished criteria by the technical experts), when and where the study took place, inclusion and exclusion criteria, interventions compared, important influencing factors, sample sizes, outcome measures and their definitions, and study results. A total of five evidence tables were prepared and are included in the Evidence Tables section.

## Supplemental Analysis

To address Key Question 1 on natural history, project staff analyzed data from the placebo or observational arm of randomized clinical trials, as well as data from nontrials (including prospective and retrospective single or comparative cohort studies). Incidence rates of each outcome indicator at each time point were estimated by pooling data from studies addressing the same patient population. For Key Question 3 on antibiotic use, only randomized controlled trials were used in meta-analysis.

The articles eligible for analysis for each key question were grouped by comparisons. Each comparison consisted of articles that were considered homogeneous from the standpoint of clinical practice. The first grouping was based on the type of antibiotics being compared in each study. The number of comparisons and the number of articles for each comparison are presented in Table 15 for Key Question 3, Table 16 presents the same for Key Question 4a, and Table 17 for Key Question 4e. The grouping of antibiotics was done first by internal experts and then discussed with the Technical Expert Panel during the fourth conference call. Meta-analyses or quantitative syntheses were performed for comparisons involving three or more articles.

Table 15. Comparisons for key question 3, antibiotics vs. no antibiotics

Question 3:The general principle agreed upon was to separate amoxicillin-clavulanate, penicillin G, penicillin V, erythromycin estolate, triple sulfonamide, and erythromycin estolate-triple sulfonamide from ampicillin/amoxicillin and each other. Penicillin G is oxidized in the stomach and is not well absorbed. Penicillin V does not cover Haemophilus Influenzaewell. Erythromycin estolate is quite different from the other antibiotics. Triple sulfonamide is no longer in common usage.
Comparison
Number of articles
ampicillin or amoxicillin vs. placebo amoxicillin-clavulanate vs. placebo penicillin G plus sulfisoxazole vs. placebo penicillin V vs. placebo erythromycin estolate vs. placebo triple sulfonamide vs. placebo erythromycin estolate-triple sulfonamide vs. placebo
6 1 1 2 1 1 1

The next major factor for consideration in the meta-analyses for each comparison was the outcome variables. A meta-analysis was performed on outcome measures that were considered clinically homogeneous, such as failure rate of antibiotics at 2-7 days. The assumption was that the 2-day failure rate reported in one study was clinically the same as the 7-day failure rate reported in another study.

Further subdivision of the articles within each comparison into subgroups for meta-analysis according to major influencing factors was considered but was not feasible due to the small number of articles. A sensitivity analysis was planned to evaluate the influence of age, otitis proneness, language, time, place, study-design quality, and appropriateness of definition of AOM. This was also not feasible due to the small number of articles in each comparison group.

Table 16. Comparisons for key question 4a: amoxicillin or trimethoprim-sulfamethoxazole vs. other anitibiotics

Question 4: The general principle agreed upon was to compare by individual antibiotic rather than by antibiotic class, spectrum, or pharmacokinetics.
- penicillin; - amoxicillin-clavulanate; - cephalexin; - cephradine; - cefuroxime axetil; - cefaclor; - loracarbef; - cefixime; - ceftriaxone; - erythromycin estolate; - clarithromycin; - clindamycin; - penicillin V and sulfisoxazole; - triple sulfonamide; - penicillin G plus triple sulfonamide; - erythromycin ethylsuccinate-sulfisoxazole; - erythromycin ethylsuccinate-acetyl sulfafurazole; - oxytetracycline and procaine penicillin plus benzathine penicillin G injection plus sulfisoxazole | 3 0 2 1 2 5 1 5 3 2 2 1 2 1 1 1 1 1
Trimethoprim-sulfamethoxazole vs. | Number of Articles
- amoxicillin-clavulanate; - cephalexin; - cephradine; - cefuroxime axetil; - cefaclor; - loracarbef; - cefixime; - ceftriaxone; - erythromycin estolate; - erythromycin ethylsuccinate; - clarithromycin; - clindamycin; - penicillin-sulfisoxazole; - triple sulfonamide; - erythromycin ethylsuccinate-sulfisoxazole; - erythromycin ethylsuccinate-acetyl sulfafurazole | 1 0 0 0 3 0 1 0 0 0 0 0 0 0 0 0

Table 17. Comparisons for key question 4e: short-term vs. long-term antibiotic therapy

Question 4e:The general principle agreed upon was to compare by individual antibiotic stratified by therapy duration < 5 days vs. 5 days.
- amoxicillin (<5d) vs. amoxicillin (7-10d); - penicillin V (<5d) vs. penicillin V (7-10d); - penicillin V (5d, either 25mg/kg/d or 50 mg/kg/d) vs. penicillin V (7-10d); - benthazine penicillin G/procaine penicillin G/potassium penicillin G (Bicillin) (1 dose) vs. tetracycline (7-10d); - benthazine penicillin G/procaine penicillin G/potassium penicillin G (Bicillin) (1 dose) vs. benthazine penicillin/procaine penicillin G/potassium penicillin G (Bicillin) (1 dose) plus triple sulonamide (7d); - amoxicillin-clavulanate (5d, either 45 mg/kg/d or 80 mg/kg/d) vs. amoxicillin-clavulanate (7-10d, either 40 mg/kg/d or 45 mg/kg/d or 80 mg/kg/d); - cefaclor (<5d) vs. cefaclor (7010d); - cefaclor (5d) vs. amoxicillin (7-10d); - cefaclor (5d) vs. cefaclor (7-10d); - cefuroxime axetil (5d) vs. amoxicillin-clavulanate (7-10d); - cefuroxime axetil (5d) vs. cefixime (7-10d); - cefpodoxime proxetil (5d) vs. amoxicillin-clavulanate (7-10d); - cefpodoxime proxetil (5d) vs. cefaclor (7-10d); - cefpodoxime proxetil (5d) vs. cefixime (7-10d); - cefprozil (5d) vs. cefprozil (7-10d); - ceftibuten (5d) vs. ceftibuten (10d); - ceftriaxone (1 dose) vs. amoxicillin (7-10d); - ceftriaxone (1 dose) vs. amoxicillin-clavulanate (7-10d); - ceftriaxone (1 dose) vs. cefaclor (7-10d); - ceftriaxone (1 dose) vs. cefuroxime axetil (7-10d); - ceftriaxone (1 dose) vs. trimethoprim-sulfamethoxazole (7-10d); - azithromycin (<5d) vs. amoxicillin-clavulanate (7-10d, either 40 mg/kg/d or 45 mg/kg/d); - azithromycin (<5d) vs. cefaclor (7-10d); - azithromycin (<5d) vs. clarithromycin (7-10d); - azithromycin (5d) vs. amoxicillin-clavulanate (7-10d) | 3 1 1 with two 5-day arms 1 2 2 1 1 1 1 1 2 1 1 1 1 3 2 1 1 1 5 2 1 3

The DerSimonian and Laird random effects model (DerSimonian and Laird, 1986) was used to pool effect sizes across studies. This method produces a summary measure that is a weighted mean. It weights each study's measure by the inverse of the sum of the within-study variance and the between-study variance. This approach allows both sampling variation and between-study heterogeneity to affect the pooled estimate. Among the three effect measures -- rate difference, relative risk, and odds ratio -- the Technical Expert Panel and the project staff chose as most suitable the rate difference and its 95 percent confidence limits, which are presented both numerically and graphically. It should be noted that the absolute rate difference was used rather than the relative rate difference to measure the effect size throughout the report.

In addition to the pooled estimate, we report the Q statistic and p-value for the Chi-squared test of heterogeneity, which tests the null hypothesis that the individual study results are homogeneous (Laird and Mosteller, 1990). Because the test is known to lack power to detect heterogeneity, we protected against spurious conclusions resulting from combining clinically heterogeneous patients or treatments in two ways, regardless of the outcome of the Chi-squared test of heterogeneity. First was the use of random effects estimates that incorporate some between-study variance even if the Chi-squared test does not reject. Second, subgroup analyses and sensitivity analyses were planned to assess the impact of possible heterogeneity on the conclusions, but these were not feasible because of the small number of studies in each comparison group.

When necessary, we had planned to conduct meta-regression analysis for comparisons where multiple arm studies where used more than once. However, we did not have any multiple-arm studies that were used more than once in our comparisons using the same outcome indicator.

We also had planned to conduct a power analysis for those comparisons where the rate difference was 10 percent or higher but did not reach statistical significance. However, none of the comparisons that did not reach statistical significance was 10 percent or higher; thus, a power analysis was not performed.

To prepare for a meta-analysis for each comparison, data were abstracted from the evidence table (one meta-analysis for each outcome measure). The following data elements were entered in an SAS program to be converted into an SAS data set: the study ID number, author, year of publication, number of adverse outcomes in the experimental group, total number of patients in the experimental group, number of adverse outcomes in the control group, and total number of patients in the control group. An SAS macro software program that was developed by RAND statistical staff was used to perform all meta-analyses; the beta-test version of the software package "MetaGraphs" (1998, Belmont Research, Inc., 84 Sherman Street, Cambridge, MA 02140) was used for the graphing.

The following statistics were generated from the SAS macro program: (a) study-level statistics (incidence rate, relative risk, risk difference, number needed to treat [NNT], odds ratio, and their 95 percent CI); (b) crude estimates and their 95 percent CI for all studies combined; (c) fixed effects estimates and their 95 percent CI for all studies combined; (d) random effects estimates and their 95 percent CI based on the DerSimonian and Laird method for pooling study results and the Chi-squared test of homogeneity; and (e) weight for each study for both fixed effects model and random effects model in calculation of risk difference and relative risk.

To use MetaGraphs for graphing, the data were entered into ASCII files using the UltraEdit-32 software. Funnel plots were produced for the purpose of screening possible publication bias and the shrinkage plots were generated to display the effect size of each study and compare it against the overall model estimate, together with their 95 percent confidence limits.

## Summary of Characteristics of Articles in Evidence Report

Of the 80 studies used in the evidence report, 40 (50 percent) were published in the 1990s, 25 (31 percent) in the 1980s, 8 (10 percent) in the 1970s, and 7 (9 percent) in the 1960s. The earliest article was published in 1964 and the latest in 1998. Forty-one studies (51 percent) were conducted in the United States. Six studies did not specify either a lower or upper age limit, although they all stated that the subjects were children (Bollag and Bollag-Albrecht, 1991; Froom, Culpepper, Grob, et al., 1990; Howie and Ploussard, 1972; Laxdal, Merida, and Jones, 1970; Tilyard, Dovey, and Walker, 1997; and Townsend, 1964). Of the six studies, four were observational cohort studies and two were randomized controlled trials. All addressed Key Questions 1 and 3. The otitis-prone status of the study population, the other influencing factor considered important by the Technical Expert Panel, was not reported in 64 percent (51/80) of the studies.

Of the 80 studies, 74 were randomized controlled trials. Their study-design quality was evaluated using the Jadad score (Jadad, Moore, Carroll, et al., 1996). Of the 74 studies, 6 (8 percent) had the highest score (5 on the Jadad scale); 12 (16 percent) scored 4; 21 (28 percent) scored 3; 26 (35 percent) scored 2; 8 (11 percent) scored 1; and 1 (1 percent) scored 0. Project staff evaluated the study-design quality of the six observational cohort studies by the presence or absence of eight components of study quality. Of the six studies, two studies addressed four of the eight components, one study addressed three, two studies addressed two, and one study addressed one. Of the 74 randomized controlled studies, 30 (41 percent) mentioned double-blinding, 52 (70 percent) described the characteristics of the dropouts, 28 (38 percent) used appropriate randomization methods, and 17 (23 percent) used appropriate blinding strategies.

For definition of AOM, none of the 80 studies used all three components (middle-ear effusion, rapid onset, and signs/symptoms of inflammation) of the proposed definition established by the Technical Expert Panel; 18 (22.5 percent) used two components; 34 (42.5 percent) used only one component; and 28 (35 percent) used none. Of the 80 studies, 42 (52.5 percent) included the middle ear effusion component, 2 (2.5 percent) included the rapid onset component, and 26 (32.5 percent) included the signs/symptoms of inflammation component.

With respect to the Technical Expert Panel's criterion that an "initial" episode of AOM be separated by at least 4 weeks from the end of an antibiotic course of treatment for the last episode of AOM, 21 of 74 (28 percent) randomized controlled trials and 6 of 6 (100 percent) cohort studies did not address this issue. Many of the other studies also did not address this issue: 9 of the 15 (60 percent) studies on natural history; 3 of the 9 (33 percent) studies on the effects of antibiotics on AOM; 12 of the 34 (35 percent) studies on ampicillin or amoxicillin or trimethoprim-sulfamethoxazole vs. other antibiotic, the single study on high-dose vs. standard-dose amoxicillin; and 5 of the 36 (14 percent) studies on short-duration vs. long-duration. Of the studies that addressed duration of the initial AOM episode, 17 met the criterion of 4 weeks or longer. None required that the last episode of AOM be documented as having cleared.

## Identification of Peer Reviewers

In the letter to the 11 organizations requesting nominations for technical experts, nominations for peer reviewers also was requested. As of November 3, 1998, a total of 21 nominations for the Peer Review Panel were received. On November 16, 1998, a letter was mailed to the Ambulatory Pediatric Association (APA) and to the American Association of Health Plans (AAHP) requesting nomination of peer reviewers. Nine additional experts expressed interest to serve on the Peer Review Panel and submitted their curriculum vitae.

Experts in systematic reviews and meta-analysis were selected from a pool of experts maintained by the Southern California Evidence-based Practice Center who were not involved with this project.

The Principal Investigator, the Task Order Manager, and the Task Order Coordinator, in consultation with the Task Order Officer, determined the relative mix of reviewers across the three domains (methodology, user, and clinical). Due to the possible difference in perspective regarding antibiotic use for AOM between U.S. and non-U.S. health care providers, the Peer Review Panel was broadened to include non-U.S. experts. The criteria for their inclusion were that they be experts in the field of AOM as represented by at least two peer-reviewed publications related to AOM in the past 5 years and that they represented different professional or academic disciplines. The Peer Review Panel (Table 18) had a total of 24 members consisting of family physicians, pediatricians, otolaryngologists, experts in infectious diseases and/or otitis media, a pediatric pharmacologist, audiologists, speech-language pathologists, nurses, health plans, consumers, systematic review methodologists, meta-analysts, a health economist, and non-U.S. experts in otitis media.

Table 18. Peer Review Panel

Technical Expert | Area of Expertise | Affiliation/Location
Alfred O. Berg, M.D., M.P.H. | Family Medicine | University of Washington, Seattle, WA
Larry Culpepper, M.D.,M.P.H. | Family Medicine | Boston Medical Center, Boston, MA
Robert Ruben, M.D. | Otolaryngology | Montefiore Medical Center, Bronx, NY
Stanford T. Shulman, M.D. | Pediatrics, Infectious Disease | Children's Memorial Hospital, Chicago
Elizabeth Susan Hodgson, M.D. | Pediatrics, Ambulatory | St. Peter's Pediatric Faculty Group PracticeNew Brunswick, NJ
Jerome Klein, M.D. | Pediatrics, Infectious Disease | Boston Medical Center, Boston, MA
Lisa L. Hunter Ph.D. | Audiology | University of Minnesota, Minneapolis, MN
Terese Finitzo, Ph.D. | Audiology | Dallas, TX
Carol Rudy, M.S.N.,C.P.N.P. | Nurse Practitioner | Spokane, WA
Tracy Lieu, M.D. | Health Plan | Harvard Pilgrim Health Care, Boston, MA
Michael Siegel, M.D. | Health Plan | Prudential Health Care Plan, CA
Fran Goldfarb, M.A. | Consumer | Family Voices, Los Angeles, CA
Mark P. Haggard, Ph.D. | Epidemiology and Outcomes Methods | Institute for Hearing Research, UK
Anne G.M. Schilder, M.D., Ph.D. | Otolaryngology | University Medical Center Utrecht, TheNetherlands
Hanan S. Bell, Ph.D. | Methodology reviewer | Seattle, WA
Vic Hasselblad, Ph.D. | Meta-analysis reviewer | Duke University, Durham, NC
Katherine Harris, Ph.D. | Cost-analysis reviewer | RAND, Santa Monica, CA
Lynne Haverkos, M.D. | Government reviewer | NICHD
Robin Yurk, M.D., M.P.H. | Consumer | The Foundation for Accountability, Portland, OR
Peer Reviewer #20 | Otolaryngologist
Peer Reviewer #21 | Nurse practitioner
Peer Reviewer #22 | Pediatric pharmacologist
Peer Reviewer #23 | Pediatrician
Peer Reviewer #23 | Methodology reviewer

## Peer Review Process

A copy of the draft evidence report was mailed to each peer reviewer on the panel together with an instruction sheet (Table 19) for reviewing the draft evidence report. The Panel was asked to respond within 3 weeks. The 24 peer reviewers responded with comments. A copy of the draft evidence report also was mailed to the members of the Technical Expert Panel. Upon receipt of all responses from the peer reviewers and technical experts, the project staff compiled a summary of the comments and changes and revised the draft evidence report. The revisions and comments from peer reviewers were sent to the Task Order Officer for approval. Once the revisions were approved, a final evidence report and a draft manuscript were produced and submitted to the technical experts and Task Order Officer for final approval.

Table 19. Instructions for reviewing draft evidence report

Enclosed is a draft evidence report on the management of acute otitis media. You may make your comments either directly on the draft evidence report, or on a separate sheet of paper. If you choose to record your comments on a separate piece of paper, please use the page and paragraph number to identify to which part of the report your comments pertain. We ask that you consider the following questions while you read this report. We realized that some of the questions may not pertain to your area of expertise. Please feel free to comment only on those that you feel most suited to answer.
1. Overall evaluation Is it clear what we did? You may agree or disagree with our methods, findings, or conclusions, but you should be able to understand what we did in order to produce this report.
2. Methodology Are the methods we used appropriate: (a) for identifying the key questions of interest from the panel of technical experts? (b) for searching and reviewing the identified literature? (c) for synthesizing the literature?
3. Evidence (a) Did we miss any crucial pieces of information in our literature search? (b) Does the evidence support the conclusions?
4. Utility Would you find this information to be useful if you had to develop clinical practice guidelines or medical review criteria for management of acute otitis media in children?