# Appendix H. Data Abstraction Form for Article Review

1. Reviewer ID (1=GT, 2=WM) ___
2. Record Number ___ ___ ___ ___
3. Unique Identifier ___ ___ ___ ___ ___ ___ ___ ___
4. Authors: __________________________________
5. Year of Publication ___ ___ ___ ___
6. Describe the Study Groups
  Parameter | Group 1 | Group 2 | Group 3 | Group 4
  Name of intervention | _____________ | _____________ | _____________ | ______________
  Dosage | _____________ | _____________ | _____________ | ______________
  Frequency | _____________ | _____________ | _____________ | ______________
  Duration | _____________ | _____________ | _____________ | ______________
  Route of administration | _____________ | _____________ | _____________ | ______________
  Co-intervention 1 | _____________ | _____________ | _____________ | ______________
  Co-intervention 1 | _____________ | _____________ | _____________ | ______________
  Co-intervention 1 | _____________ | _____________ | _____________ | ______________
  Co-therapies | _____________ | _____________ | _____________ | ______________
  Co-therapies | _____________ | _____________ | _____________ | ______________
  Co-therapies | _____________ | _____________ | _____________ | ______________
  Co-therapies | _____________ | _____________ | _____________ | ______________
  N at beginning of study | _____________ | _____________ | _____________ | ______________
  N lost to followup | _____________ | _____________ | _____________ | ______________
  Inception time of subjects | _____________ | _____________ | _____________ | ______________
7. List inclusion criteria
  a)_____________________ | b) ___________________ | c) _____________________
  d)____________________ | e) ____________________ | f)_____________________
  g)_____________________ | h)____________________ | i) _____________________
  j)_____________________ | k)___________________ | l) _____________________
8. List exclusion criteria
  a) _____________________ | b) ___________________ | c) _____________________
  d) ____________________ | e) ____________________ | f)_____________________
  g) _____________________ | h) ____________________ | i) _____________________
  j) _____________________ | k) ___________________ | l) _____________________
9. Circle the 'x' at which the outcome measure(s) was(were) studied.
  | Time at which outcome was measured
  Outcomes | <48hrs | 3-7 d | 7-14 d | 14d-3 m | >3 m
  Presence/absence of
  Pain | x____ | x____ | x____ | x____ | x____
  Otorrhea | x____ | x____ | x____ | x____ | x____
  Irritability | x____ | x____ | x____ | x____ | x____
  Fever | x____ | x____ | x____ | x____ | x____
  Anorexia | x____ | x____ | x____ | x____ | x____
  nausea (disequilibrium) | x____ | x____ | x____ | x____ | x____
  vomiting | x____ | x____ | x____ | x____ | x____
  diarrhea | x____ | x____ | x____ | x____ | x____
  Presence/absence of
  limited or absent mobility of TM | x____ | x____ | x____ | x____ | x____
  hearing deficit | x____ | x____ | x____ | x____ | x____
  speech problem | | | | | x____
  Presence/absence of
  recurrence of AOM | | | | x____ | x____
  Presence/absence of
  acute suppurative complication/
  secondary complications
  mastoiditis | x____ | x____ | x____ | x____ | x____
  petrositis | x____ | x____ | x____ | x____ | x____
  acute suppurative labyrinthitis | x____ | x____ | x____ | x____ | x____
  extradural abscess | x____ | x____ | x____ | x____ | x____
  subdural abscess (empyema) | x____ | x____ | x____ | x____ | x____
  brain abscess | x____ | x____ | x____ | x____ | x____
  lateral sinus thrombosis | x____ | x____ | x____ | x____ | x____
  Presence/absence of
  side/adverse effects from meds | x____ | x____ | x____ | x____ | x____
  Presence/absence of
  bacteria (sterile/nonsterile) | x____ | x____ | x____ | x____ | x____
  resistant bacteria | x____ | x____ | x____ | x____ | x____
  Cost of care
  direct cost | x____ | x____ | x____ | x____ | x____
  indirect cost | x____ | x____ | x____ | x____ | x____
  total cost | x____ | x____ | x____ | x____ | x____
  Quality of life | x____ | x____ | x____ | x____ | x____
10. Circle the influencing factors studied and write down how measured (categories).
  Demographic
  Age of child | x ____________________________________
  Gender | x ____________________________________
  Ethnicity/race | x ____________________________________
  Environmental
  Presence of sibling(s) | x ____________________________________
  Attendance at day care center | x ____________________________________
  Sibling(s) in day care center | x ____________________________________
  Feeding mode-bottle vs. breast | x ____________________________________
  Pacifier use | x ____________________________________
  Tobacco smoke exposure | x ____________________________________
  Ear infections in parents/siblings | x ____________________________________
  Season of the year | x ____________________________________
  Symptoms by history
  Otalgia and severity | x ____________________________________
  Hearing deficit and severity | x ____________________________________
  Signs/physical findings
  Pulling of ear in an infant | x ____________________________________
  Otorrhea | x ____________________________________
  Irritability | x ____________________________________
  Fever | x ____________________________________
  Hearing loss | x ____________________________________
  TM inflammation | x ____________________________________
  Retracted TM | x ____________________________________
  Purulent otorrhea | x ____________________________________
  Middle ear effusion | x ____________________________________
  Other clinical factors
  Otitis prone | x ____________________________________
  Underlying predisposing problem | x ____________________________________
  Prior antibiotic use & when used | x ____________________________________
  Concurrent use of analgesics, etc. | x ____________________________________
  Prior hearing deficit | x ____________________________________
  Inability to express symptoms | x ____________________________________
  Atopy or allergy | x ____________________________________
  Presence of tube | x ____________________________________
  Parent/caretaker
  Parent/caretaker availability | x ____________________________________
  Parent/caretaker preference | x ____________________________________
  Parent/caretaker education | x ____________________________________
  Examiner
  Type of examiner | x ____________________________________
  Skill to diagnose (validated) | x ____________________________________
  Setting | x ____________________________________
  Monitoring during episode/therapy course
  When | x ____________________________________
  | x ____________________________________
  Primary person (parent/provider) | x ____________________________________
  Type | x ____________________________________
  Cost
  Cost of treatment | x ____________________________________
  ___________________________________ | x ____________________________________
  ___________________________________ | x ____________________________________
  ___________________________________ | x ____________________________________
  ___________________________________ | x ____________________________________
  ___________________________________ | x ____________________________________
  ___________________________________ | x ____________________________________
  ___________________________________ | x ____________________________________
11. For each outcome at each time point and for each age group, influencing factor group, intervention group, provide the following:
  Study Group | Age Gp Studied | Factor 1 Subgroup | Factor 2 Subgroup | Factor 3 Subgroup | Outcome | Begin Time | End Time | N in Group | N had Event
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
  ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________ | ________
12. Was there multivariate analysis performed?
  Yes | No | Unsure
  1 | 0 | 0
  If "Yes", continue.
13. Type of analysis: _____________________________________ Dependent variable(s): _____________________________________ _____________________________________ _____________________________________ Independent variables: _____________________________________ _____________________________________ _____________________________________ _____________________________________ _____________________________________ _____________________________________ Equations/Numerical Results: ___________________________________________________________________ ___________________________________________________________________ ___________________________________________________________________ ___________________________________________________________________ ___________________________________________________________________ ___________________________________________________________________ ___________________________________________________________________ ___________________________________________________________________ ___________________________________________________________________