# Appendix G. Article Quality Review Form

## 1. Article Quality Review Form

1. Reviewer ID (1=GT, 2=WM) ___ 1/
2. Record Number ___ ___ ___ ___ 2-5/
3. Unique Identifier ___ ___ ___ ___ ___ ___ ___ ___ 6-13/
4. Authors:
5. Year of Publication ___ ___ ___ ___ 14-17/
6. Study Design
  Randomized controlled trial........................................................ | 1 18/
  Non-randomized controlled trial.................................................... | 2
  Prospective comparative cohorts................................................ | 3
  Retrospective comparative cohorts............................................. | 4
  Case control.............................................................................. | 5
  Natural history/Observational/Longitudinal single cohort............ | 6
  Unsure......................................................................................... | 9
  IF NONE OF THE ABOVE, STOP.
7. Key Question Addressed
  | | Yes | No | Unsure
  Natural history.................................................. | | 1 | 2 | 9 | 19/
  Antibiotic vs. Observation.................................. | | 1 | 2 | 9 | 20/
  Antibiotic vs. Placebo......................................... | | 1 | 2 | 9 | 21/
  Antibiotic vs. Antibiotic
  a) | antibiotics of broader coverage vs. amoxicillin or trimethoprim/sulfamethoxazole | 1 | 2 | 9 | 22/
  b) | oral fluoroquinolones.................................. | 1 | 2 | 9 | 23/
  c) | high-dose amoxicillin or amoxicillin-clavulanate vs. standard dose.................. | 1 | 2 | 9 | 24/
  d) | twice a day high-dose amoxicillin therapy vs. three time a day amoxicillin.............. | 1 | 2 | 9 | 25/
  e) | short- vs. long-term antibiotic therapy.... | 1 | 2 | 9 | 26/
  f) | other........................................................... | 1 | 2 | 9 | 27/
  IF NONE OF THE ABOVE, STOP.

### Quality of Definition of Acute Otitis Media

8 Check all criteria used in defining acute otitis media:
  | | Yes | No | Unsure
  a) | presence of fluid in the middle ear on tympanocentesis....... | 1 | 2 | 9 | 28/
  b) | limited/absent mobility of TM on pneumatic otoscopy......... | 1 | 2 | 9 | 29/
  c) | limited/absent mobility of TM on tympanogram................. | 1 | 2 | 9 | 30/
  d) | limited/absent mobility of TM on acoustic reflectometry... | 1 | 2 | 9 | 31/
  e) | opacification, not including erythema................................ | 1 | 2 | 9 | 32/
  f) | a full or bulging tympanic membrane................................ | 1 | 2 | 9 | 33/
  g) | hearing loss..................................................................... | 1 | 2 | 9 | 34/
  h) | rapid onset (within 48 hours)........................................... | 1 | 2 | 9 | 35/
  i) | otalgia (or pulling of ear in an infant).............................. | 1 | 2 | 9 | 36/
  j) | otorrhea........................................................................... | 1 | 2 | 9 | 37/
  k) | irritability....................................................................... | 1 | 2 | 9 | 38/
  m) | fever............................................................................. | 1 | 2 | 9 | 39/
  n) | anorexia............................................................................ | 1 | 2 | 9 | 40/
  o) | nausea............................................................................... | 1 | 2 | 9 | 41/
  p) | vomiting............................................................................ | 1 | 2 | 9 | 42/
  q) | diarrhea................................................................. | 1 | 2 | 9 | 43/
  r) | _________________________________________________ | 1 | | | 44/
  | _________________________________________________
  s) | _________________________________________________ | 1 | | | 45/
  | _________________________________________________
  t) | _________________________________________________ | 1 | | | 46/
  | _________________________________________________
  u) | _________________________________________________ | 1 | | | 47/
  | _________________________________________________
  v) | _________________________________________________ | 1 | | | 48/
  | _________________________________________________
  w) | _________________________________________________ | 1 | | | 49/
  | _________________________________________________
  x) | _________________________________________________ | 1 | | | 50/
  | _________________________________________________
  y) | _________________________________________________ | 1 | | | 51/
  | _________________________________________________
  z) | _________________________________________________ | 1 | | | 52/
  | _________________________________________________

### QUALITY OF CONTROLLED TRIALS (Answer 1 or 2 in Item 6)

| | Yes | No | Unsure
9. | Was the study described as randomized? | 1 | 0 | 53/
10. | Was the study described as double-blind? | 1 | 0 | 54/
11. | Was there a description of withdrawals and dropouts? | 1 | 0 | 55/
12. | Was randomization procedure appropriate? | 1 | −1 | 0 | 56/
13. | Was blinding procedure appropriate? | 1 | −1 | 0 | 57/
14. | Were the groups (exposed or unexposed) similar at baseline regarding the most important prognostic variables? | 1 | 0 | 0 | 58/
15. | Was compliance with treatment addressed adequately? | 1 | 0 | 0 | 59/
16. | Was complete followup achieved? | 1 | 0 | 0 | 60/

### QUALITY OF COHORT(S) STUDY (Answer 3 or 4 in Item 6)

| | Yes | No/Unsure
17. | Was the study cohort(s) clearly defined? (Inclusion and exclusion criteria clearly spelled out) | 1 | 0 | 61/
18. | Was the study cohort(s) assembled at an early and uniform point (inception) in the course of the illness? | 1 | 0 | 62/
19. | Was the pathway(s) by which patients entered the study clearly described? | 1 | 0 | 63/
20. | Was complete followup achieved? | 1 | 0 | 64/
21. | Was there a description of withdrawals and dropouts? | 1 | 0 | 65/
22. | Were objective outcome criteria developed and used? | 1 | 0 | 66/
23. | Was the outcome assessment "blind?" | 1 | 0 | 67/
24. | Was adjustment for extraneous prognostic factors carried out? | 1 | 0 | 68/

### QUALITY OF CASE-CONTROL STUDY (Answer 5 in Item 6)

| | Yes | No/Unsure
25. | Was the source of cases identified? | 1 | 0 | 69/
26. | Was the source of controls identified? | 1 | 0 | 70/
27. | Was there blinded assessment of
| a) eligibility of cases and controls | 1 | 0 | 71/
| b) outcome | 1 | 0 | 72/
| c) exposure | 1 | 0 | 73/
28. | Were the matching criteria of cases and controls clearly spelled out? | 1 | 0 | 74/
29. | Were the criteria defining the cases clearly spelled out? | 1 | 0 | 75/
30. | Was the exposure status clearly identified? | 1 | 0 | 76/
31. | Was the duration of exposure defined? | 1 | 0 | 77/
32. | Was the temporal relation of the exposure to the case event clearly defined? | 1 | 0 | 78/
33. | Was there an adjustment in the analysis for known confounders not included in matching? | 1 | 0 | 79/

### QUALITY OF SINGLE COHORT OBSERVATIONAL STUDY FOR NATURAL HISTORY STUDY (Answer 6 in Item 6)

| | Yes | No/Unsure
34. | The study was qualified as a natural history study because
| a) it was designed as a natural history study | 1 | | 80/
| b) it was the control arm of a clinical trial | 2
| c) it was the control arm of a cohort study | 3
| d) unsure | 9
35. | Was the outcome(s) of the study clearly defined? | 1 | 0 | 81/
36. | Was the time point(s) at which the outcome(s) was measured clearly defined? | 1 | 0 | 82/
37. | Was the cohort of subjects followed without any intervention? | 1 | 0 | 83/
38. | Was there blinded assessment of the outcomes of the study? | 1 | 0 | 84/
39. | Were point estimates and measures of variability provided for the main adverse outcome measures? | 1 | 0 | 85/

## 2. Instructions for Article Quality Review Form

1. Reviewer ID: self-explanatory
2. Record number: self-explanatory
3. Unique identifier: self-explanatory
4. Authors: self-explanatory
5. Year of publication: self-explanatory
6. Study design:
  a. In general, this item is self-explanatory.
  b. Remember that case studies, case series, and cross-sectional studies are not included in this list because they are not eligible for the analysis.
  c. If you think the study may be one of those listed or might have the potential with acquisition of the data and reanalysis, mark "9" and, if you like, write a comment.
7. Key question addressed:
  a. In general, this item is self-explanatory and has the same instructions as for the titles/abstracts screening form.
  b. A particular article may be pertinent to zero or > 1 key question. Circle all that apply.
  c. For 7.a), recall that "antibiotics of broader coverage" may be defined as second-line-or-higher-level treatment.
  d. For 7.e), recall that short-term therapy is < 5 days and that long-term therapy is > 5 days.
  e. For 7.f), "other" is any other comparison of antibiotic vs. antibiotic.
8. Criteria used in defining acute otitis media:
  a. Some studies may not list any criteria; in this case, circle "2" for 8.a)-8.q).
  b. Be sure to list only those criteria actually used by a study to define a case of acute otitis media. Many studies will also note other signs or symptoms but not actually use them to define acute otitis media.
  c. We will have to go back to the articles and make sure we have the logic and wording of the definitions correct for the evidence tables, especially for the "write-in" criteria 8.r)-8.z).
9. Randomization: A study calls itself randomized.
10. Double-blind: "A study must be regarded as double blind if the word 'double blind' is used." (Jadad, Moore, Carroll, et al., 1996)
11. Withdrawals and dropouts: "Participants who were included in the study but did not complete the observation period or who were not included in the analysis must be described. The number and the reasons for withdrawal in each group must be stated. If there were not withdrawals, it should be stated in the article. If there is no statement on withdrawals, this item must be given no points." (Jadad, Moore, Carroll, et al., 1996)
12. Appropriate randomization:
  a. "A method to generate the sequence of randomization will be regarded as appropriate if it allowed each study participant to have the same chance of receiving each intervention and the investigators could not predict which treatment was next. Methods of allocation using date of birth, date of admission, hospital numbers, or alternation should not be regarded as appropriate." (Jadad, Moore, Carroll, et al., 1996)
  b. "Assign patients to groups in a way that gives each patient an equal chance of falling into one or the other group." (Fletcher, Fletcher, and Wagner, 1982)
13. Appropriate blinding: "The method will be regarded as appropriate if it is stated that neither the person doing the assessments nor the study participant could identify the intervention being assessed, or if in the absence of such a statement for use of active placebos, identical placebos, or dummies is mentioned." (Jadad, Moore, Carroll, et al., 1996)
14. Similarity of comparison groups:
  a. In general, this item is self-explanatory.
  b. At minimum, the groups should be comparable with regard to age, especially the proportion less-than two years of age.
15. Compliance: self-explanatory
16. Complete follow-up: The outcome is known for each patient. See item 20 on complete follow-up for a cohort study. The same principles apply.
17. Cohorts defined: self-explanatory
18. Inception point: self-explanatory
19. Entry pathway: self-explanatory
20. Complete follow-up: "All members of the inception cohort should be accounted for at the end of the follow-up period, and their clinical status should be known." (Sackett, Haynes, and Tugwell, 1985)
21. Withdrawals and dropouts: See item 11.
22. Objective outcome criteria: self-explanatory
23. Blind outcome assessment: The investigator assessing the outcome(s) does not know what exposure(s) the patient has experienced.
24. Adjustment for extraneous prognostic factors: self-explanatory
25. Source of cases: self-explanatory
26. Source of controls: self-explanatory
27. Blind assessment: See item 23.
28. Matching criteria: self-explanatory
29. Criteria defining cases and controls: self-explanatory
30. Exposure status: self-explanatory
31. Duration of exposure: self-explanatory
32. Temporal relation of exposure to case event: self-explanatory
33. Adjustment for confounders: self-explanatory
34. Qualification for natural history study: self-explanatory
35. Outcome(s) defined: self-explanatory
36. Time point(s) of outcome(s): self-explanatory
37. Absence of intervention: self-explanatory
38. Blind outcome(s) assessment: See item 23.
39. Point estimates and variability for outcome(s): self-explanatory