# Appendix F. Title and Abstract Screening Form

1. Reviewer ID (1=GT, 2=LW) ___
2. Record #:
3. Unique Identifier:
4. Author(s):
5. Year of Publication
6. Revisit Search Rejection Criteria GO IN ORDER FROM R1 TO R5, STOP AT FIRST "YES"
  | Yes | No | Unsure
  R1: Case report/editorial/letter/clinical practice/overview/...... Practice guidelines/consensus statements | 1 | 2 | 9
  R2: Non-human subjects........................................................ | 1 | 2 | 9
  R3: Study condition is NOT acute otitis media...................... | 1 | 2 | 9
  R4: Age of study population < 4 weeks or >=18 years | 1 | 2 | 9
  R5: Study population on patients with immunodeficiencies or Craniofacial deficiencies including cleft palate | 1 | 2 | 9
7. Key Question Addressed
  | Yes | No | Unsure
  Natural history.................................................................. | 1 | 2 | 9
  Antibiotic vs Observation................................................ | 1 | 2 | 9
  Antibiotic vs Placebo........................................................ | 1 | 2 | 9
  Antibiotic vs Antibiotic........................................................ | 1 | 2 | 9
  END

## Instructions for Screening

1. For each title/abstract, go in order of the five rejection criteria, from R1 to R5. Stop at the first "Yes" in item 6.
2. If the article is not rejected by R1 through R5, go on to item 7. If item 7 has ALL "No"s, the article will be rejected.
3. Specific instruction on R1:
  a. Case report includes case series
  b. Overview includes reviews
4. Specific instruction on AOM:
  a. Reject if the study is solely on: (compiled from Bluestone and Klein, 1996; Otitis Media with Effusion Guidelines, 1994; Harkness and Topham, 1998; and Paparella, Bluestone, et al., 1985)
    1. Otitis media with effusion including the following synonyms: Serous otitis media or serotympanum or acute serous otitis media or chronic serous otitis media Secretory otitis media Allergic otitis media Catarrhal otitis media or catarrh Nonsuppurative otitis media or chronic nonsuppurative otitis media Mucoid otitis media or mucotympanum or chronic mucoid otitis media Secondary otitis media Tubotympanic catarrh Hydrotubotympanum Exudative catarrh Tubotympanitis Tympanic hydrops Glue ear Fluid ear
    2. Other chronic or persistent forms of otitis media: Chronic otitis media Chronic tubotympanic suppurative otitis media Chronic atticoantral suppurative otitis media Chronic suppurative otitis media Chronic purulent otitis media Persistent otitis media
  b. Reject if the PRIMARY condition of the article is not AOM.
  c. Do not reject if the diagnostic term is vague, such as otitis media without any descriptors, or a term with which we are not familiar.
  d. Do not reject if AOM is one of several conditions studied. Synonyms for acute otitis media include: (Bluestone and Klein, 1996) Acute suppurative otitis media Acute purulent otitis media Bacterial otitis media
5. Specific instructions on AGE:
  a. Do not reject if the term "neonate" is used without reference to a specific age range that is completely outside of our scope of greater-than 4 weeks and less-than 18 years.
  b. Reject if the population is referred to as an adult population even if a specific age is not mentioned.
  c. Do not reject if the age scope of the study is a subset of the acceptable age range or has an age range larger than our acceptable age range.
6. Specific instruction on Natural History:
  a. Criteria for Natural History: Must address
    a. outcome and
    b. time and
    c. without any intervention
    If abstract does not address one or more of the criteria, mark unsure.
  b. If a study involves other interventions besides antibiotics, such as myringotomy/tympanocentesis, but has a control arm that uses placebo or no intervention, then it qualifies for a Natural History study.
7. Specific instruction on Type of Antibiotics:
  a. The following antibiotics are included: Amoxicillin Amoxicillin-clavulanate Azithromycin Cefdinir Cefixime/Cefprozil Cefpodoxime Ceftibuten Ceftriaxone Cefuroxime Clarithromycin Clindamycin Loracarbef Sulfisoxazole Trimethoprim-sulfamethoxazole
  b. Include all studies on antibiotics, antimicrobials, anti-bacterials, anti-infectives.
  c. If uncertain, do not reject study.