# Appendix E. Scope of the Evidence Report

I. Scope of the Evidence Report as of December 18, 1998

Disease entity: | Uncomplicated Acute Otitis Media ^1^
Disease entity: | Exclude: patients with immunodeficiencies and craniofacial deficiencies including cleft palate.
Patient population: | Age 4 weeks to 18 years
Setting: | All types of providers and practice settings
Intervention: | Observation/no intervention/natural history/placebo ^2^
Intervention: | Antibiotic treatment (all classes, schedule, dosage, length, and mode) ^3^
Influencing factors: | Demographic
Influencing factors: | Age of child
Influencing factors: | Gender
Influencing factors: | Ethnicity/race
Influencing factors: | Environmental
Influencing factors: | Presence of sibling(s)
Influencing factors: | Attendance at day care center
Influencing factors: | Sibling(s) in day care center
Influencing factors: | Feeding mode-bottle vs. breast
Influencing factors: | Pacifier use
Influencing factors: | Tobacco smoke exposure
Influencing factors: | History and/or presence of ear infections in parents or siblings
Influencing factors: | Signs and symptoms by history
Influencing factors: | Prior history of recurrent AOM
Influencing factors: | Otalgia (or pulling of ear in an infant)
Influencing factors: | Otorrhea
Influencing factors: | Irritability
Influencing factors: | Fever
Influencing factors: | Hearing loss (older children)
Influencing factors: | Severity of initial symptoms
Influencing factors: | Season of the year
Influencing factors: | Physical findings
Influencing factors: | Tympanic membrane (TM) inflammation
Influencing factors: | Retracted TM
Influencing factors: | Purulent otorrhea
Influencing factors: | Middle ear effusion
Influencing factors: | Other clinical factors
Influencing factors: | Underlying predisposing problem (viral infection)
Influencing factors: | Prior antibiotic use
Influencing factors: | Concurrent use of analgesics
Influencing factors: | Multiple previous episodes
Influencing factors: | Hearing and/or speech problems
Influencing factors: | Atopy or allergy
Influencing factors: | Craniofacial problems
Influencing factors: | Parent/caretaker
Influencing factors: | Parent/caretaker availability
Influencing factors: | Parent/caretaker preference
Influencing factors: | Parent/caretaker education
Influencing factors: | Provider
Influencing factors: | Type of provider
Influencing factors: | Experience
Influencing factors: | Setting
Influencing factors: | Monitoring system of course of antibiotic treatment or during episode
Influencing factors: | Frequency (none, daily, every other day)
Influencing factors: | Primary person (parent or provider)
Influencing factors: | Type (tympanometry, acoustic reflectometry, pneumatic otoscopy)
Influencing factors: | Cost
Influencing factors: | Cost of treatment
Influencing factors: | Cost of total care
Outcome measures: | Within 48 hours
Outcome measures: | Presence/absence of pain/otorrhea/irritability/fever/hearing loss
Outcome measures: | Presence/absence of discharge/inflammation of TM
Outcome measures: | Presence/absence of acute suppurative complications/secondary complications
Outcome measures: | Mastoiditis
Outcome measures: | Petrositis
Outcome measures: | Acute suppurative labyrinthitis
Outcome measures: | Extradural abscess
Outcome measures: | Subdural abscess (empyema)
Outcome measures: | Brain abscess
Outcome measures: | Meningitis
Outcome measures: | Lateral sinus thrombosis
Outcome measures: | Presence/absence of all signs/symptoms except middle ear effusion
Outcome measures: | Cost of care
Outcome measures: | Presence/absence of resistant bacteria
Outcome measures: | Between 3-7 days
Outcome measures: | Presence/absence of pain/otorrhea/irritability/fever/hearing loss
Outcome measures: | Presence/absence of discharge/inflammation of TM
Outcome measures: | Presence/absence of acute suppurative complications/secondary complications
Outcome measures: | Mastoiditis
Outcome measures: | Petrositis
Outcome measures: | Acute suppurative labyrinthitis
Outcome measures: | Extradural abscess
Outcome measures: | Subdural abscess (empyema)
Outcome measures: | Brain abscess
Outcome measures: | Meningitis
Outcome measures: | Lateral sinus thrombosis
Outcome measures: | Presence/absence of all signs/symptoms except middle ear effusion
Outcome measures: | Cost of care
Outcome measures: | Presence/absence of resistant bacteria
Outcome measures: | Between 7-14 days
Outcome measures: | Presence/absence of pain/otorrhea/irritability/fever/hearing loss
Outcome measures: | Presence/absence of discharge/inflammation of TM
Outcome measures: | Presence/absence of acute suppurative complications/secondary complications
Outcome measures: | Mastoiditis
Outcome measures: | Petrositis
Outcome measures: | Acute suppurative labyrinthitis
Outcome measures: | Extradural abscess
Outcome measures: | Subdural abscess (empyema)
Outcome measures: | Brain abscess
Outcome measures: | Meningitis
Outcome measures: | Lateral sinus thrombosis
Outcome measures: | Presence/absence of all signs/symptoms except middle ear effusion
Outcome measures: | Cost of care
Outcome measures: | Presence/absence of resistant bacteria
Outcome measures: | Between 14 days--3 months
Outcome measures: | Presence/absence of asymptomatic middle ear effusion
Outcome measures: | Presence/absence of acute suppurative complications (mastoiditis)
Outcome measures: | Presence/absence of recurrence
Outcome measures: | Presence/absence of acute suppurative complications/secondary complications
Outcome measures: | Mastoiditis
Outcome measures: | Petrositis
Outcome measures: | Acute suppurative labyrinthitis
Outcome measures: | Extradural abscess
Outcome measures: | Subdural abscess (empyema)
Outcome measures: | Brain abscess
Outcome measures: | Meningitis
Outcome measures: | Lateral sinus thrombosis
Outcome measures: | Presence/absence of hearing problems
Outcome measures: | Presence/absence of speech problems
Outcome measures: | Cost of total care
Outcome measures: | Presence/absence of resistant bacteria
Outcome measures: | Greater than 3 months (to be determined)
Time period: | 1966- 1998
Literature source: | MEDLINE
Literature source: | EMBASE
Literature source: | HealthSTAR
Literature source: | CINAHL (nursing and allied paramedical professionals)
Literature source: | Cochrane Database of Systematic Reviews
Literature source: | Database of Abstracts and Reviews of Effectiveness (English National Health Services Center for Reviews and Dissemination)
Literature source: | References of published articles
Language: | English and foreign Languages
Study design: | Randomized controlled trials, blinded and unblinded
Study design: | Non-randomized controlled trials, blinded and unblinded
Study design: | Prospective cohort studies (for observational/no treatment)
Study design: | Retrospective cohort studies
Study design: | Case-control studies

1 Acute otitis media is defined as 1) rapid onset of 2) signs of middle ear effusion and and inflammation accompanied by 3) clinical findings which generally include one or more of the following: a) otalgia (or pulling of ear in an infant), b) otorrhea, c) irritability, d) fever, and e) hearing loss (older children). Uncomplicated AOM is defined as AOM limited to the middle ear cleft.

2 Observational treatment or no intervention is defined as initial management of the disease WITHOUT antibiotic streatment with or without a monitoring protocol. Placebo treatment is defined as initial management of the disease with a placebo in place of antibiotics in randomized controlled trials. Natural history is defined as the natural course of the disease without any intervention by provider or parent.

3 For Question 3 all antibiotic regimens are aggregated, and for Question 4 the antibiotic regimens are specified as per the subquestions.

II. Revised Scope of the Evidence Report asof February 1, 1999

Disease entity: | Uncomplicated Acute Otitis Media ^1^
Disease entity: | Exclude: patients with immunodeficiencies and craniofacial deficiencies including cleft palate
Patient population: | Age 4 weeks to 18 years
Setting: | All types of providers and practice settings
Intervention: | Observation/no intervention/natural history/placebo ^2^
Intervention: | Antibiotic treatment (all classes, schedule, dosage, length, and mode) ^3^
Influencing factors ^4^ : | Demographic
Influencing factors ^4^ : | Age of child
Influencing factors ^4^ : | Gender
Influencing factors ^4^ : | Ethnicity/race
Influencing factors ^4^ : | Environmental
Influencing factors ^4^ : | Presence of sibling(s)
Influencing factors ^4^ : | Attendance at day care center
Influencing factors ^4^ : | Sibling(s) in day care center
Influencing factors ^4^ : | Feeding mode-bottle vs. breast
Influencing factors ^4^ : | Pacifier use
Influencing factors ^4^ : | Tobacco smoke exposure
Influencing factors ^4^ : | History and/or presence of ear infections in parents or siblings
Influencing factors ^4^ : | Season of the year
Influencing factors ^4^ : | Symptoms by history
Influencing factors ^4^ : | Otalgia and severity
Influencing factors ^4^ : | Hearing deficit and severity
Influencing factors ^4^ : | Signs/physical findings
Influencing factors ^4^ : | Pulling of ear in an infant
Influencing factors ^4^ : | Otorrhea
Influencing factors ^4^ : | Irritability
Influencing factors ^4^ : | Fever
Influencing factors ^4^ : | Hearing loss
Influencing factors ^4^ : | Tympanic membrane (TM) inflammation
Influencing factors ^4^ : | Retracted TM
Influencing factors ^4^ : | Purulent otorrhea
Influencing factors ^4^ : | Middle ear effusion
Influencing factors ^4^ : | Other clinical factors
Influencing factors ^4^ : | Otitis prone ^5^ (prior history of recurrent AOM, multiple previous episodes)
Influencing factors ^4^ : | Underlying predisposing problem (viral infection)
Influencing factors ^4^ : | Prior antibiotic use and when used
Influencing factors ^4^ : | Concurrent use of analgesics
Influencing factors ^4^ : | Prior hearing deficit
Influencing factors ^4^ : | Inability to express symptoms
Influencing factors ^4^ : | Atopy or allergy
Influencing factors ^4^ : | Presence of tube
Influencing factors ^4^ : | Parent/caretaker
Influencing factors ^4^ : | Parent/caretaker availability
Influencing factors ^4^ : | Parent/caretaker preference
Influencing factors ^4^ : | Parent/caretaker education
Influencing factors ^4^ : | Examiner
Influencing factors ^4^ : | Type of examiner (family physician, otolaryngologist, pediatrician, nurse practitioner, physician assistant, etc.)
Influencing factors ^4^ : | Skill to diagnose (validated examiner/observer)
Influencing factors ^4^ : | Setting (public, private, PPO, HMO, etc.)
Influencing factors ^4^ : | Monitoring during episode or course of therapy
Influencing factors ^4^ : | When
Influencing factors ^4^ : | Frequency (none, daily, every other day)
Influencing factors ^4^ : | Primary person (parent or provider)
Influencing factors ^4^ : | Type (tympanometry, acoustic reflectometry, pneumatic otoscopy)
Influencing factors ^4^ : | Cost
Influencing factors ^4^ : | Cost of treatment

1 Acute otitis media is defined as 1) presence of middle ear effusion as demonstrated by the actual presence of fluid in the middle ear as diagnosed by tympanocentesis or indicated by limited or absent mobility of the tympanic membrane as diagnosed by pneumatic otoscopy, tympanogram, or acoustic reflectometry with or without the following: a) opacification, not including erythema, b) a full or bulging tympanic membrane, or c) hearing loss AND 2) rapid onset (over the course of 48 hours) OF 3) one or more of the following clinical signs or symptoms: a) otalgia (or pulling of ear in an infant), b) otorrhea, c) irritability in the infant or toddler, or d) fever, with or without anorexia, nausea, vomiting, or diarrhea. Uncomplicated AOM defined as AOM limited to the middle ear cleft.

2 Observational treatment or no intervention is defined as initial management of the disease WITHOUT antibiotic treatment with or without a monitoring protocol. Placebo treatment is defined as initial management of the disease with a placebo in place of antibiotics in randomized controlled trials. Natural history is defined as the natural course of the disease without any intervention by provider or parent.

3 For Question 3 all antibiotic regimens are aggregated, and for Question 4 the antibiotic regimens are specified as per the subquestions.

4 An influencing factor is defined as a characteristic of the patient or the environment or the health care delivery system that may affect the natural history of the disease or the outcome(s) of the intervention of interest. The list of influencing factors has been reorganized and contains several additional factors since the last revision.

5 To be defined by polling technical experts.

Outcome measures ^6^ : | Time at which outcomes are measured
<48hrs | 3-7d | 7-14d | 14 d-3m | >3 m
Presence/absence of
pain | x | x | x | x | x
otorrhea | x | x | x | x | x
irritability | x | x | x | x | x
fever | x | x | x | x | x
anorexia | x | x | x | x | x
nausea (disequilibrium) | x | x | x | x | x
vomiting | x | x | x | x | x
diarrhea | x | x | x | x | x
Presence/absence of
limited or absent mobility of TM | x | x | x | x | x
hearing deficit | | x | x | x | x
speech problem | | | | | x
Presence/absence of
recurrence of AOM | | | | x | x
Presence/absence of
acute suppurative complications/
secondary complications
mastoiditis | x | x | x | x | x
petrositis | x | x | x | x | x
acute suppurative labyrinthitis | x | x | x | x | x
extradural abscess | x | x | x | x | x
subdural abscess (empyema) | x | x | x | x | x
brain abscess | x | x | x | x | x
lateral sinus thrombosis | x | x | x | x | x
Presence/absence of
side/adverse effects from meds | x | x | x | x | x
Presence/absence of
resistant bacteria | x | x | x | x | x
Cost of care
direct cost | x | x | x | x | x
indirect cost | x | x | x | x | x
total cost | x | x | x | x | x
Quality of life | x | x | x | x | x

6 The outcome measures listed here define the scope of the project. The time point at which each outcome measure is considered relevant is marked by "x." This outcome-time matrix will be used as a guide for our evidence analysis in the context of the key questions.

Time period: | 1966- 1999
Literature source: | MEDLINE
Literature source: | EMBASE
Literature source: | HealthSTAR
Literature source: | CINAHL (nursing and allied paramedical professionals)
Literature source: | BIOSYS
Literature source: | Cochrane Database of Systematic Reviews
Literature source: | Database of Abstracts and Reviews of Effectiveness (English National Health Services Center for Reviews and Dissemination)
Literature source: | References of published articles
Language: | English and Foreign languages
Study design: | Randomized controlled trials, blinded and unblinded
Study design: | Non-randomized controlled trials, blinded and unblinded
Study design: | Prospective cohort studies (for observation/No treatment)
Study design: | Retrospective cohort studies (for observation/no treatment)
Study design: | Case-control studies

III. Revised Scope of the Evidence Report as of February 24, 1999

Disease Entity: | Uncomplicated Acute Otitis Media ^1^
Disease Entity: | Exclude: patients with immunodeficiencies and craniofacial deficiencies including cleft palate
Patient Population: | Age 4 weeks to 18 years
Setting: | All types of providers and practice settings
Intervention: | Observation/no intervention/natural history/placebo ^2^
Intervention: | Antibiotic treatment (all classes, schedule, dosage, length, and mode) ^3^
Influencing factors ^4^ : | Demographic
Influencing factors ^4^ : | Age of child
Influencing factors ^4^ : | Gender
Influencing factors ^4^ : | Ethnicity/race
Influencing factors ^4^ : | Environmental
Influencing factors ^4^ : | Presence of sibling(s)
Influencing factors ^4^ : | Attendance at day care center
Influencing factors ^4^ : | Sibling(s) in day care center
Influencing factors ^4^ : | Feeding mode-bottle vs. breast
Influencing factors ^4^ : | Pacifier use
Influencing factors ^4^ : | Tobacco smoke exposure
Influencing factors ^4^ : | History and/or presence of ear infections in parents or siblings
Influencing factors ^4^ : | Season of the year
Influencing factors ^4^ : | Symptoms by history
Influencing factors ^4^ : | Otalgia and severity
Influencing factors ^4^ : | Hearing deficit and severity
Influencing factors ^4^ : | Signs/Physical findings
Influencing factors ^4^ : | Pulling of ear in an infant
Influencing factors ^4^ : | Otorrhea
Influencing factors ^4^ : | Irritability
Influencing factors ^4^ : | Fever
Influencing factors ^4^ : | Hearing loss
Influencing factors ^4^ : | Tympanic membrane (TM) inflammation
Influencing factors ^4^ : | Retracted TM
Influencing factors ^4^ : | Purulent otorrhea
Influencing factors ^4^ : | Middle ear effusion
Influencing factors ^4^ : | Other clinical factors
Influencing factors ^4^ : | Otitis prone ^5^ (prior history of recurrent AOM/multiple previous episodes)
Influencing factors ^4^ : | Underlying predisposing problem (viral infection)
Influencing factors ^4^ : | Prior antibiotic use and when used
Influencing factors ^4^ : | Concurrent use of analgesics
Influencing factors ^4^ : | Prior hearing deficit
Influencing factors ^4^ : | Inability to express symptoms
Influencing factors ^4^ : | Atopy or allergy
Influencing factors ^4^ : | Presence of tube
Influencing factors ^4^ : | Parent/caretaker
Influencing factors ^4^ : | Parent/caretaker availability
Influencing factors ^4^ : | Parent/caretaker preference
Influencing factors ^4^ : | Parent/caretaker education
Influencing factors ^4^ : | Examiner
Influencing factors ^4^ : | Type of examiner (family physician, otolaryngologist, pediatrician, nurse practitioner, physician assistant, etc.)
Influencing factors ^4^ : | Skill to diagnose (validated examiner/observer)
Influencing factors ^4^ : | Setting (public, private, PPO, HMO, etc.)
Influencing factors ^4^ : | Monitoring during episode or course of therapy
Influencing factors ^4^ : | When
Influencing factors ^4^ : | Frequency (none, daily, every other day)
Influencing factors ^4^ : | Primary person (parent or provider)
Influencing factors ^4^ : | Type (tympanometry, acoustic reflectometry, pneumatic otoscopy)
Influencing factors ^4^ : | Cost
Influencing factors ^4^ : | Cost of treatment

1 Acute otitis media is defined as 1) presence of middle ear effusion as demonstrated by the actual presence of fluid in the middle ear as diagnosed by tympanocentesis or the physical presence of liquid in the external ear canal as a result of tympanic membrane perforation or indicated by limited or absent mobility of the tympanic membrane, excluding the retracted tympanic membrane, as diagnosed by pneumatic otoscopy, tympanogram, or acoustic reflectometry with or without the following: a) opacification, not including erythema, b) a full or bulging tympanic membrane, or c) hearing loss, and 2) rapid onset (over the course of 48 hours) or 3) one or more of the following signs or symptoms: 1) otalgia (or pulling of ear in an infant), b) otorrhea, c) irritability in the infant or toddler^2^, or fever^2^with or without anorexia, nausea, vomiting, or diarrhea. (Rapid onset is defined as less-than or equal to 48 hours from the onset of acute signs or symptoms first noted by the parent or guardian to contact with the health system. ^2^Irritability in the infant or toddler and fever must be associated with either otalgia or otorrhea to fulfill criteria 3.) Uncomplicated AOM is defined as AOM limited to the middle ear cleft. The issue of the role acoustic reflectometry as a legitimate diagnostic tool for the establishment of middle ear effusion is not resolved.

2 Observational treatment or no intervention is defined as initial management of the disease WITHOUT antibiotic treatment with or without a monitoring protocol. Placebo treatment is defined as initial management of the disease with a placebo in place of antibiotics in randomized controlled trials. Natural history is defined as the natural course of the disease without any intervention by provider or parent.

3 For Question 3 all antibiotic regimens are aggregated, and for Question 4 the antibiotic regimens are specified as per the subquestions.

4 An influencing factor is defined as a characteristic of the patient or the environment or the health care delivery system that may affect the natural history of the disease or the outcome(s) of the intervention of interest.

5 The otitis-prone child is defined as the child who has had three episodes of AOM in a 6-month period or four episodes of AOM in a 12-month period. The episodes of AOM should be well-documented. Each episode of AOM should preferably have been separated by at least 4 weeks from the previous episode of AOM and treatment course or documented on followup to have cleared.

Outcome Measures ^6^ : | Time at which outcomes are measured
<48hrs | 3-7d | 7-14 d | 14d-3m | >3m
Presence/absence of
pain. | x | x | x | x | x
otorrhea | x | x | x | x | x
irritability | x | x | x | x | x
fever | x | x | x | x | x
anorexia | x | x | x | x | x
nausea (disequilibrium) | x | x | x | x | x
vomiting | x | x | x | x | x
diarrhea | x | x | x | x | x
Presence/absence of
limited or absent mobility of TM | x | x | x | x | x
hearing deficit | | x | x | x | x
speech problem | | | | | x
Presence/absence of
recurrence of AOM | | | | x | x
Presence/absence of
acute suppurative complications/
secondary complications
mastoiditis | x | x | x | x | x
petrositis | x | x | x | x | x
acute suppurative labyrinthitis | x | x | x | x | x
extradural abscess | x | x | x | x | x
subdural abscess (empyema) | x | x | x | x | x
brain abscess | x | x | x | x | x
lateral sinus thrombosis | x | x | x | x | x
Presence/absence of
side/adverse effects from meds | x | x | x | x | x
Presence/absence of
resistant bacteria | x | x | x | x | x
Cost of care
direct cost | x | x | x | x | x
indirect cost | x | x | x | x | x
total cost | x | x | x | x | x
Quality of life | x | x | x | x | x

6 The outcome measures listed here define the scope of the project. The time point at which each outcome measure is considered relevant is marked by "x." This outcome-time matrix will be used as a guide for our evidence analysis in the context of the key questions.

Time Period: | 1966- 1998
Literature Source: | MEDLINE
Literature Source: | EMBASE
Literature Source: | HealthSTAR
Literature Source: | CINAHL (nursing and allied paramedical professionals)
Literature Source: | BIOSYS
Literature Source: | Cochrane Database of Systematic Reviews
Literature Source: | Database of Abstracts and Reviews of Effectiveness (English National Health Services Center for Reviews and Dissemination)
Literature Source: | References of published articles
Language: | English and foreign languages
Study Design: | Randomized controlled trials, blinded and unblinded
Study Design: | Non-randomized controlled trials, blinded and unblinded
Study Design: | Prospective cohort studies (for observation/no treatment)
Study Design: | Retrospective cohort studies (for observation/no treatment)
Study Design: | Case-control studies

IV. Final Version of Scope of the Evidence Report, Revised as of March 26, 1999

Disease Entity: | Uncomplicated Acute Otitis Media ^1^
Disease Entity: | Exclude: patients with immunodeficiencies and craniofacial deficiencies including cleft palate
Patient Population: | Age 4 weeks to 18 years
Setting: | All types of providers and practice settings
Intervention: | Observation/no intervention/natural history/placebo ^2^
Intervention: | Antibiotic treatment (all classes, schedule, dosage, length, and mode) ^3^
Influencing factors ^4^ : | Demographic
Influencing factors ^4^ : | Age of child
Influencing factors ^4^ : | Gender
Influencing factors ^4^ : | Ethnicity/race
Influencing factors ^4^ : | Environmental
Influencing factors ^4^ : | Presence of sibling(s)
Influencing factors ^4^ : | Attendance at day care center
Influencing factors ^4^ : | Sibling(s) in day care center
Influencing factors ^4^ : | Feeding mode-bottle vs. breast
Influencing factors ^4^ : | Pacifier use
Influencing factors ^4^ : | Tobacco smoke exposure
Influencing factors ^4^ : | History and/or presence of ear infections in parents or siblings
Influencing factors ^4^ : | Season of the year
Influencing factors ^4^ : | Symptoms by history
Influencing factors ^4^ : | Otalgia and severity
Influencing factors ^4^ : | Hearing deficit and severity
Influencing factors ^4^ : | Signs/physical findings
Influencing factors ^4^ : | Pulling of ear in an infant
Influencing factors ^4^ : | Otorrhea
Influencing factors ^4^ : | Irritability
Influencing factors ^4^ : | Fever
Influencing factors ^4^ : | Hearing loss
Influencing factors ^4^ : | Tympanic membrane (TM) inflammation
Influencing factors ^4^ : | Retracted TM
Influencing factors ^4^ : | Purulent otorrhea
Influencing factors ^4^ : | Middle ear effusion
Influencing factors ^4^ : | Other clinical factors
Influencing factors ^4^ : | Otitis prone ^5^ (prior history of recurrent AOM/multiple previous episodes)
Influencing factors ^4^ : | Underlying predisposing problem (viral infection)
Influencing factors ^4^ : | Prior antibiotic use and when used
Influencing factors ^4^ : | Concurrent use of analgesics/antipyretic/antihistamines/decongestants/ear or nose drops
Influencing factors ^4^ : | Prior hearing deficit
Influencing factors ^4^ : | Inability to express symptoms
Influencing factors ^4^ : | Atopy or allergy
Influencing factors ^4^ : | Presence of tube
Influencing factors ^4^ : | Parent/caretaker
Influencing factors ^4^ : | Parent/caretaker availability
Influencing factors ^4^ : | Parent/caretaker preference
Influencing factors ^4^ : | Parent/caretaker education
Influencing factors ^4^ : | Examiner
Influencing factors ^4^ : | Type of examiner (family physician, otolaryngologist, pediatrician, nurse practitioner, physician assistant, etc.)
Influencing factors ^4^ : | Skill to diagnose (validated examiner/observer)
Influencing factors ^4^ : | Setting (public, private, PPO, HMO, etc.)
Influencing factors ^4^ : | Monitoring during episode or course of therapy
Influencing factors ^4^ : | When
Influencing factors ^4^ : | Frequency (none, daily, every other day)
Influencing factors ^4^ : | Primary person (parent or provider)
Influencing factors ^4^ : | Type (tympanometry, acoustic reflectometry, pneumatic otoscopy)
Influencing factors ^4^ : | Cost
Influencing factors ^4^ : | Cost of treatment

1 Acute otitis media is defined as 1) presence of middle ear effusion as demonstrated by the actual presence of fluid in the middle ear as diagnosed by tympanocentesis or the physical presence of liquid in the external ear canal as a result of tympanic membrane perforation or indicated by limited or absent mobility of the tympanic membrane, as diagnosed by pneumatic otoscopy, tympanogram, or acoustic reflectometry with or without the following: a) opacification, not including erythema, b) a full or bulging tympanic membrane, or c) hearing loss AND 2) rapid onset (over the course of 48 hours) or 3) one or more of the following signs or symptoms: 1) otalgia (or pulling of ear in an infant), b) otorrhea, c) irritability in the infant or toddler, d) fever with or without anorexia, nausea or vomiting. (Rapid onset is defined as less-than or equal to 48 hours from the onset of acute signs or symptoms first noted by the parent or guardian to contact with the health system.) Uncomplicated AOM is defined as AOM limited to the middle ear cleft.

2 Observational treatment or no intervention is defined as initial management of the disease WITHOUT any active intervention (pharmacologic or surgical) other than topical or systemic medications (that do not contain antibiotics) given for symptomatic relief (e.g., analgesics, antipyretics, antihistamines, decongestants, ear or nose drops), with or without a monitoring protocol. Placebo treatment is defined as initial management of the disease with a placebo in place of antibiotics in randomized controlled trials. Natural history is defined as the natural course of the disease without any intervention by provider or parent.

3 For Question 3 all antibiotic regimens are aggregated, and for Question 4 the antibiotic regimens are specified as per the subquestions.

4 An influencing factor is defined as a characteristic of the patient or the environment or the health care delivery system that may affect the natural history of the disease or the outcome(s) of the intervention of interest.

5 The otitis-prone child is defined as the child who has had three or more episodes of AOM in a 6-month period or four or more episodes of acute otitis media in a 12-month period. The episodes of AOM should be well-documented. Each episode of AOM should preferably have been separated by at least 4 weeks from the previous episode of AOM and treatment course or documented on followup to have cleared.

Outcome Measures ^6^ : | Time at which outcomes are measured
<48hrs | 3-7d | 7-14 d | 14d-3m | >3m
Presence/absence of
pain | x | x | x | x | x
otorrhea | x | x | x | x | x
irritability | x | x | x | x | x
fever | x | x | x | x | x
anorexia | x | x | x | x | x
nausea (disequilibrium) | x | x | x | x | x
vomiting | x | x | x | x | x
diarrhea | x | x | x | x | x
Presence/absence of
limited or absent mobility of TM | x | x | x | x | x
hearing deficit | | x | x | x | x
speech problem | | | | | x
Presence/absence of
recurrence of AOM | | | | x | x
Presence/absence of
acute suppurative complication/
secondary complications
mastoiditis | x | x | x | x | x
petrositis | x | x | x | x | x
acute suppurative labyrinthitis | x | x | x | x | x
extradural abscess | x | x | x | x | x
subdural abscess (empyema) | x | x | x | x | x
brain abscess | x | x | x | x | x
lateral sinus thrombosis | x | x | x | x | x
Presence/absence of
side/adverse effects from meds | x | x | x | x | x
Presence/absence of
bacteria(sterile/nonsterile) | x | x | x | x | x
resistant bacteria | x | x | x | x | x
Cost of care
direct cost | x | x | x | x | x
indirect cost | x | x | x | x | x
total cost | x | x | x | x | x
Quality of life | x | x | x | x | x

6 The outcome measures listed here define the scope of the project. The time point at which each outcome measure is considered relevant is marked by "x." This outcome-time matrix will be used as a guide for our evidence analysis in the context of the key questions.

Time Period: | 1966- 1999 for database searches
Literature Source: | MEDLINE
Literature Source: | EMBASE
Literature Source: | HealthSTAR
Literature Source: | CINAHL (nursing and allied paramedical professionals)
Literature Source: | BIOSIS
Literature Source: | Cochrane Library
Literature Source: | International Pharmaceutical Abstracts
Literature Source: | References of published articles
Language: | English and foreign languages
Study Design: | Randomized controlled trials, blinded and unblinded
Study Design: | Nonrandomized controlled trials, blinded and unblinded
Study Design: | Prospective cohort studies (for observation/no treatment)
Study Design: | Retrospective cohort studies (for observation/no treatment)
Study Design: | Case-control studies