# Appendix D. Definitions of Acute Otitis Media

## I. Initial Proposed Definition of Acute Otitis Media, as of December 1, 1998

### Background

One of the tasks arising out of the second conference call on 12/1/98 was to establish a definition for the term acute otitis media. The following definition for acute otitis media is found in Bluestone and Klein (1996):

"Acute otitis media is the rapid onset of signs and symptoms of acute infection within the middle ear."

Bluestone and Klein (1996) further state:

"One or more local or systemic signs are present: otalgia (or pulling of the ear in the young infant), otorrhea, fever, recent onset of irritability, anorexia, vomiting, or diarrhea. The tympanic membrane is full or bulging, is opaque, and has limited or no mobility to pneumatic otoscopy -- indicative of middle-ear effusion."

Bluestone and Klein (1996) define middle ear effusion as follows:

"Middle-ear effusion is liquid in the middle ear."

Dr. Rosenfeld has previously suggested that the presence of middle ear effusion be a criterion for diagnosing acute otitis media. Dr. Marcy and Dr. Casselbrant suggested that vomiting and diarrhea not be included among the eligible local or systemic signs or symptoms for diagnosis of acute otitis media.

Dr. Marcy recommended the deletion of anorexia and the addition of hearing loss. Dr. Casselbrant suggested that the diagnosis be based on the presence of one sign and one symptom. Based on these recommendations, the following definition for acute otitis media is proposed:

### Proposed Definition

Acute otitis media is the

1. rapid onset of
2. signs of middle ear effusion and inflammation accompanied by
3. clinical findings which generally include one or more of the following:
  a. otalgia (or pulling of ear in an infant)
  b. otorrhea
  c. irritability
  d. fever
  e. hearing loss (older children)

## II. Revised Definition of Acute Otitis Media, as of February 1, 1999

Acute otitis media is defined as

1. presence of middle ear effusion as demonstrated by the actual presence of fluid in the middle ear as diagnosed by tympanocentesis or indicated by limited or absent mobility of the tympanic membrane as diagnosed by pneumatic otoscopy, tympanogram, or acoustic reflectometry with or without the following:
  a. opacification, not including erythema
  b. a full or bulging tympanic membrane
  c. hearing loss
  AND
2. rapid onset (over the course of 48 hours) OF
3. one or more of the following signs or symptoms:
  a. otalgia (or pulling of ear in an infant)
  b. otorrhea
  c. irritability in infant or toddler
  d. fever
  with or without anorexia, nausea, vomiting, or diarrhea.

### Rationale for the fourth revision

The changes were made based on input from technical and internal experts.

1. It appears that there has been confusion between creating a definition of AOM and creating criteria for diagnosing AOM. We need to do both. We need a definition to establish the criteria by which we feel AOM should be diagnosed. We will then use our criteria for diagnosing AOM to assess how closely the studies in our evidence analysis approximate our definition and each other. (See point 3 below.) Because the issue of the definition and diagnosis of AOM was not one of the key questions chosen by the technical expert panel for analysis, we will not do a formal evidence analysis of the criteria for diagnosis but will instead rely on the consensus of the technical expert panel.
2. We revised the definition as follows: The criteria for diagnosis should specify how middle ear effusion, rapid onset of clinical signs and symptoms, and clinical signs and symptoms are established.
  a. Most would agree that tympanocentesis is the gold standard for establishing the presence of fluid in the middle ear. The majority of the technical expert panel agreed with the decision to include limited or absent mobility of the tympanic membrane as a sign of middle ear effusion, and this decision is supported by the findings of a study by Karma, Penttila, Sipila, et al., 1989, and indirectly by the recommendation of the Otitis Media with Effusion Guidelines (Stool, Berg, Berman, et al., 1994a) to utilize pneumatic otoscopy as the primary means for diagnosing middle ear effusion. The technical expert panel also agreed to adding change from normal color and translucency as a sign of middle ear effusion, and one technical expert wanted to specify this finding to "red or white opacification" and to add "full or bulging tympanic membrane" as well. Erythema of the tympanic membrane, however, is not specific for AOM (Karma, Penttila, Sipila, et al., 1989). Cloudiness or opacification of the tympanic membrane, excluding erythema, and bulging of the tympanic membrane have been shown to be associated with middle ear effusion with and without the acute symptoms listed in criterion three (Karma, Penttila, Sipila, et al., 1989). Several of our technical experts pointed out that any signs or symptoms of middle ear effusion in criterion three, such as hearing loss, should more appropriately be placed in the first criterion. The technical experts were split, however, on whether to retain hearing loss in the definition. For this reason, hearing loss was moved into the first criterion as a non absolute finding because its presence would seem a confirmation of the presence of middle ear effusion that should be established by the more specific finding of middle ear fluid aspirated by tympanocentesis or limited or decreased mobility of the tympanic membrane.
  b. For rapid onset, the majority of the technical expert panel felt that rapid onset of symptoms would be within 48 hours.
  c. It is not clear from either the original definition in Bluestone and Klein, 1996, nor from any of the comments from the technical experts what specific information is being added by the clinical signs and symptoms in the third criterion. In Bluestone and Klein, 1996, there is reference to the signs and symptoms being indicative of inflammation in one part of the chapter and indicative of acute infection in another part of the chapter. Certainly an acute infection would lead to inflammation. On the other hand, can one assume that the presence of inflammation necessarily implies the presence of infection? The Otitis Media with Effusion Guidelines state that AOM is "inflammation of the middle ear with signs or symptoms of middle ear infection" (Stool, Berg, Berman, et al., 1994a) or "fluid in the middle ear accompanied by signs or symptoms of ear infection" (Stool, Berg, Berman, et al., 1994b) and that otitis media with effusion is "fluid in the middle ear without signs or symptoms of ear infection" (Stool, Berg, Berman, et al., 1994a). On the other hand, Rosenfeld (1996) states that the term "ear infection" "applies to AOM [acute otitis media] and OME [otitis media with effusion], because pathogenic bacteria generally are present in the middle ear with both conditions." It appears that the experts disagree whether the presence of infection is the distinguishing point between the two otitis media conditions that are perhaps the most common to be encountered, AOM and AME. If it were true that infection was not the distinguishing feature, another approach would be to use the clinical signs and symptoms to indicate severity of illness and establish a severity above which AOM is diagnosed and below which OME is diagnosed. For the purpose of this study, we will simply note this dilemma of criterion three and list those signs or symptoms that traditionally have been listed as being indicative of AOM. Because a majority of the technical expert panel feel that gastrointestinal findings such as anorexia, nausea, vomiting, and diarrhea should not be included in the list of clinical findings, they are no longer included in the signs and symptoms that would establish a diagnosis of AOM in conjunction with middle ear effusion. One technical expert did point out that nausea and vomiting, though immediate gastrointestinal symptoms, may be indicative of effects on the vestibular system; therefore, reference to gastrointestinal findings, as found in most traditional definitions of AOM, is retained in the present definition. The project staff also note that all the signs and symptoms in criterion three are observable, either objectively or subjectively, by the patient or guardian and, therefore, would help to establish the rapid onset required in criterion two.
3. The definition of AOM will be used to evaluate the appropriateness of the studies for our topic in the following way: "well defined" when the study used the same primary criteria as in our definition; "moderately defined" when the study used some but not all of the primary criteria as in our definition; "undefined" when the study did not use any of the criteria or did not specify any criteria used. We will categorize the studies according to these criteria and analyze them accordingly.

## III. Further Revision of Definition of Acute Otitis Media, as of March 3, 1999

Acute otitis media is defined as

1. presence of middle ear effusion as demonstrated by the actual presence of fluid in the middle ear as diagnosed by tympanocentesis or the physical presence of liquid in the external ear canal as a result of tympanic membrane perforation or indicated by limited or absent mobility of the tympanic membrane, excluding the retracted tympanic membrane, as diagnosed by pneumatic otoscopy, tympanogram, or acoustic reflectometry with or without the following:
  a. opacification, not including erythema
  b. a full or bulging tympanic membrane
  c. hearing loss
  AND
2. rapid onset (over the course of 48 hours ^1^ ) OF
  ^1^Rapid onset is defined as less than or equal to 48 hours from the onset of acute signs or symptoms first noted by the parent or guardian to contact with the health system.
3. one or more of the following signs or symptoms:
  a. otalgia (or pulling of ear in an infant)
  b. otorrhea
  c. irritability in the infant or toddler ^2^
    ^2^Irritability in the infant or toddler and fever must be associated with either otalgia or otorrhea to fulfill criteria 3.
  d. fever ^2^
  with or without anorexia, nausea, or vomiting.

### Rationale for the fifth revision

1. The majority of the technical expert panel felt that limited or absent mobility of the tympanic membrane in light of a retracted tympanic membrane was not indicative of fluid in the middle ear. In addition, the project staff recognized that in some cases of AOM tympanic membrane perforation may have occurred and neither tympanocentesis nor testing for tympanic membrane mobility would be possible. It was recognized that in those cases the presence of fluid in the external ear canal also would confirm the presence of a middle ear effusion.
2. 2. One of the technical experts felt, based on the 1994 Otitis Media with Effusion Guidelines, that acoustic reflectometry is not a valid diagnostic procedure to establish the presence of middle ear effusion. The project staff has determined that "The [OME] Panel judged the evidence in support of acoustic reflectometry to be insufficient to make a recommendation regarding use of this test in screening for or diagnosis of otitis media with effusion." (Stool, Berg, Berman, et al., 1994b) A recent publication, however, found that compared to the presence of middle ear effusion at time of surgery in a population with a 58% prevalence of middle ear effusion, acoustic reflectometry had a sensitivity of 95%, specificity of 31%, positive predictive value of 66%, and negative predictive value of 83% when the cutoff level was set at an angle of 95; and a sensitivity of 38%, specificity of 93%, positive predictive value of 88%, and a negative predictive value of 52% when the cutoff level was set at an angle of 49. (Barnett, Klein, Hawkins, et al., 1998) Barnett, Klein, Hawkins, et al. (1998) also found the comparable indices for tympanometry with a cutoff level of 0.2 compliance peak to be sensitivity 54%, specificity 75%, positive predictive value 78%, and negative predictive value 59%; and with a cutoff level of 0.1 compliance peak to be sensitivity 54%, specificity 84%, positive predictive value 82%, and negative predictive value 56%. Based on this study, it would seem appropriate to keep acoustic reflectometry as a viable diagnostic tool to establish the presence of middle ear effusion because it performed as well as tympanometry which the OME Guidelines panel had previously deemed an appropriate diagnostic tool.
3. The majority of the technical expert panel also felt that the 48-hour period of rapid onset was defined as the time from the onset of acute signs or symptoms first noted by the parent or guardian to contact with the health system.
4. One of the technical experts pointed out that the fourth revision of the definition would not work for the following case: "...a child with stable OME who develops febrile rotavirus diarrhea meets the definition (whether they have any of the...a, b, or c findings). I'm not sure how that can work." The project staff are in agreement with this assessment and also feel that irritability is nonspecific. The project staff is proposing that neither "irritability in the infant or toddler" nor "fever" can stand alone to meet criteria 3 but must exist in association with a sign or symptom directly referable to the ear, (i. e., otalgia or otorrhea).
5. The project staff have decided to delete reference to diarrhea from the definition because there is no apparent pathophysiologic connection between AOM and diarrhea as had been previously pointed out by many of the technical expert panel members.

## IV. Final Version of Definition of Acute Otitis Media, as of March 26, 1999

Acute otitis media is defined as

1. presence of middle ear effusion as demonstrated by the actual presence of fluid in the middle ear as diagnosed by tympanocentesis or the physical presence of liquid in the external ear canal as a result of tympanic membrane perforation or indicated by limited or absent mobility of the tympanic membrane as diagnosed by pneumatic otoscopy, tympanogram, or acoustic reflectometry with or without the following:
  a. opacification, not including erythema
  b. a full or bulging tympanic membrane
  c. hearing loss
  AND
2. rapid onset (over the course of 48 hours ^1^ ) OF
  ^1^Rapid onset is defined as less than or equal to 48 hours from the onset of acute signs or symptoms first noted by the parent or guardian to contact with the health system.
3. one or more of the following signs or symptoms:
  a. otalgia (or pulling of ear in an infant)
  b. otorrhea
  c. irritability in the infant or toddler
  d. fever
  with or without anorexia, nausea, or vomiting.

### Rationale for the sixth revision

1. During the 3/26/99 conference call, the technical expert panel agreed to delete the phrase "excluding the retracted tympanic membrane" from the fifth revision of the definition.
2. During the 3/26/99 conference call, the technical expert panel agreed to delete footnote 2 from the fifth revision of the definition. The experts felt that with the required presence of middle ear effusion, "irritability" and "fever" were both specific enough for criterion 3.
3. During the 3/26/99 conference call, the technical expert panel expressed the need for a "sound bite" definition of AOM. The project staff agrees that the complexity of the above definition lies in the embedding of criteria within the structure of the definition. The project staff proposes that the definition without embedded criteria is as follows: Acute otitis media is the presence of middle ear effusion in conjunction with the rapid onset of one or more signs or symptoms of inflammation of the middle ear.