# Appendix C. Key Questions

## I. Initial Set of Three Key Questions as of December 18, 1998

### Question 1: On the Observational or No Treatment or Natural History of AOM

a. During an episode of uncomplicated acute otitis media (AOM) that is initially managed WITHOUT antibiotics, what proportion of children have the following outcomes:
  1. presence/absence of pain/otorrhea/irritability/fever/hearing loss at 24 hours, 2-3 days, and 4-7 days?
  2. presence/absence of ALL clinical signs/symptoms, except middle ear effusion (MEE), at 7-14 days?
  3. presence/absence of asymptomatic MEE at 2 weeks, 1 month, and at 3 months?
  4. presence/absence of acute suppurative complications/secondary complications?
b. To what degree are the above outcomes attributable to:
  1. clinical characteristics including hearing and/or speech delay?
  2. age of the child?
  3. provider degree of diagnostic uncertainty for true AOM?
  4. parent reliability (low vs. high) to report symptom resolution or progression at 48-72 hours if antibiotics are initially withheld?
  5. parent preference concerning antibiotic therapy?
  6. parent education?
  7. analgesic use?

### Question 3: On Antibiotic Treatment of AOM

a. Are antibiotics effective (in terms of statistical significance and magnitude of absolute clinical benefit above and beyond placebo/observational/no treatment/natural history) in the initial treatment of uncomplicated AOM with respect to the following outcome indicators:
  1. presence/absence of pain/otorrhea/irritability/fever/hearing loss at 24 hours, 2-3 days, and 4-7 days?
  2. presence/absence of ALL clinical signs/symptoms, except MEE, at 7-14 days?
  3. presence/absence of asymptomatic MEE at 2 weeks, 1 month, and at 3 months?
  4. presence/absence of acute suppurative complications/secondary complications?
b. When antibiotics are used in the initial treatment of uncomplicated AOM, which of the following characteristics are associated with better outcomes compared to placebo/observational/no treatment/natural history?
  1. clinical characteristics including hearing and/or speech delay?
  2. age of the child?
  3. provider degree of diagnostic uncertainty for true AOM?
  4. parent reliability (low vs. high) to report symptom resolution or progression at 48-72 hours if antibiotics are initially withheld?
  5. parent preference concerning antibiotic therapy?
  6. parent education?
  7. analgesic use?

### Question 4: On Antibiotic Regimen for AOM

Does the specific antibiotic regimen make a difference? (Antibiotic class) Are antibiotics with broader coverage than amoxicillin or trimethoprim sulfa more cost-effective or cost-beneficial in the initial treatment of uncomplicated AOM?

a. (Antibiotic class) What is the utility of oral fluoroquinolones in the initial treatment of uncomplicated AOM in childhood? What are the side effects?
b. (Dose of antibiotic) What is the value of using 60-80 mg/kg/dof amoxicillin or amoxicillin-clavulanate vs. the standard 40 mg/kg/d?
c. (Schedule of antibiotic) Is twice a day high dose amoxicillin therapy as effective as three time a day amoxicillin therapy in the initial treatment of uncomplicated AOM?
d. (Length of treatment) What is the comparative efficacy of short- vs. long-term antibiotic
e. therapy in children younger than 2 years of age and those older than 2 years of age? Is the use of a single injection of ceftriaxone or the use of other cephalosporin for treatment of AOM more or less likely than 7-10 days of oral amoxicillin to predispose to creation of a penicillin/cephalosporin resistant pneumococcal nasopharyngeal flora? Does the risk benefit justify the use of a single injection of ceftriaxone? (Need discussion)

#### Changes Made and Rationale

1. Several of the technical experts felt that Question 1 should be split into outcome and influencing factor questions like Question 3.
2. One issue brought up during the second conference call related to the difference between "natural history of acute otitis media when nothing is done including not seeking care from the health care provider" and "observational treatment prescribed by the health care provider." We decided that the issue brought up an important point and Question 1 was retitled to address the latter.
3. Another issue brought up was on the real objective of Question 3b. Are we addressing the amount of influence of the listed factors on the "selective initial use of antibiotics" or on the "effectiveness of the initial use of antibiotics." The former is an analysis of the prescribing pattern which is a process variable and the latter is an analysis of the effectiveness of initial use of antibiotics which is an outcome variable. Our project team decided to address the influence of the factors on the effectiveness of initial use of antibiotics and leave it up to users of our evidence report to develop guidelines for appropriate prescribing patterns. Question 3b) was thus reworded accordingly.
4. On the issue of defining uncomplicated AOM, there were several suggestions, ranging from "inflammation of the middle ear cleft" to "one sign and one symptom" to "definitions used by the different studies." The project team decided that a definition must be established before the study could go on because it would affect the search strategy. A poll will be taken among the experts as to the best definition to use for this evidence report. For the evidence analysis, several of the technical experts felt that we may have to accept whatever definition of AOM is found in any given study as they will be quite disparate; however, the project staff feel it is important to establish a standard definition for comparison.
5. Another issue brought up was on some subquestions in Question 4 that addressed more toward complicated AOM rather than uncomplicated AOM. The two specific ones are 4b) Would antibiotic selection based on local or regional bacterial resistance pattern improve the outcome of antibiotic treatment of AOM? and 4h) How long after an antibiotic is used is it reasonable for it to be used again to treat AOM in terms of reducing the likelihood of developing resistance to antibiotics? These two subquestions were thus excluded from the scope of this evidence report.
6. An issue on defining endpoints for the study was brought up. The group decided to leave them open to definitions used by different studies. However, the project staff decided that it is important to define the most appropriate endpoints before the literature search and then compare what the literature used with our definitions.
7. Another issue was on the age of the child to be included in the evidence report. It was suggested by some of the technical experts to exclude the neonate as defined by an age of younger than 8 weeks. Epidemiologically, a neonate is referred to as a newborn 28 days old or younger. For this evidence report we will include studies on children between 28 days and 18 years old.
8. Several factors were added as influencing factors: gender, ethnicity, presence of ear infection in sibling, craniofacial problems, and cost. In addition, the project staff, based on information in Attachment 4.b-1, added race, sibling(s) in day care, pacifier use, presence of sibling(s), and atopy or allergy. They are included in the scope of the evidence report.

## II. Revised Key Questions as of January 25, 1999

### Question 1: On the Observational or No Treatment or Natural History of AOM

a. During an episode of uncomplicated acute otitis media (AOM) that is initially managed WITHOUT any intervention, what proportion of children have the outcomes delineated in the scope of the evidence report?
b. To what degree are the above outcomes attributable to the influencing factors delineated in the scope of the evidence report?

### Question 3: On Antibiotic Treatment of AOM

a. Are antibiotics effective (in terms of statistical significance and magnitude of absolute clinical benefit above and beyond placebo/observational/no treatment/natural history) in the initial treatment of uncomplicated AOM with respect to the outcomes delineated in the Scope of the Evidence Report?
b. When antibiotics are used in the initial treatment of uncomplicated AOM, which of the influencing factors delineated in the scope of the evidence report are associated with better outcomes compared to placebo/observational/no treatment/natural history?

### Question 4: On Antibiotic Regimen for AOM

Does the specific antibiotic regimen make a difference?

(Antibiotic class) Is treatment with antibiotics of broader coverage than amoxicillin or trimethoprim sulfa more effective or result in less total cost in the initial treatment of uncomplicated AOM?

a. (Antibiotic class) What is the utility of oral fluoroquinolones in the initial treatment of uncomplicated AOM in childhood? What are the side effects?
b. (Dose of antibiotic) What is the value of using 60-80 mg/kg/d of amoxicillin or amoxicillin-clavulanate vs. the standard 40 mg/kg/d?
c. (Schedule of antibiotic) Is twice a day high-dose amoxicillin therapy as effective as three time a day amoxicillin therapy in the initial treatment of AOM?
d. (Length of treatment) What is the comparative effectiveness of short- vs. long-term antibiotic therapy in children younger than 2 years of age and those older than 2 years of age?

#### Rationale for Changes Made Since 12/23/98 and Other Issues

1. The original intent of Question 1, which was to study the natural history of AOM, implies that the clinical course is to be observed "WITHOUT any intervention" and not "WITHOUT antibiotics," which does not exclude the possibility of other interventions.
2. In Question 1, none of the children will be taking antibiotics; so, parent preference concerning antibiotic therapy should not have any influence on the outcomes. One of the technical experts also felt this factor should be removed from Question 1. One would expect that parent preference concerning antibiotic therapy might be important when antibiotics are being administered and parental compliance with therapeutic recommendations is necessary to complete the treatment as in Question 3.
3. The term "initial treatment" was not changed; however, the project staff feel that the technical experts must state whether or not "initial treatment" refers to the first course of treatment for an independent episode of uncomplicated AOM. If so, the technical experts must then define what is meant by an independent episode: is it an episode of uncomplicated AOM that is preceded by at least a 3-week period without AOM?
4. The project staff added side effects and adverse events attributable to antibiotics to the outcomes in Question 3.
5. For clarity, we refer to the outcomes and influencing factors listed in the scope of the evidence report as being our a priori subquestions of interest. In addition, our economic experts have pointed out that longer-term outcomes, for example greater than 3 months, need to be added, and these have already been added to the scope of the evidence analysis.
6. It was felt by many of the technical and internal experts and project staff that we should study effectiveness and cost in this study and not cost-effectiveness or cost-benefit because of the lack of time in the 1-year timeframe of this contract to conduct such a detailed microeconomic analysis. Thus, all references to cost-effectiveness and cost-benefit have been changed to references to effectiveness and cost.
7. Although one of our technical experts pointed out that oral fluoroquinolones have not been approved by the Food and Drug Administration for use in the general populace, we have retained this question because research studies of this antibiotic may be available in the literature.
8. Any references to efficacy were changed to effectiveness because this study is interested in the impact on outcomes in the clinical setting.
9. Subquestion 4.f) was absorbed into subquestion 4.a). Subquestion 4.a) will address "antibiotics with broader coverage than amoxicillin or trimethoprim sulfa" which would include single-injection ceftriaxone and other cephalosporins. Subquestion 4.a) will look at bacterial resistance to antibiotics as an outcome as was the case in subquestion 4.f). This suggestion also had been made during the first conference call by one of the technical experts.

## Revised Key Questions as of Revised February 24, 1999

### Question 1: On the Observational or No Treatment or Natural History of AOM

a. During an episode of uncomplicated acute otitis media (AOM) that is initially managed WITHOUT any active intervention (pharmacologic or surgical) other than topical or systemic medications (that do not contain antibiotics) given for symptomatic relief, (e.g., analgesics, antipyretics, antihistamines, decongestants, ear or nose drops), what proportion of children have the outcomes delineated in the scope of the evidence report?
b. To what degree are the above outcomes attributable to the influencing factors delineated in the Scope of the Evidence Report?

### Question 3: On Antibiotic Treatment of AOM

a. Are antibiotics effective (in terms of statistical significance and magnitude of absolute clinical benefit above and beyond placebo/observational/no treatment/natural history) in the initial ^1^ treatment of uncomplicated AOM with respect to the outcomes delineated in the scope of the evidence report?
  1 An episode of uncomplicated AOM may be considered distinct from a previous episode of AOM and eligible for "initial" treatment if the most recent course of antibiotic ended 4 weeks prior to the episode of AOM in question or if there is documentation by an examiner that a prior episode of AOM has been cleared.
b. When antibiotics are used in the initial ^1^ treatment of uncomplicated AOM, which of the influencing factors delineated in the scope of the evidence report are associated with better outcomes compared to placebo/observational/no treatment/natural history?

### Question 4: On Antibiotic Regimen for AOM

Does the specific antibiotic regimen make a difference?

a. (Antibiotic class) Is treatment with antibiotics of broader coverage than amoxicillin or trimethoprim sulfa more effective or result in less total cost in the initial ^1^ treatment of uncomplicated AOM?
b. (Antibiotic class) What is the utility of oral fluoroquinolones in the initial ^1^ treatment of uncomplicated AOM in childhood? What are the side effects?
c. (Dose of antibiotic) What is the value of using 60-80 mg/kg/d of amoxicillin or amoxicillin-clavulanate vs. the standard 40 mg/kg/d in the initial ^1^ treatment of uncomplicated AOM?
d. (Schedule of antibiotic) Is twice a day high-dose amoxicillin therapy as effective as three times a day amoxicillin therapy in the initial ^1^ treatment of uncomplicated AOM?
e. (Length of treatment) What is the comparative effectiveness of short- vs. long-term antibiotic therapy in children younger than 2 years of age and those older than 2 years of age in the initial ^1^ treatment of uncomplicated AOM?

#### Rationale for changes made since 1/25/99

1. It was pointed out by one of the technical experts that unless we allowed studies that included children who had used "topical or systemic medications (that do not contain antibiotics) given for symptomatic relief (e.g., analgesics, antipyretics, antihistamines, decongestants, ear or nose drops)," we would have to "exclude nearly every published article from consideration." We have thus reworded Question 1 and will stratify in the analysis, if possible, to look at studies that truly have no intervention and those that included children who had used medications for symptomatic relief. Medications for symptomatic relief with commercial names in parentheses would include: (List is not exhaustive.) (From Physicians Desk Reference, 1998, Taketomo, 1999)
  a. analgesics: (See ear drops)
    1. acetaminophen (Anacin-3, Datril, Panadol, Tempra, Tylenol)
    2. ibuprofen (Advil, Motrin, PediaProfen)
  b. antipyretics:
    1. acetaminophen (Anacin-3, Datril, Panadol, Tempra, Tylenol)
    2. ibuprofen (Advil, Motrin, PediaProfen)
  c. antihistamines:
    1. astemizole (Hismanal)
    2. cetirizine hydrochloride (Zyrtec)
    3. chlorpheniramine maleate (Chlor-Trimeton)
    4. cyproheptadine hydrochloride (Periactin)
    5. dimenhydrinate (Dramamine)
    6. diphenhydramine (Benadryl)
    7. hydroxyzine (Atarax, Vistaril)
    8. loratadine (Claritin)
    9. meclizine hydrochloride (Antivert, Bonine)
    10. phenindamine tartrate (Nolahist)
    11. promethazine hydrochloride (Phenergan)
    12. terfenadine (Seldane)
  d. decongestants:
    1. phenylpropanolamine hydrochloride (Propagest)
    2. pseudoephedrine hydrochloride (Sudafed)
  e. antihistamine and/or decongestant combinations:
    1. acrivastine and pseudoephedrine hydrochloride (Semprex-D)
    2. azatadine maleate and pseudoephedrine sulfate (Trinalin)
    3. brompheniramine maleate and phenylpropanolamine hydrochloride (Dimetapp)
    4. brompheniramine maleate and pseudoephedrine hydrochloride (Bromfed, Bromfed-PD)
    5. chlorpheniramine maleate and pseudoephedrine hydrochloride (Atrohist Pediatric, Codimal-L.A., Codimal-L.A.-HALF, Fedahist Gyrocaps, Kronofed-A, Kronofed-A-Jr.)
    6. chlorpheniramine tannate and phenylephrine tannate and pyrilamine tannate (Atrohist)
    7. phenindamine tartrate and chlorpheniramine maleate and phenylpropanolamine hydrochloride (Nolamine)
    8. promethazine and phenylephrine (Phenergan VC)
    9. triprolidine hydrochloride and pseudoephedrine hydrochloride (Actifed)
  f. otic preparations:
    1. includes analgesic/local anesthestic
      a. antipyrine (cerumenolytic) and benzocaine (Aurafair, Auralgan, Auroto)
      b. benzocaine (Americaine Otic)
      c. phenylephrine hydrochloride (decongestant) and benzocaine (Tympagesic Otic Solution)
    2. includes steroid
      a. dexamethasone sodium phosphate (Decadron Phosphate)
      b. hydrocortisone and acetic acid in propylene glycol vehicle (VoSoL HC)
    3. non-antibiotic antimicrobial
      a. acetic acid in aqueous aluminum acetate otic solution (Otic Domeboro)
      b. acetic acid in propylene glycol vehicle (VoSoL)
    4. cerumenolytic
      a. carbamide peroxide (Debrox, Gly-Oxide)
      b. triethanolamine polypeptide oleate-condensate (Cerumenex)
  g. nasal preparations:
    1. antihistamines or decongestants
      a. azelastine hydrochloride (Astelin)
      b. naphazoline hydrochloride (AK-Con, Albalon, Liquifilm, Naphcon, Naphcon Forte, Vasocon Regular)
      c. oxymetazoline hydrochloride (Afrin)
      d. phenylephrine hydrochloride (Neo-Synephrine)
    2. steroids
      a. beclomethasone diproprionate (Beconase, Beconase AQ, Vancenase, Vancenase AQ, Vancenase AQ 84 mcg)
      b. budesonide (Rhinocort)
      c. dexamethasone sodium phosphate (Dexacort Phosphate)
      d. flunisolide (Nasalide, Nasarel)
      e. fluticasone proprionate (Flonase)
      f. triamcinolone Acetomide (Nasacort, Nasacort AQ)
2. The phrase "in the initial ^1^ treatment of uncomplicated AOM" was inadvertently omitted from questions 4. c) and 4. e) and has been added.
  1 An episode of uncomplicated AOM may be considered distinct from a previous episode of AOM and eligible for "initial" treatment if the most recent course of antibiotic ended 4 weeks prior to the episode of AOM in question or if there is documentation by an examiner that a prior episode of AOM has been cleared.
3. The majority of the technical experts felt that an episode of uncomplicated AOM may be considered distinct from a previous episode of AOM and eligible for "initial" treatment if the most recent course of antibiotic ended 4 weeks prior to the episode of AOM in question or if there is documentation by an examiner that a prior episode of AOM has been cleared.

## IV. Final Version of Key Questions for Task Order, Revised March 26, 1999

### Question 1: On the Observational or No Treatment or Natural History of AOM

a. During an episode of uncomplicated acute otitis media (AOM) that is initially managed WITHOUT any active intervention (pharmacologic or surgical) other than topical or systemic medications (that do not contain antibiotics) given for symptomatic relief, (e.g)., analgesics, antipyretics, antihistamines, decongestants, ear or nose drops), what proportion of children have the outcomes delineated in the scope of the evidence report?
b. To what degree are the above outcomes attributable to the influencing factors delineated in the scope of the evidence report?

### Question 3: On Antibiotic Treatment of AOM

a. Are antibiotics effective (in terms of statistical significance and magnitude of absolute clinical benefit above and beyond placebo/observational/no treatment/natural history) in the initial ^1^ treatment of uncomplicated AOM with respect to the outcomes delineated in the scope of the evidence report?
b. When antibiotics are used in the initial ^1^ treatment of uncomplicated AOM, which of the influencing factors delineated in the scope of the evidence report are associated with better outcomes compared to placebo/observational/no treatment/natural history?

### Question 4: On Antibiotic Regimen for AOM

Does the specific antibiotic regimen make a difference?

a. (Antibiotic class) Is treatment with antibiotics other than amoxicillin or trimethoprim sulfa more effective or result in less total cost in the initial ^1^ treatment of uncomplicated AOM?
b. (Antibiotic class) What is the utility of oral fluoroquinolones in the initial ^1^ treatment of uncomplicated AOM in childhood? What are the side effects?
c. (Dose of antibiotic) What is the value of using > 60 mg/kg/d of amoxicillin or amoxicillin-clavulanate vs. the standard 40 mg/kg/d in the initial ^1^ treatment of uncomplicated AOM?
d. (Schedule of antibiotic) Is twice a day high-dose amoxicillin therapy as effective as three times a day amoxicillin therapy in the initial ^1^ treatment of uncomplicated AOM?
e. (Length of treatment) What is the comparative effectiveness of short- vs. long-term antibiotic therapy in children younger than 2 years of age and those older than 2 years of age in the initial ^1^ treatment of uncomplicated AOM?

#### Rationale for changes made since 2/24/99

1. During the 3/26/99 conference call, the technical expert panel agreed to replace the phrase "of broader coverage" in the 2/24/99 version with the word "other."
2. During the 3/26/99 conference call, the technical expert panel agreed to change the dosage "60-80 mg/kg/d" in the 2/24/99 version with "> 60 mg/kg/d."