# Appendix B. Conceptual Framework For Management Of Acute Otitis Media

1. The patient presents, either in the office or by phone, with ear pain or some other symptom suggesting otitis media, type unspecified. At this point, the practitioner does not know with absolute certainty if the patient has:
  a. a diagnosis other than otitis media
  b. otitis media with effusion
  c. acute otitis media
  d. otitis media without effusion (i.e., myringitis)
  e. otitis media with another diagnosis
2. The practitioner must have in mind definitions for diagnosing:
  a. a diagnosis other than otitis media
  b. otitis media with effusion
  c. acute otitis media
  d. otitis media without effusion (i.e., myringitis)
  e. otitis media with another diagnosis The definitions may be correct or incorrect.
3. The practitioner must gather appropriate information:
  a. history
  b. physical examination (e.g., pneumootoscopy)
  c. diagnostic tests (e.g., tympanogram, tympanocentesis, acoustic reflectometry, audiogram) The practitioner may gather the correct or incorrect information.
4. The practitioner must use the information gathered to make a diagnosis of:
  a. a diagnosis other than otitis media
  b. otitis media with effusion
  c. acute otitis media
  d. otitis media without effusion (i.e., myringitis)
  e. otitis media with another diagnosis The diagnosis may be correct or incorrect
5. Once a diagnosis of acute otitis media is made, the practitioner must choose a therapeutic option:
  a. observation and no intervention
  b. antibiotics
    1. which antibiotic
    2. dose of antibiotic
    3. schedule of antibiotics
    4. length of treatment
  c. steroids
  d. analgesics
  e. antihistamines/decongestants
  f. tympanostomy
  g. any combination of 5.b.-5.f. The therapeutic option chosen may be correct or incorrect. ^1^
    1 Many factors other than the treatment option prescribed and the followup strategy chosen may affect the outcome:
    1. patient characteristics such as
      a. age
      b. genetic factors (e.g., predisposition in certain genetic conditions such as Down syndrome or possibly familial factors)
      c. comorbid conditions, such as cleft palate and other craniofacial anomalies and certain immunodeficiency syndromes
    2. parent characteristics such as compliance with recommendations
    3. environmental factors such as second hand smoke, hygienic measures
    4. provider practice characteristics
    5. organizational restraints
    6. et cetera
6. After implementing a therapeutic option, the practitioner must prescribe a followup strategy:
  a. followup
    1. length of time after initiation or end of treatment
    2. number of followups
    3. intervals between followups if more than one
  b. no followup The practitioner must have in mind criteria for the need for recheck and followup that may be correct or incorrect; the followup strategy chosen may itself be correct or incorrect. ^1^ , ^2^
    2 At any point after the first therapeutic intervention, the outcomes may be assessed:
    1. hearing acuity
    2. speech development
    3. complications such as mastoiditis
    4. social interactions
    5. family function
    6. cost
    7. et cetera The outcome assessment depends on the time at which the assessment is made and on the viewpoint taken (i.e., the patient, the family, the practitioner, the health plan, society). Cost-effectiveness is the ultimate outcome.
7. At followup, the practitioner must have in mind definitions for:
  a. successful treatment of acute otitis media
  b. unsuccessful treatment of acute otitis media
    1. persistent
    2. recurrent
    3. complications such as mastoiditis
    The definitions may be correct or incorrect.
8. At followup, the practitioner must gather appropriate information:
  a. history (e.g., prior infection)
  b. physical examination (e.g., pneumootoscopy)
  c. diagnostic tests (e.g., tympanogram, acoustic reflectometry, tympanocentesis, audiogram) The practitioner may gather the correct or incorrect information.
9. At followup, the practitioner must use the information gathered to make a diagnosis of:
  a. successful treatment
  b. unsuccessful treatment
    1. persistent
    2. recurrent
    3. complications such as mastoiditis
    The diagnosis may be correct or incorrect.
10. At followup, the practitioner must then decide if further treatment is needed.
  a. If diagnosed as successful treatment, various treatment options may be considered:
    1. observation and no intervention
    2. prophylactic antibiotics
      a. which antibiotic
      b. dose of antibiotic
      c. schedule of antibiotics
      d. length of treatment
    3. refer to Otolaryngology for consideration of:
      a. pressure equalizing tubes
      b. adenoidectomy
      c. tonsillectomy
    4. refer to Hearing and Speech
      a. hearing evaluation
      b. speech evaluation and/or treatment
    5. any combination of 10.a.2)-10.a.4)
  b. If diagnosed as unsuccessful treatment, various treatment options may be considered:
    1. observation and no intervention
    2. antibiotics
      a. which antibiotic
      b. dose of antibiotic
      c. schedule of antibiotics
      d. length of treatment
    3. steroids
    4. analgesics
    5. antihistamines/decongestants
    6. tympanostomy
    7. refer to Otolaryngology for consideration of:
      a. pressure equalizing tubes
      b. adenoidectomy
      c. tonsillectomy
      d. mastoidectomy
    8. refer to Hearing and Speech
      c) | hearing evaluation
      d) | speech evaluation and/or treatment
    9. treatment of complications, such as mastoiditis
    10. any combination of 10.b.2)-10.b.9)
    The treatment chosen may be correct or incorrect. ^1^
11. After follow-up and implementation of a therapeutic option, the practitioner must prescribe a followup strategy:
  a. follow-up
    1. length of time after initiation or end of treatment
    2. number of followups
    3. intervals between followups if more than one
    4. go to 7 ^3^
      3 The cycle of care 7-11 may be repeated one or more times and for each cycle of care the practitioner may decide upon the same or a different combination of diagnostic evaluation, therapeutic option, and followup strategy. The choice of what data to gather and which therapeutic option and followup strategy to implement in a particular cycle of care may be affected by various factors:
      1. patient characteristics, such as
        a. age
        b. speech level
        c. hearing acuity status
        d. frequency and/or severity of previous episodes of otitis media
        e. persistence of infection
        f. presence of other middle ear findings such as tympanic membrane perforation, cholesteatoma, et cetera
        g. antibiotic usage history
        h. genetic factors (e.g., predisposition in certain genetic conditions such as Down syndrome or possibly familial factors)
        i. comorbid conditions such as cleft palate and other craniofacial anomalies and certain immunodeficiency syndromes
      2. parent characteristics such as compliance with recommendations and process and outcome preferences
      3. environmental factors such as second hand smoke, day care setting, and hygienic measures
      4. provider practice characteristics
      5. organizational restraints
  b. no followup The practitioner must have in mind criteria for the need for recheck and followup that may be correct or incorrect; the followup strategy chosen may itself be correct or incorrect. ^1^