# Attachment to Appendix A: Technical Report on the Societal Cost Burden of Acute Otitis Media

## Previous Estimates of the Societal Cost of Otitis Media in the United States

A review of the economic literature identified four estimates of the annual cost of OM in the United States. Each is a prevalence estimate derived as the product of an estimated cost per patient and an estimated annual prevalence of the illness.

### Review of Literature

Gates (1996b) placed the annual national total cost of AOM at $3.15 billion in the 0-4 year age group at an unspecified date in the early or mid- 1990s. The estimated cost per episode of illness was $233.50 ($100 in direct medical costs, $25 in travel expenses, and $107.50 in lost parental wages due to caregiving), and the total annual number of episodes of illness was assumed to be 14 million. ^2^ However, Gates also assumed an average of 2.5 physician visits per episode of illness, so that the total national number of physician visits would have been 35 million for the 0-4 year age group alone. There are no national data that are consistent with so large a number. Data from the 1995 NAMCS indicate a national total of 24.781 million ambulatory care visits for "otitis media and eustachian tube disorders" in all age groups (Schappert, 1997), and the number of visits received by children in the 0-4 year age group for AOM would have been somewhat smaller still. This suggests that Gates' estimate of the national cost burden of AOM is exaggerated by more than 50 percent.

2 According to the assumptions, the actual total annual cost was $3.27 billion.

The most often-cited estimate of the national cost of OM is by Stool and Field (1989). Stool and Field put the cost at $2.4-3.3 billion in the 0-6 year age group in an unspecified year -- apparently in the middle or late 1980s. Like the Gates study, Stool and Field may have intended their estimate as an approximation of the true figure rather than as a precise calculation. The direct medical cost per episode was assumed to be $91, the average cost of surgery was placed at $37-$75, and lost parental wages were set at $18-$36. The total annual number of episodes of illness was unreferenced but assumed to be 16.8 million. Like Gates' assumed prevalence, the figure of 16.8 million episodes seems excessively high, and it almost certainly biases the Stool and Field estimate of the national cost of OM upward. Otherwise, the large difference in the cost per episode between the Stool and Field and Gates estimates -- $100 or more -- is due to Gates' inclusion of parental travel costs in the calculation and his imputation of a much larger value of lost parental wages.

In the third study, Berman et al. (1994) used the decision-tree method to estimate the total cost per case (including parental travel expenses and lost wages) of persistent middle ear effusion (PMEE) for a hypothetical 13-month-old boy. Priced at Colorado Medicaid reimbursement levels in 1992, the cost per case was $720-$1,372, varying with the assumed treatment regimen. Priced at private practice reimbursement levels in Denver in the same year, the cost was $1,265-$2,588, also varying with the assumed treatment regimen. Although Berman et al. did not give a national cost estimate, they conjectured an annual national total of 1.9 million cases of PMEE in the group younger than age 2 on the assumption of 9.3 million cases of AOM in the age group, 20 percent of which result in PMEE. At 1.9 million cases per year, the annual medical cost of PMEE in the 0-1 year age group would have been $1.37-$4.92 billion, depending on the treatment regimen and whether utilization was priced at Colorado Medicaid payment levels or private practice payment levels in the Denver area.

The only estimate of the national cost of OM using a data-based estimate of costs per case was prepared for the guidelines on treating OME by Stool et al. (1994). Claims data from more than 100 health insurers were used to estimate the direct costs of OME in the 2-year-old age group in 1991. Including estimates of lost parental wages, the total cost of OME was put at $406 per child for medical treatment only, $2,174 for a child undergoing myringotomy with tube insertion, and $3,433 per child undergoing adenoidectomy. The estimated overall average cost per child was $1,330. The annual national prevalence of OME in the 2-year-old age group was set at 821,700 episodes, so that the national total cost of OME was estimated at $1.09 billion in 1991.

### Assessment of Literature

The four studies imply that the annual national cost of OM runs into several billions of dollars, but in other respects their results cannot be easily summarized. Only one of the four expressly estimated the national cost of AOM. The Gates and Stool and Field estimates assume prevalences of illness that seem to be at odds with the only available national data on the utilization of ambulatory care visits for OM. The estimates from the Berman et al. and Stool et al. studies are restricted to episodes of illness in very young children. All of the studies omitted the indirect cost of unpaid family caregiving services provided by unemployed parents and by employed parents during nonworking hours.

On balance, the national cost estimates are overstated insofar as they embody inflated estimates of the prevalence of OM. They also are understated to the extent that they are restricted to very young age groups of children, do not include all forms of OM, and exclude the indirect costs of unpaid family caregiving services.

## Estimating the National Cost of AOM in Children Younger Than 18

### Methodology: Background

The societal cost of an illness is conventionally defined as the total value (priced as an aggregate opportunity cost) of all goods and services consumed, destroyed, or foregone as a result of the illness and its treatment. In addition, the societal cost of a treatment encompasses not only the value of resources consumed by the treatment itself, but also the value of resources consumed, destroyed, or foregone due to treatment complications and failures. For this report, OME and chronic middle ear infections were considered the consequences of unsuccessful treatments of AOM. In cost-of-illness studies and cost-effectiveness analyses, it is customary to regard the costs of treatment failures and sequelae as costs of the initial illness and its treatment. Thus, the cost of AOM was defined as the societal cost of all forms of OM and not just of AOM alone.

The national cost of OM was estimated with the same two-step method employed in the four studies described above. That is, estimates of the cost per episode of OM were multiplied by estimates of the total number of episodes of illness. We assumed that we could estimate the total annual number of episodes of OM as the product of age-specific (and possibly sex-specific) episode rates of OM and the sizes of the relevant-age cohorts of children in the United States. We reviewed the epidemiological literature for age-specific annual episode rates of illness.

Two limitations were imposed on the review: it was restricted to findings on U.S. samples of children, and it was narrowed to studies performed after 1990. The reasoning was as follows.

First, a substantial body of epidemiological research on OM has been performed outside the United States, particularly in Northern Europe. Nevertheless, it is well known that the incidence and prevalence rates of OM vary with race, climate, urban and rural location, frequency of contact with other children (such as in day care centers), and other factors. Because it is unclear that these influences are the same in the United States and other countries, estimates of the incidence and prevalence rates of OM obtained outside the United States and Canada may not be applicable to this country. Therefore, non-U.S., non-Canadian studies were consequently omitted from the review.

Second, there is significant evidence that the prevalence rate of OM in this country increased dramatically from the mid- 1970s to 1990. The indications are mixed as to whether the upward trend in the prevalence rate has leveled off in the 1990s. In any event, it seemed likely that episode rates of OM derived before 1990 would give downward-biased estimates of the episode rates prevailing in the mid- or late 1990s. This is not to say that all such studies are biased. If a pre- 1990s study focused on a sample of children with predispositions to OM, its episode rates might have considerably overrepresented national rates at the time it was performed but give accurate estimates of rates in the mid- and late 1990s. Nevertheless, although epidemiological studies conducted as early as the late 1970s were reviewed, they were set aside on grounds that they were not clearly applicable to recent experience in the United States.

Only one relevant epidemiological study of OM has been performed in the U.S. since the mid- 1980s (Yawn and Lydick, 1996). The study, conducted in Rochester, MN in 1994-95, reported the numbers of episodes of illness per child within 1-year age cohorts for children aged 12 and younger. However, when these episode rates were multiplied by the sizes of 1-year age cohorts in the 0-12-year U.S. population in 1995 (Day, 1996), they produced a total of 36.3 million episodes of OM, and it is not possible to reconcile this estimate with the NAMCS estimate of 24.781 million ambulatory care visits for "otitis media and eustachian tube disorders" in the same year (Schappert, 1997). The Yawn et al. estimates were obtained by telephone interviews with parents. Thus, many responses may have been inaccurate or, if they were accurate, many of the reported episodes of infection may not have received medical care. ^3^ For this report it was taken as a working hypothesis that the NAMCS estimate is correct and thus that the Yawn et al. episode rates greatly exaggerate the national number of treated cases of OM. We therefore concluded that all published estimates of the rates of episodes of OM per child significantly bias estimates of the national number of treated episodes of OM in the mid- 1990s.

3 It may also be true that the NAMCS estimate understates the national ambulatory care utilization rate for OM, although if that is the case it is difficult to claim that any reliable estimate of the national number of episodes of OM exists.

Because the epidemiological literature appeared not to yield demonstrably reliable rates for episodes of illness (and none at all in the 13- to 17-year-old age group), the total national number of episodes of AOM in 1995 was estimated from NAMCS and other national data and from individual studies in which the number of physician visits per episode of illness was reported.

The dearth of data and information sources made it necessary to use a number of assumptions and simplifications to derive both the national number of episodes of OM and the cost per episode. In summary, the principal features and premises of the estimation procedure were these:

- National illness costs were derived for the year 1995. Certain data used in deriving and validating the estimates were not yet available for 1996 and later years when the report was begun.
- The estimated national cost of OM refers to children younger than 18 years of age.
- The estimates of total national medical care utilization for OM were constructed to be as closely consistent as possible with the available (NAMCS and other) reports of national utilization for ear infections.
- Episodes of OME/chronic middle ear infection that result from unsuccessful treatments of AOM were considered complications of AOM, and their cost was consequently considered a cost of AOM.

### Estimates of the National Numbers of Episodes of AOM and OME/Chronic Middle Ear Infection in 1995

It was assumed that the 1995 (NAMCS) national total of 24.781 million ambulatory visits for OM and eustachian tube disorders were for OM and its complications. No age distribution of the visits has been published. Thus, to estimate the number of visits by patients aged 17 and younger, it was assumed that the age distribution of visits was identical to the national age distribution of acute ear infections as reported by the National Health Interview Survey (NHIS) in 1995. According to the 1995 NHIS, there were 23.568 million acute ear infections in the United States, 82. 195 percent of which occurred in the 17-year old and younger age group (Benson and Marano, 1998). Hence, it was assumed that 20.38 million (24.781 million x 0.82 196) ambulatory care visits were provided nationally in 1995 to children under 18 with OM.

It was next assumed that the total number of ambulatory care visits for OM is the sum of the numbers of visits for AOM and OME/chronic middle ear infections. To estimate the numbers of episodes of AOM and OME/chronic middle ear infection from the total number of ambulatory care visits for OM, the following method was employed. Let

- A=
- total annual number of episodes of AOM

- O=
- total annual number of episodes of OME/chronic middle ear infection

- k=
- fraction of all episodes of OM that are episodes of OME/chronic middle ear infection

- T=
- total number of ambulatory care visits for OM

- V_a_=
- average number of ambulatory care visits/episode for AOM

- V_o_=
- average number of ambulatory care visits/episode for OME/chronic middle ear infection. Then

A·V_a_ + O·V_o_=T

O=k·(A+O).

Assuming that the values of all variables other than A and O are known or estimable, the solution of the equation system is

(1) A=(1-k)T/[(1-k)V_a_ + kV_o_]

(2) O=kA/(1-k).

These two relations were used to estimate the numbers of episodes of AOM and OME/chronic middle ear infusion.

The total number of ambulatory care visits (T) was set at 20.38 million as above. Published estimates of the mean number of physician visits per episode of AOM range from 1 to 2.5 (Table 53). Absent compelling reasons for other assumptions, the base-case mean rate for this report was placed at V_a_=1.75 visits per episode -- the midpoint of the range. Stool et al. (1994) reported an estimate of 5.1 physician visits per episode for OME from a large sample of insurance plan claims data in 1991. No other estimates of the visit rate were found. Hence, it was assumed that the mean rate of physician utilization for an episode of OME/chronic middle ear infection was set at V_o_=5.1 visits. The percentage of all episodes of OM that are episodes of OME/chronic middle ear infection is poorly known. To estimate the cost of OME for the Stool et al. (1994) report, Lewin-VHI assumed that the percentage ranges from 25 to 35 and used a base-case figure of 30. The same percentage was employed for the base case here. Hence, k=0.3.

Table 53. Estimated Costs Per Episode of Acute Otitis Media

Cost Component | Cost ($) | Assumptions | Source
Direct Costs | 114.69
Physician Visits | 75.69 | 1.75 visits/episode 2/3 of visits to pediatricians, 1/3 to family/general practitioners Mean charge/visit=$48.07 Physicians paid 90% of charges | Branthaver et al (1997); Gates (1996b); Kaplan et al (1997); Landholt and Kotschwar (1994); Stool and Field (1989) Oh et al (1996); Weiss and Melman (1988); Nelson and Woodwell (1998); Gonzalez (1995)
Drugs | 19.62 | 1 course of antibiotics Mean costs in 2 Medicaid plans | White et al (1996); Berman et al (1997)
Laboratory | 5.63 | -- | Kaplan et al (1997)
Travel | 8.75 | $5/physician visit | Berman et al (1994); Gates (1996) ; Kaplan et al (1997); author
Paid in-home care, supplies | 5.00 | -- | Landholt and Kotschwar (1994); Kaplan et al (1997); Yawn et al (1996)
Indirect Costs | 99.50
Lost parental wages | 54.50 | 4 hours @ $11.35/hour plus 20% fringe benefits | Gates (1996) ; Kaplan et al (1997); Landholt and Kotschwar (1994); Stool and Field (1989); Weiss and Melman (1988); Yawn et al (1996)
Unpaid caregiving services, excluding lost work time | 45.00 | 6 hours @ $7.50/hour | Author
Total Cost | 214.19

The base-case values of T, V_a_, V_o_, and k applied to the equations (1) and (2) yielded an estimated 5.18 million annual episodes of AOM and 2.22 million episodes of OME/chronic middle ear infection. Following Berman et al. (1994), it was next assumed that 20 percent of all treated episodes of AOM progress to OME/chronic middle ear infection. Under that assumption, 1.04 million episodes of OME/chronic middle ear infection (approximately 47 percent of the total number of episodes) were complications of or the results of failed treatments for AOM. The cost of 1.04 million episodes of OME/chronic middle ear infection was therefore attributed to AOM.

### Estimated Cost per Episode of AOM

The cost per treated episode of AOM has been estimated in seven studies published since the late 1980s (Branthaver et al., 1997; Gates, 1996b; Kaplan et al., 1997; Landholt and Kotschwar, 1994; Oh et al., 1996; Stool and Field, 1989; Weiss and Melman, 1988). The costs range from $39 to $233.50, varying with the date and geographic location of the estimate and with the items of direct and indirect cost included by authors. After inflating them to mid- 1990s price levels, the majority of the estimates cluster at roughly $125-$130 per episode. Even so, they differ sufficiently in composition and assumptions (such as the number of physician visits per episode) to make them dubiously representative of the average national cost per episode of AOM.

#### Direct cost per episode

To estimate the direct cost per treated episode of AOM, it was assumed as above that patients received an average of 1.75 physician office or clinic visits. In 1995, private family and general practitioners charged an average of $45.87 for an office visit with an established patient, and pediatricians in private practice charged $49.17 (Gonzalez, 1996). It was then assumed that:

- two-thirds of the children with AOM visited pediatricians and one-third visited family/general practitioners (Nelson and Woodwell, 1998);
- (private) physicians were paid 90 percent of their billed charges; and
- payments per visit -- $41.28 and $44.25 respectively -- are reasonable estimates of the societal costs per visit for treating AOM.

The assumptions yield a mean cost per visit of $43.25 and a cost of $75.69 per episode of AOM for physician services.

The standard premise in all seven studies of AOM treatment costs is that (successfully) treated patients receive one or two courses (or prescriptions) of antibiotics, most commonly amoxicillin or cefaclor. It was assumed conservatively that patients received an average of only one course of treatment. The mean cost of one course of first-line antibiotics for AOM was said to be $16. 19 in the Tennessee Medicaid plan in 1993 (White, Holiman, Tepedino, et al., 1996) and $20.27 in the Colorado Medicaid plan in 1991-92 (Berman, Byrns, Bondy, et al., 1997). Other reports or estimates of drug costs are taken from much smaller samples of data and vary widely with the specific drugs prescribed by physicians. The Tennessee and Colorado Medicaid plan costs were therefore inflated to 1995 levels by the drug component of the Consumers Price Index (U.S. Bureau of the Census, 1998) and averaged. The resulting cost, $ 19.62, was taken as a reasonable estimate of the societal cost of antibiotics for an episode of AOM.

Only one estimate of laboratory costs per episode, $5.63 in a Charleston, WV, practice in 1994 (Kaplan et al., 1997), has been reported in the recent literature. It was used as an approximation of the costs of laboratory services. Family travel costs have been estimated by authors or derived from data in three recent studies. The costs were priced at $7.70, $7.59, and $10 per physician visit (Berman et al., 1994; Gates, 1996b; Kaplan et al., 1997). Although it is hard to conjecture an average cost of travel to providers, the direct cost per round trip was placed conservatively at $5 per physician visit or $8.75 per episode. Families also may pay for in-home care for the child and buy supplies such as antidiarrheals, electrolytes, and extra diapers for children experiencing the adverse side effects of antibiotic therapy. There are two reports of these costs -- $0.77 for baby sitters (Kaplan et al., 1997) and $1.79-$6.82 for other supplies (Landholt and Kotschwar, 1994). Yawn et al. (1996) gave the figure of about 30 minutes of unnamed "special child arrangements" per episode of OM. They did not assign a cost to the arrangements, but it seems unlikely that the cost would exceed $3-$4 per episode. The total cost of paid inhome care and nonmedical supplies was therefore set at $5 per episode of AOM.

Together, the preceding assumptions yield an average total direct cost of $114.69 per episode of treated AOM. The estimates are summarized in Table 53.

#### Indirect cost per episode

All published estimates of the indirect cost of AOM limit the scope of the cost to foregone parental wages. The common assumption or observation is that an employed parent leaves work to take the sick child to visit a physician. The estimates of lost work time and lost wages (i.e., the value of labor product forgone by society because of the child's illness) differ markedly, possibly because of interstudy differences in work force participation rates. Yawn et al. (1996), and Weiss and Melman (1988) gave estimates of 0.4-0.5 work days lost per episode of AOM, but Landholt and Kotschwar (1994) put the average family work time loss at only 0.6-1.3 hours per episode. Kaplan et al. (1997) gave an apparently data-based estimate of $34.38 in lost parental wages per episode of illness. Stool and Field (l989) and Gates (1996b) conjectured costs of $18-$36 and $107.50 per episode, respectively.

Unpaid caregiving services for AOM include travel services by parents, communication with physicians, shopping services for prescriptions and other supplies, and all exceptional child care (feeding, attending, administering drugs, doing laundry, etc.) caused by illness. Because there are no conclusive ways of knowing whether the typical or average caregiver of a sick child is employed, the relatively conservative assumption was made that 4 work hours or 0.5 work days per child are lost due to caregiving for an episode of AOM. In 1995 the average hourly earnings of employed workers was $11.35, excluding fringe benefits (U.S. Bureau of the Census, 1996). Consequently, given a fringe benefit rate of 20 percent, the average indirect cost of societal lost work product was $54.50 per episode of AOM.

There are no estimates of the indirect cost of unpaid family caregiving services by unemployed parents or by employed parents during weekends or other nonworking hours. Any imputation of this cost must therefore be speculative. It was assumed conservatively that the family devotes an hour of unpaid caregiving each day over a 10-day course of illness. As above, 4 hours were provided by a parent who left work, and the remaining 6 were provided with no loss of work time. In 1995, the mean hourly wage rate for paid inhome health care services was $10.91 (U.S. Bureau of the Census, 1996). However, because a high level of caregiving skill is probably not necessary for a child with OM, the hourly opportunity cost of unpaid services was set at $7.50, approximately the average of $10.91 and the hourly minimum wage. The estimated opportunity cost of unpaid caregiving services was therefore $45.00 (6 × $7.50) per episode of AOM.

#### Total cost per episode of AOM

The preceding estimates yield a total cost of $214. 19 per episode of AOM, including $99.50 in indirect costs. The estimates, assumptions, and sources are summarized in Table 53.

### Estimated Cost per Episode of OME/Chronic Middle Ear Infection

Berman et al. (1994) put the average cost, including all direct costs and the indirect cost of lost parental wages, of an episode of OME/recurrent or persistent middle ear infection at $720-$2,588 for a "hypothetical 13-month-old boy" in the Colorado study in 1992. The wide range occurred because of variations in treatment and differences in the payment mechanism (Medicaid or private fee-for-service).

The only data-based estimate of the cost of OME is by Lewin-VHI and is reported in Stool et al. (1994). It was used here to estimate the cost per episode of OME/chronic ear infection. The estimate was derived from a sample of health insurance claims (from more than 100 different insurers) for 1,898 patients. Mean direct, indirect, and total costs (payments to providers) per episode of illness were placed at $1,060, $270, and $1,330 per episode, respectively, in 1991. Unfortunately, the figures obtained by Lewin-VHI have several shortcomings. First, the cost estimates were made only for 2-year-old children, and the authors remark that costs were "similar [but] not identical" for other age groups. Second, the costs of drugs were not observed but conjectured on the basis of prescription patterns obtained from "practice surveys [and] an unpublished study." Third, indirect costs were defined only as foregone wage and salary income when parents left work to transport children to medical providers. Moreover, the authors assumed rather than observed the durations of missed work time. Any of these features of the cost calculations might give distorted estimates of the true costs per case.

The Lewin-VHI estimate of direct cost per episode of illness was inflated to 1995 price levels by the medical care component of the Consumer's Price Index. The estimate of indirect cost per episode of illness was inflated by the percentage change in average national hourly earnings from 1991 to 1995 (U.S. Bureau of the Census, 1992, 1996). The 1995 estimates of direct, indirect, and total costs per episode of OME were $1,321, $299, and $1,620.

#### Estimated indirect cost per episode of unpaid caregiving services

The indirect cost of unpaid family caregiving services provided to children with OME/chronic ear infections by unemployed parents and employed parents during nonworking hours has never been estimated and must also be conjectured. Recent studies place the average duration of an episode of OME at 17-23 days (Casselbrant et al., 1985; Klein et al., 1990; Teele et al., 1990; Paradise et al., 1997). Because all of the estimates refer to children aged 7 or younger and the duration of illness appears to decline with age, the average length of illness for all children aged 17 and younger was conservatively set at 17 days. In the absence of more complete data, it was consequently assumed that families provide an average of 1.5 (nonworking) hours per day of unpaid caregiving services to children with OME/chronic middle ear infection over 17 days of illness. Lewin-VHI (Stool et al., 1994) reported that 55 percent of their sample of 2-year-olds continued treatment for OME for at least 3 months. Hence, the estimate of 25.5 hours of nonworking caregiving time per episode of OME may be conservative. The level of required caregiving skill may be higher than that needed for AOM, but the imputed hourly wage rate for unpaid care was set at $7.50 as before. Thus, the total opportunity cost of unpaid caregiving services was $ 191.25 per episode of illness.

#### Total cost per episode of OME/chronic middle ear infection

The assumptions given here yield a total cost of $1,811.25 for an episode of OME/chronic middle ear infection in 1995.

The estimated direct and indirect costs per episode of illness were $1,321 and $490.25, respectively.

### Estimated Total National Cost of OM in 1995

To summarize, the procedures described here yielded the following estimates for the 0- to 17-year age group:

- Total annual number of episodes of AOM: 5.18 million.
- Number of episodes of OME/chronic middle ear infection attributable to AOM: 1.04 million.
- Direct, indirect, and total costs per episode of AOM: $114.69, $99.50, and $214. 19, respectively.
- Direct, indirect, and total costs per episode of OME/chronic middle ear effusion: $1,321.00, $490.25, and $1,811.25, respectively.
- In 1995, the estimated total national cost of AOM and its complications was therefore $2.983 billion [(5.18million)·$214. 19 + (1.04 million)·$1,811.25]. The total direct cost was $1.961 billion and the total indirect cost was $1.022 billion.
- Direct and indirect costs accounted for approximately 66 percent and 34 percent, respectively, of total illness costs.

#### Sensitivity analysis

Because of the large number of assumptions necessary to produce the cost estimate, a sensitivity analysis of the underlying parameter values was performed. Selected results of the analysis are presented in Table 54. The cost estimate was found to be relatively insensitive to nearly all of the parameters used in deriving it. For the most part, variations in the values of the parameters by given percentages (P) cause percentage variations in the cost estimate of size 0.4P or less.

Table 54. Sensitivity analysis of estimated total annual national cost of acute otitis media in < 18-year age group: variations in total costs with respect to variations in the total annual national number of ambulatory care visits for otitis media, the percentage of episodes of otitis media that are episodes of otitis media with effusion/chronic ear infection, and the percentage of episodes of acute otitis media that progress to otitis media with effusion/chronic ear infection (Costs in millions of dollars) ^1^

Episodes of OME/Chronic Middle Ear Infection as Percentage of All Episodes of OM | Percentage of Episodes of AOM That Progress to OME/Chronic Ear Infection
Episodes of OME/Chronic Middle Ear Infection as Percentage of All Episodes of OM | 10 | 20 | 30 | 40
Annual Number of Ambulatory Care Visits for OM=20.37 Million (Base Case)
10 | 3,476 | 5,068 | 6,661 | 8,254
25 | 2,334 | 3,403 | 4,473 | 5,542
30 | 2,046 | 2,983 | 3,921 | 4,858
35 | 1,791 | 2,612 | 3,432 | 4,253
50 | 1,176 | 1,714 | 2,253 | 2,791
Annual Number of Ambulatory Care Visits for OM=25 Million
10 | 4,266 | 6,221 | 8,175 | 10,130
25 | 2,865 | 4,177 | 5,490 | 6,802
30 | 2,511 | 3,662 | 4,812 | 5,963
35 | 2.198 | 3,205 | 4.212 | 5,219
50 | 1,443 | 2,104 | 2,765 | 3,426
Annual Number of Ambulatory Care Visits for OM=30 Million
10 | 5,119 | 7,465 | 9,810 | 12,156
25 | 3,438 | 5,013 | 6,588 | 8,163
30 | 3,013 | 4,394 | 5,775 | 7,155
35 | 2,638 | 3,846 | 5,055 | 6,263
50 | 1,731 | 2,525 | 3,318 | 4,111
Annual Number of Ambulatory Care Visits for OM=35 Million
10 | 5,972 | 8,709 | 11,445 | 14,182
25 | 4,010 | 5,848 | 7,865 | 9,523
30 | 3,515 | 5,126 | 6,737 | 8,348
35 | 3,077 | 4,487 | 5,897 | 7,307
50 | 2,020 | 2,945 | 3,871 | 4,796
Annual Number of Ambulatory Care Visits for OM=50 Million
10 | 8,532 | 12,441 | 16,350 | 20,259
25 | 5,729 | 8,354 | 10,979 | 13,604
30 | 5,022 | 7,323 | 9,624 | 11,925
35 | 4,396 | 6,410 | 8,425 | 10,439
50 | 2,885 | 4,208 | 5,530 | 6,852

1 Circled figure is the total cost derived from base-case assumptions.

However, the cost estimate is particularly sensitive to the values of the three parameters represented in Table 54: the total annual national number of ambulatory care visits for OM, the percentage of episodes of OME/chronic middle ear infection, and the percentage of episodes of AOM that progress to episodes of OME/chronic middle ear infection. Unfortunately, these three parameters cannot be estimated reliably either because of sketchy empirical information or, in the case of the visit totals, conflicting implications of the epidemiological evidence.

For example, although the NAMCS data on ambulatory care visit totals seem more accurate than the visit totals implied by epidemiological studies of OM, it has been suggested that the national numbers of ambulatory care visits compiled by NAMCS significantly understate the true totals (Glass et al., 1991). Although there exists no hard evidence that supports the claim, it remains a possibility that the 20.37 million visits figure used to estimate costs is biased downward.

In addition, Teele et al. (1980) reported that 40 percent of treated AOM patients exhibit symptoms of illness for at least 1 month and that 20 percent exhibit symptoms for at least 2 months. This could mean that the true percentage of the episodes of AOM that progress to OME/chronic middle ear infection is somewhat higher than the base-case percentage (20) used in the analysis here.

The figures in Table 54 show that the estimate of the total national cost of AOM increases with the assumed total number of ambulatory care visits for OM and with the percentage of episodes of AOM assumed to progress to OME/chronic middle ear effusion. Hence, the base-case national cost estimate of $2.983 billion is most likely to understate rather than overstate the true annual national cost of AOM. It may not be unrealistic to assume that the true annual national total of ambulatory care visits for OM is 30 million in the <18-year age group and that 30 percent of the episodes of AOM progress to OME/chronic middle ear infection. Under those assumptions and the premise that OME/chronic middle ear infection represents 25-35 percent of all episodes of OM, the estimated national cost of AOM is $5.055-$6.588 billion (Table 54). Although there are no ways of verifying the correctness of these assumptions, it seems reasonable to think that the annual national cost of AOM is at least $3 billion and may be as much as $6 billion.

## Review of Epidemiology: Number of Episodes of Otitis Media per Child per Year

### Background

A review of the epidemiological literature on OM was conducted to determine whether it provided reliable estimates of the annual rate of episodes of illness per child. The review was limited to studies performed in the United States and Canada during or after the late 1970s. As stated in the preceding section, studies performed elsewhere were deemed of doubtful relevance to the occurrence of OM in the United States. Studies published before 1980 also were excluded because of the apparently large increase in OM attack rates after 1975. For example, data from the NAMCS show that, depending on age and sex, the annual number of office visits per child for OM increased by 125-250 percent from 1975 to 1990 in the 0- to 5-year old age group (Schappert, 1992). Similarly, data from the National Health Interview Surveys (NHIS) indicate that the annual prevalence rate of acute ear infections in the 0- to 4-year old age group increased by 28-84 percent from 1982 -- the first year that these infections were reported -- to 1990, also depending on sex (National Center for Health Statistics, 1985; Adams and Benson, 1991). An epidemiological study performed in the early 1980s in Montreal also described an 11-26 percent increase over a 3-year period in the number of episodes per child of OM among 3- and 7-year-olds (Croteau et al., 1990). This evidence strongly implies that the prevalence and incidence rates of OM estimated before 1980 are likely to give downward-biased estimates of the current prevalence and incidence rates of OM.

It is not altogether clear that upward trends in the incidence and prevalence rates of OM have stabilized since 1990. At present, the only longitudinal data pertinent to the issue are NAMCS and NHIS data, and these have been published only up to the mid- 1990s. According to NAMCS and NHAMCS estimates, the total national number of ambulatory care visits for suppurative and unspecified OM (all ages) peaked at 20.033 million in 1989, fell to 16.185 million in 1991, and rose to 19.309 million in 1993 (Nelson and Woodwell, 1998). NHIS data also show large annual variations in the national prevalence rate of acute ear infections in the 0-17-year-old age group from 1990 to 1995, but reasonably evident trends in the rate appear only for children age 5-17 -- a 14 percent increase for girls and a 32 percent increase for boys (Adams and Benson, 1991; Benson and Marano, 1998). Although these data summaries give a mixed picture, they suggest that the occurrence of OM in the 0-17 year age group may still be increasing. If that is true, incidence and prevalence rates derived as recently as the early 1990s may also understate the true current rates.

### Assessment of Literature

The search of the epidemiological literature uncovered 13 studies published in 1980 or later in which the occurrence of OM was examined in samples of U.S. or Canadian children. Seven of the 13 presented only the percentages of children with one or more episodes of illness, the age distribution of cases, or similar findings (Howie and Schwartz, 1983; Starfield et al., 1984; Roland et al., 1989; Casselbrant et al., 1990; Marx et al., 1995; Paradise et al., 1997; Zimmerman et al., 1998). The remaining six reported the mean numbers of episodes of illness per child or provided information from which these numbers could be derived. To provide a comparison of the six studies, the reported mean numbers of episodes per child-year by age cohort were multiplied by the U.S. Bureau of the Census' projected population sizes by age cohort for July 1, 1998 (Day, 1996). Each of the resulting products is an estimate of the total annual number of episodes for the given age cohort. The estimates are shown in Table 55. For those that provided data for more than one age cohort, the table allows inter-study comparisons to be made.

Table 55. Estimated Number of Episodes of Otitis Media in the U.S., 1995, Based on Estimates of the Number of Episodes per Child in 6 Studies

Study | Biles et al (1980) ^1^ | Marchant et al. (1984) ^2^ | Casselbrant et al. (1985) 3, ^4^ | Teele et al. (1989) ^4^ | Croteau et al. (1990) ^5^ | Yawn et al. (1996) ^5^
Definition of illness | Otitis media | Otitis media | Otitis media with effusion | Acute otitis media | Otitis media | Otitis media
Date of study | 1975 | Not specified | 1981-83 | 1975-84 | 1981-83 | 1994-95
Location | Galveston, TX | Cleveland, OH | Pittsburgh, PA | Boston, MA | Montreal, QU | Rochester, MN
Sample size | 1,018 | 70 | 140 | 498 | Very large, not specified | 9,047
Age group (years) | 0-8 | < 1 | 2-6 | 0-6 | 3, 7 | 0-12

Estimated Number of Episodes, 1995 (millions)^6^
Age Group (Years)
< 1 | | 8.1 (36.5% aymptomatic) | | 4.6 | | 3.8
3 | | | | 3.2 | 2.7 | 4.3
0-6 | | | | 21.1 | | 30.4
2-6 | | | 36.9 | 12.3 | | 18.1
7 | | | | | 1.4 | 1.6
0-8 | 15.0 | | | | | 33.2
0-12 | | | | | | 36.3

1 Data collected retrospectively from medical records. Authors say estimates may understate true prevalence.

2 Some cases of illness diagnosed during monthly well-child visits.

3 All children in sample attended day care center.

4 Dropouts from initial sample had lower rates of illness than patients remaining in study to conclusion. Authors say that dropout behavior may have caused the observed prevalences of illness to overstate those of t he overall population.

5 Data collected by RNs from telephone interviews with parents.

6 Mean episodes per child reported by authors times estimated U.S. population in age cohort (Day, 1996).

The comparisons in Table 55 are obviously disappointing. The estimated annual national numbers of episodes of OM vary widely, probably because of differences in sample locations or other characteristics and the procedures used by researchers to identify cases of OM. For example, one of the studies (Casselbrant et al., 1985) was performed on children in day care centers, and its findings were not intended to be applied to the population of all children. Given the large disparities in the estimates in Table 55 it is extremely difficult to say whether any of the studies represented in the table produces accurate estimates of the annual number of treated episodes of acute and other OM in U.S. children.

On that basis it was concluded from the review that the existing epidemiological literature does not provide reliable estimates of the annual numbers of treated episodes of OM in the U.S. during recent years.