# Appendix I. Acknowledgements

We gratefully acknowledge the following individuals who provided assistance in the screening and reviewing of non-English-language articles: Enkhjargal Badamgarav, M.D., M.P.H., for Russian; Anna Butturini, M.D., for Italian; Margaretha Casselbrant, M.D., Ph.D., for Danish, Norwegian, and Swedish; Barbara Korsch, M.D., for German; Margaret Khoury, M.D., for Polish; Manuel Lorenzo, M.D., for Spanish; Bracha Shaham, M.D., for Hebrew; Sina Sirabionian for Romanian; Jan Van Tornout, M.D., for Dutch; Laura Wachsman, M.D., for French and German; and Shoji Yano, M.D., Ph.D., for Japanese.

In addition, we wish to thank the technical experts for their tireless efforts throughout the entire process: Tony Arboleda, M.D.; Margaretha Casselbrant, M.D., Ph.D.; F. Lane France, M.D.; Theodore G. Ganiats, M.D.; Janice Goertz, R.N., C.P.N.P.; Judith S. Gravel, Ph.D.; Martin C. Mahoney, M.D., Ph.D.; Jennifer Postley, BA; Joanne Roberts, Ph.D.; Richard M. Rosenfeld, M.D., M.P.H.; and Leonard B. Weiner, M.D.

As well, we wish to thank the peer reviewers for their indepth reviews: Hanan S. Bell, Ph.D.; Alfred O. Berg, M.D., M.P.H.; Jeffrey L. Blumer, Ph.D., M.D.; Larry Culpepper, M.D., M.P.H; Terese Finitzo, Ph.D.; Fran Goldfarb, M.A.; Mark P. Haggard, Ph.D.; Katherine Harris, Ph.D.; Vic Hasselblad, Ph.D.; Lynne Haverkos, M.D; Elizabeth Susan Hodgson, M.D.; Lisa L. Hunter Ph.D.; Jerome Klein, M.D.; Tracy Lieu, M.D.; Jack Paradise, M.D.; William P. Potsic, M.D.; Robert Ruben, M.D.; Carol Rudy, M.S.N., C.P.N.P.; Anne G.M. Schilder, M.D., Ph.D.; Stanford T. Shulman, M.D.; Robin Yurk, M.D., M.P.H.; and Joost Zaat, M.D.

Finally, we are very grateful to Estela Alvidrez, Shannon Rhodes, and Sandra Wong for their superb project assistance, and to Laura Zakaras, Ph.D., for assistance in scientific writing.