# Appendixes

Appendix A. Economic Burden of Illness

Attachment to Appendix A: Technical Report on the Societal Cost Burden of Acute Otitis Media

Appendix B. Conceptual Framework For Management Of Acute Otitis Media

Appendix C. Key Questions

Appendix D. Definitions of Acute Otitis Media

Appendix E. Scope of the Evidence Report

Appendix F. Title and Abstract Screening Form

Appendix G. Article Quality Review Form

Appendix H. Data Abstraction Form for Article Review

Appendix I. Acknowledgements