# List of Acronyms/Abbreviations

ABMS | American Board of Medical Specialties
ACCP | American College of Chest Physicians
AHRQ | Agency for Healthcare Research and Quality
AMA | American Medical Association
CI | Confidence interval
CME | Continuing medical education
EPC | Evidence-based Practice Center
KQ | Key questions
KR20 | Kuder-Richardson 20
MOC | Maintenance of Certification
NIH | National Institutes of Health
SD | Standard deviation
US | United States