# References

1 American Academy of Family Practice. CME Requirements for Members. Accessed 22 November 2006 at http://www.aafp.org/online/en/home/cme/cmea/cmerequirements.html.
2 American Medical Association. House of Delegates Policy #300.988. Restoring Integrity to Continuing Medical Education. Accessed 12 September 2006 at http://www.ama-assn.org/apps/pf_new/pf_online?f_n=resultLink&doc=policyfiles/HnE/H-300.988.HTM&s_t=300.988&catg=AMA/HnE&catg=AMA/BnGnC&catg=AMA/DIR&&nth=1&&st_p=0&nth=1&.
3 Chassin MR, Galvin RW. The urgent need to improve health care quality. Institute of Medicine National Roundtable on Health Care Quality. JAMA. 1998;280(11):1000-5. [pmid: 9749483].
4 Steinbrook R. Renewing board certification. N Engl J Med. 2005;353(19):1994-7. [pmid: 16282173].
5 U.S. Department of Health and Human Services. Moving Medical Innovations Forward - New Initiatives from HHS, U.S. Department of Health and Human Services. January 2005 Accessed November 2006 at http://www.hhs.gov/reference/medicalinnovations.shtml#_Toc93371787.
6 Cabana MD, Rand CS, Powe NR, et al. Why don't physicians follow clinical practice guidelines? A framework for improvement. JAMA. 1999;282(15):1458-65. [pmid: 10535437].
7 Berlin JA. Does blinding of readers affect the results of meta-analyses? University of Pennsylvania Meta-analysis Blinding Study Group. Lancet. 1997;350(9072):185-6. [pmid: 9250191].
8 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
9 Kaufman DM. Applying educational theory in practice. Br Med J. 2003;326(7382):213-6. [pmid: 12543841]. [pmcid: 1125068].
10 Moher D, Cook DJ, Eastwood S, Olkin I, Rennie D, Stroup DF. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999;354(9193):1896-900. [pmid: 10584742].
11 Reed D, Price EG, Windish DM, et al. Challenges in systematic reviews of educational intervention studies. Ann Intern Med. 2005;142(12 Pt 2):1080-9. [pmid: 15968033].
12 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. Br Med J. 2004;328(7454):1490. [pmid: 15205295]. [pmcid: 428525].
13 Mukohara K, Schwartz MD. Electronic delivery of research summaries for academic generalist doctors: a randomised trial of an educational intervention. Med Educ. 2005;39(4):402-9. [pmid: 15813763].
14 Bjornson DC, Rector TS, Daniels CE, Wertheimer AI, Snowdon DA, Litman TJ. Impact of a drug-use review program intervention on prescribing after publication of a randomized clinical trial. Am J Hosp Pharm. 1990;47(7):1541-6. [pmid: 2368745].
15 Dormuth CR, Maclure M, Bassett K, Jauca C, Whiteside C, Wright JM. Effect of periodic letters on evidence-based drug therapy on prescribing behaviour: a randomized trial. CMAJ. 2004;171(9):1057-61. [pmid: 15505268]. [pmcid: 526331].
16 Schectman JM, Schroth WS, Elinsky EG, Ott JE. The effect of education and drug samples on antihistamine prescribing costs in an HMO. HMO Pract. 1996;10(3):119-22. [pmid: 10160286].
17 Slotnick HB. Educating physicians through advertising: using the brief summary to teach about pharmaceutical use. J Contin Educ Health Prof. 1993;13(4):299-314.
18 Zuckerman IH, Weiss SR, McNally D, Layne B, Mullins CD, Wang J. Impact of an educational intervention for secondary prevention of myocardial infarction on Medicaid drug use and cost. Am J Manag Care. 2004;10(7 Pt 2):493-500. [pmid: 15298236].
19 Cohn BA, Wingard DL, Patterson RC, McPhee SJ, Gerbert B. The National DES Education Program: effectiveness of the California Health Provider Intervention. J Cancer Educ. 2002;17(1):40-5. [pmid: 12000106].
20 Ray WA, Schaffner W, Federspiel CF. Persistence of improvement in antibiotic prescribing in office practice. JAMA. 1985;253(12):1774-6. [pmid: 3974058].
21 Chan DH, Leclair K, Kaczorowski J. Problem-based small-group learning via the Internet among community family physicians: a randomized controlled trial. MD Comput. 1999;16(3):54-8. [pmid: 10439603].
22 Rost K, Nutting P, Smith J, Werner J, Duan N. Improving depression outcomes in community primary care practice: a randomized trial of the quEST intervention. Quality Enhancement by Strategic Teaming. J Gen Intern Med. 2001;16(3):143-9. [pmid: 11318908]. [pmcid: 1495192].
23 Winickoff RN, Coltin KL, Morgan MM, Buxbaum RC, Barnett GO. Improving physician performance through peer comparison feedback. Med Care. 1984;22(6):527-34. [pmid: 6738143].
24 Mazmanian PE, Daffron SR, Johnson RE, Davis DA, Kantrowitz MP. Information about barriers to planned change: a randomized controlled trial involving continuing medical education lectures and commitment to change. Acad Med. 1998;73(8):882-6. [pmid: 9736848].
25 Greenberg LW, Jewett LS. The impact of two teaching techniques on physicians' knowledge and performance. J Med Educ. 1985;60(5):390-6. [pmid: 3989846].
26 Haque S, Srinivasan S. A meta-analysis of the training effectiveness of virtual reality surgical simulators. IEEE Trans Inf Technol Biomed. 2006;10(1):51-8. [pmid: 16445249].
27 Issenberg SB, McGaghie WC, Petrusa ER, Lee Gordon D, Scalese RJ. Features and uses of high-fidelity medical simulations that lead to effective learning: a BEME systematic review. Med Teach. 2005;27(1):10-28. [pmid: 16147767].
28 Hmelo CE. Computer-assisted instruction in health professions education: a review of the published literature. J Educ Technol. 1990;18(2):83-101.
29 Aucar JA, Groch NR, Troxel SA, Eubanks SW. A review of surgical simulation with attention to validation methodology. Surg Laparosc Endosc Percutan Tech. 2005;15(2):82-9. [pmid: 15821620].
30 Gerson LB, Van Dam J. Technology review: the use of simulators for training in GI endoscopy. Gastrointest Endosc. 2004;60(6):992-1001. [pmid: 15605024].
31 Sutherland LM, Middleton PF, Anthony A, et al. Surgical simulation: a systematic review. Ann. Surg. 2006;243(3):291-300.
32 Gerrity MS, Cole SA, Dietrich AJ, Barrett JE. Improving the recognition and management of depression: is there a role for physician education?. J Fam Pract. 1999;48(12):949-57. [pmid: 10628575].
33 Kiang KM, Kieke BA, Como-Sabetti K, Lynfield R, Besser RE, Belongia EA. Clinician knowledge and beliefs after statewide program to promote appropriate antimicrobial drug use. Emerg Infect Dis. 2005;11(6):904-11. [pmid: 15963286].
34 Curran VR, Hoekman T, Gulliver W, Landells I, Hatcher L. Web-based continuing medical education. (II): Evaluation study of computer-mediated continuing medical education. J Contin Educ Health Prof. 2000;20(2):106-19. [pmid: 11232219].
35 Costanza ME, Zapka JG, Harris DR, et al. Impact of a physician intervention program to increase breast cancer screening. Cancer Epidemiol Biomarkers Prev. 1992;1(7):581-9. [pmid: 1302571].
36 Andersen SM, Harthorn BH. Changing the psychiatric knowledge of primary care physicians. The effects of a brief intervention on clinical diagnosis and treatment. Gen Hosp Psychiatry. 1990;12(3):177-90. [pmid: 2335304].
37 Block L, Banspach SW, Gans K, et al. Impact of public education and continuing medical education on physician attitudes and behavior concerning cholesterol. Am J Prev Med. 1988;4(5):255-60. [pmid: 3224002].
38 Premi J SS. Randomized controlled trial of a combined video-workbook educational program for CME. Acad Med. 1993;68(10 Suppl):S13-5. [pmid: 8216618].
39 Harris JM Jr, Kutob RM, Surprenant ZJ, Maiuro RD, Delate TA. Can Internet-based education improve physician confidence in dealing with domestic violence?. Fam Med. 2002;34(4):287-92. [pmid: 12017143].
40 Doucet MD, Purdy RA, Kaufman DM, Langille DB. Comparison of problem-based learning and lecture format in continuing medical education on headache diagnosis and management. Med Educ. 1998;32(6):590-6. [pmid: 10211248].
41 Premi J, Shannon S, Hartwick K, Lamb S, Wakefield J, Williams J. Practice-based small-group CME. Acad Med. 1994;69(10):800-2. [pmid: 7916790].
42 Fordis M, King JE, Ballantyne CM, et al. Comparison of the instructional efficacy of Internet-based CME with live interactive CME workshops: a randomized controlled trial. JAMA. 2005;294(9):1043-51. [pmid: 16145024].
43 Stewart M, Marshall JN, Ostbye T, et al. Effectiveness of case-based on-line learning of evidence-based practice guidelines. Fam Med. 2005;37(2):131-8. [pmid: 15690254].
44 Beaulieu M, Choquette D, Rahme E, Bessette L, Carrier R. CURATA: A patient health management program for the treatment of osteoarthritis in Quebec: an integrated approach to improving the appropriate utilization of anti-inflammatory/analgesic medications. Am J Manag Care. 2004;10(8):569-75. [pmid: 15352533].
45 Lane DS, Messina CR, Grimson R. An educational approach to improving physician breast cancer screening practices and counseling skills. Patient Educ Couns. 2001;43(3):287-99. [pmid: 11384826].
46 Gifford DR, Mittman BS, Fink A, Lanto AB, Lee ML, Vickrey BG. Can a specialty society educate its members to think differently about clinical decisions? Results of a randomized trial. J Gen Intern Med. 1996;11(11):664-72. [pmid: 9120652].
47 Maiman LA, Becker MH, Liptak GS, Nazarian LF, Rounds KA. Improving pediatricians' compliance-enhancing practices. A randomized trial. Am J Dis Child. 1988;142(7):773-9. [pmid: 3381783].
48 White CW, Albanese MA, Brown DD, Caplan RM. The effectiveness of continuing medical education in changing the behavior of physicians caring for patients with acute myocardial infarction. A controlled randomized trial. Ann Intern Med. 1985;102(5):686-92. [pmid: 3985516].
49 Terry PB, Wang VL, Flynn BS, et al. A continuing medical education program in chronic obstructive pulmonary diseases: design and outcome. Am Rev Respir Dis. 1981;123(1):42-6. [pmid: 6161574].
50 Short LM, Surprenant ZJ, Harris JM Jr. A community-based trial of an online intimate partner violence CME program. Am J Prev Med. 2006;30(2):181-5. [pmid: 16459218]. [pmcid: 1413953].
51 Meredith LS, Jackson-Triche M, Duan N, Rubenstein LV, Camp P, Wells KB. Quality improvement for depression enhances long-term treatment knowledge for primary care clinicians. J Gen Intern Med. 2000;15(12):868-77. [pmid: 11119183]. [pmcid: 1495711].
52 Mann KV, Lindsay EA, Putnam RW, Davis DA. Increasing physician involvement in cholesterol-lowering practices: The role of knowledge, attitudes and perceptions. Adv Health Sci Educ Theory Pract. 1997;2(3):237-53. [pmid: 12386401].
53 Gerstein HC, Reddy SS, Dawson KG, Yale JF, Shannon S, Norman G. A controlled evaluation of a national continuing medical education programme designed to improve family physicians' implementation of diabetes-specific clinical practice guidelines. Diabet Med. 1999;16(11):964-9. [pmid: 10588528].
54 Chung S, Mandl KD, Shannon M, Fleisher GR. Efficacy of an educational Web site for educating physicians about bioterrorism. Acad Emerg Med. 2004;11(2):143-8. [pmid: 14759955].
55 Elliott TE, Murray DM, Oken MM, et al. Improving cancer pain management in communities: main results from a randomized controlled trial. J Pain Symptom Manage. 1997;13(4):191-203. [pmid: 9136230].
56 Evans CE, Haynes RB, Birkett NJ, et al. Does a mailed continuing education program improve physician performance? Results of a randomized trial in antihypertensive care. JAMA. 1986;255(4):501-4. [pmid: 3941533].
57 Maxwell JA, Sandlow LJ, Bashook PG. Effect of a medical care evaluation program on physician knowledge and performance. J Med Educ. 1984;59(1):33-8. [pmid: 6690696].
58 Kemper KJ, Gardiner P, Gobble J, Mitra A, Woods C. Randomized controlled trial comparing four strategies for delivering e-curriculum to health care professionals. BMC Med Educ. 2006;6(1):2. [pmid: 16405734]. [pmcid: 1382227].
59 Rosenthal MS, Lannon CM, Stuart JM, Brown L, Miller WC, Margolis PA. A randomized trial of practice-based education to improve delivery systems for anticipatory guidance. Arch Pediatr Adolesc Med. 2005;159(5):456-63. [pmid: 15867120].
60 Hergenroeder AC, Chorley JN, Laufman L, Fetterhoff A. Two educational interventions to improve pediatricians' knowledge and skills in performing ankle and knee physical examinations. Arch Pediatr Adolesc Med. 2002;156(3):225-9. [pmid: 11876665].
61 Des Marchais JE, Jean P, Castonguay LG. Training psychiatrists and family doctors in evaluating interpersonal skills. Med Educ. 1990;24(4):376-81. [pmid: 2395430].
62 Chodosh J, Berry E, Lee M, et al. Effect of a dementia care management intervention on primary care provider knowledge, attitudes, and perceptions of quality of care. J Am Geriatr Soc. 2006;54(2):311-7. [pmid: 16460384].
63 White M, Michaud G, Pachev G, Lirenman D, Kolenc A, FitzGerald JM. Randomized trial of problem-based versus didactic seminars for disseminating evidence-based guidelines on asthma management to primary care physicians. J Contin Educ Health Prof. 2004;24(4):237-43. [pmid: 15709563].
64 Lockyer JM, Fidler H, Hogan DB, Pereles L, Lebeuf C, Wright B. Dual-track CME: accuracy and outcome. Acad Med. 2002;77(10 Suppl):S61-3. [pmid: 12377707].
65 Kutcher SP, Lauria-Horner BA, MacLaren CM, Bujas-Bobanovic M. Evaluating the impact of an educational program on practice patterns of canadian family physicians interested in depression treatment. Prim Care Companion J Clin Psychiatry. 2002;4(6):224-31. [pmid: 15014713]. [pmcid: 315492].
66 Heale J, Davis D, Norman G, Woodward C, Neufeld V, Dodd P. A randomized controlled trial assessing the impact of problem-based versus didactic teaching methods in CME. Res Med Educ. 1988;27:72-7. [pmid: 3218878].
67 Labelle M, Beaulieu M, Renzi P, Rahme E, Thivierge RL. Integrating clinical practice guidelines into daily practice: impact of an interactive workshop on drafting of a written action plan for asthma patients. J Contin Educ Health Prof. 2004;24(1):39-49. [pmid: 15069911].
68 Bloomfield HE, Nelson DB, van Ryn M, et al. A trial of education, prompts, and opinion leaders to improve prescription of lipid modifying therapy by primary care physicians for patients with ischemic heart disease. Qual Saf Health Care. 2005;14(4):258-63. [pmid: 16076789]. [pmcid: 1744060].
69 Lane DS, Polednak AP, Burg MA. Effect of continuing medical education and cost reduction on physician compliance with mammography screening guidelines. J Fam Pract. 1991;33(4):359-68. [pmid: 1919452].
70 Lewis CE, Bursch B, Klau M, Konitsney D, Conrow S. Continuing medical education for AIDS: an organizational response. AIDS Educ Prev. 1993;5(3):263-71. [pmid: 8217478].
71 Kronick J, Blake C, Munoz E, Heilbrunn L, Dunikowski L, Milne WK. Improving on-line skills and knowledge. A randomized trial of teaching rural physicians to use on-line medical information. Can Fam Physician. 2003;49:312-7. [pmid: 12675544]. [pmcid: 2214189].
72 Brown JB, Boles M, Mullooly JP, Levinson W. Effect of clinician communication skills training on patient satisfaction. A randomized, controlled trial. Ann Intern Med. 1999;131(11):822-9. [pmid: 10610626].
73 Lin EH, Katon WJ, Simon GE, et al. Achieving guidelines for the treatment of depression in primary care: is physician education enough?. Med Care. 1997;35(8):831-42. [pmid: 9268255].
74 Pinto BM, Goldstein MG, DePue JD, Milan FB. Acceptability and feasibility of physician-based activity counseling. The PAL project. Am J Prev Med. 1998;15(2):95-102. [pmid: 9713664].
75 Harris SB, Leiter LA, Webster-Bogaert S, Van DM, O'Neill C. Teleconferenced educational detailing: diabetes education for primary care physicians. J Contin Educ Health Prof. 2005;25(2):87-97. [pmid: 16078807].
76 Jennett PA, Laxdal OE, Hayton RC, et al. The effects of continuing medical education on family doctor performance in office practice: a randomized control study. Med Educ. 1988;22(2):139-45. [pmid: 3374415].
77 Rodney WM, Albers G. Flexible sigmoidoscopy: primary care outcomes after two types of continuing medical education. Am J Gastroenterol. 1986;81(2):133-7. [pmid: 3946367].
78 Clark NM, Gong M, Schork MA, et al. Long-term effects of asthma education for physicians on patient satisfaction and use of health services. Eur Respir J. 2000;16(1):15-21. [pmid: 10933079].
79 Grady KE, Lemkau JP, Lee NR, Caddell C. Enhancing mammography referral in primary care. Prev Med. 1997;26(6):791-800. [pmid: 9388790].
80 Leopold SS, Morgan HD, Kadel NJ, Gardner GC, Schaad DC, Wolf FM. Impact of educational intervention on confidence and competence in the performance of a simple surgical task. J Bone Joint Surg Am. 2005;87(5):1031-7. [pmid: 15866966].
81 Norris SL, Grothaus LC, Buchner DM, Pratt M. Effectiveness of physician-based assessment and counseling for exercise in a staff model HMO. Prev Med. 2000;30(6):513-23. [pmid: 10901494].
82 Schroy PC, Heeren T, Bliss CM, Pincus J, Wilson S, Prout M. Implementation of on-site screening sigmoidoscopy positively influences utilization by primary care providers. Gastroenterology. 1999;117(2):304-11. [pmid: 10419910].
83 Cherkin D, Deyo RA, Berg AO, Bergman JJ, Lishner DM. Evaluation of a physician education intervention to improve primary care for low-back pain. I. Impact on physicians. Spine. 1991;16(10):1168-72. [pmid: 1836676].
84 Roter DL, Hall JA, Kern DE, Barker LR, Cole KA, Roca RP. Improving physicians' interviewing skills and reducing patients' emotional distress. A randomized clinical trial. Arch Intern Med. 1995;155(17):1877-84. [pmid: 7677554].
85 Macrae HM, Regehr G, McKenzie M, et al. Teaching practicing surgeons critical appraisal skills with an Internet-based journal club: a randomized, controlled trial. Surgery. 2004;136(3):641-6. [pmid: 15349113].
86 Gerbert B, Bronstone A, Maurer T, Berger T, McPhee SJ, Caspers N. The effectiveness of an Internet-based tutorial in improving primary care physicians' skin cancer triage skills. J Cancer Educ. 2002;17(1):7-11. [pmid: 12000111].
87 Frush K, Hohenhaus S, Luo X, Gerardi M, Wiebe RA. Evaluation of a Web-based education program on reducing medication dosing error: a multicenter, randomized controlled trial. Pediatr Emerg Care. 2006;22(1):62-70. [pmid: 16418617].
88 Carney PA, Dietrich AJ, Freeman DH Jr, Mott LA. A standardized-patient assessment of a continuing medical education program to improve physicians' cancer-control clinical skills. Acad Med. 1995;70(1):52-8. [pmid: 7826445].
89 Farrin A, Russell I, Torgerson D, Underwood M. Differential recruitment in a cluster randomized trial in primary care: the experience of the UK back pain, exercise, active management and manipulation (UK BEAM) feasibility study. Clin Trials. 2005;2(2):119-24. [pmid: 16279133].
90 Frumovitz M, Ramirez PT, Greer M, et al. Laparoscopic training and practice in gynecologic oncology among Society of Gynecologic Oncologists members and fellows-in-training. Gynecol Oncol. 2004;94(3):746-53. [pmid: 15350368].
91 Olson AL, Dietrich AJ, Prazar G, et al. Two approaches to maternal depression screening during well child visits. J Dev Behav Pediatr. 2005;26(3):169-76. [pmid: 15956865].
92 Juzych NS, Banerjee M, Essenmacher L, Lerner SA. Improvements in antimicrobial prescribing for treatment of upper respiratory tract infections through provider education. J Gen Intern Med. 2005;20(10):901-5. [pmid: 16191135]. [pmcid: 1490221].
93 Goldberg HI, Deyo RA, Taylor VM, et al. Can evidence change the rate of back surgery? A randomized trial of community-based education. Eff Clin Pract. 2001;4(3):95-104. [pmid: 11434080].
94 Sharif I, Oruwariye T, Cohen R, Ozuah PO. Effectiveness of clinician training in smoking cessation counseling. Arch Pediatr Adolesc Med. 2002;156(9):944-5. [pmid: 12197805].
95 Stein CM, Griffin MR, Taylor JA, Pichert JW, Brandt KD, Ray WA. Educational program for nursing home physicians and staff to reduce use of non-steroidal anti-inflammatory drugs among nursing home residents: a randomized controlled trial. Med Care. 2001;39(5):436-45. [pmid: 11317092].
96 Maclure M, Dormuth C, Naumann T, et al. Influences of educational interventions and adverse news about calcium-channel blockers on first-line prescribing of antihypertensive drugs to elderly people in British Columbia. Lancet. 1998;352(9132):943-8. [pmid: 9752816].
97 Rabin DL. Adapting an effective primary care provider STD/HIV prevention training programme. AIDS Care. 1998;10(Suppl 1):S75-82. [pmid: 9625896].
98 Schwartzberg JG, Guttman R. Effect of training on physician attitudes and practices in home and community care of the elderly. Arch Fam Med. 1997;6(5):439-44. [pmid: 9305686].
99 Mehler PS, Krantz MJ, Lundgren RA, et al. Bridging the quality gap in diabetic hyperlipidemia: a practice-based intervention. Am J Med. 2005;118(12):1414. [pmid: 16378790].
100 Rahme E, Choquette D, Beaulieu M, et al. Impact of a general practitioner educational intervention on osteoarthritis treatment in an elderly population. Am J Med. 2005;118(11):1262-70. [pmid: 16271911].
101 Davis RS, Bukstein DA, Luskin AT, Kailin JA, Goodenow G. Changing physician prescribing patterns through problem-based learning: an interactive, teleconference case-based education program and review of problem-based learning. Ann Allergy Asthma Immunol. 2004;93(3):237-42. [pmid: 15478382].
102 Herbert CP, Wright JM, Maclure M, et al. Better Prescribing Project: a randomized controlled trial of the impact of case-based educational modules and personal prescribing feedback on prescribing for hypertension in primary care. Fam Pract. 2004;21(5):575-81. [pmid: 15367481].
103 Anderson JF, McEwan KL, Hrudey WP. Effectiveness of notification and group education in modifying prescribing of regulated analgesics. Can Med Assoc J. 1996;154(1):31-9. [pmid: 8542565]. [pmcid: 1488091].
104 Ozer EM, Adams SH, Lustig JL, et al. Increasing the screening and counseling of adolescents for risky health behaviors: a primary care intervention. Pediatrics. 2005;115(4):960-8. [pmid: 15805371].
105 Soumerai SB, Avorn J. Predictors of physician prescribing change in an educational experiment to improve medication use. Med Care. 1987;25(3):210-21. [pmid: 3821226].
106 Chassin MR, McCue SM. A randomized trial of medical quality assurance. Improving physicians' use of pelvimetry. JAMA. 1986;256(8):1012-6. [pmid: 3735627].
107 Perera DR, LoGerfo JP, Shulenberger E, Ylvisaker JT, Kirz HL. Teaching sigmoidoscopy to primary care physicians: a controlled study of continuing medical education. J Fam Pract. 1983;16(4):785-8. [pmid: 6833967].
108 Schectman JM, Schroth WS, Verme D, Voss JD. Randomized controlled trial of education and feedback for implementation of guidelines for acute low back pain. J Gen Intern Med. 2003;18(10):773-80. [pmid: 14521638]. [pmcid: 1494929].
109 Ray WA, Stein CM, Byrd V, et al. Educational program for physicians to reduce use of non-steroidal anti-inflammatory drugs among community-dwelling elderly persons: a randomized controlled trial. Med Care. 2001;39(5):425-35. [pmid: 11317091].
110 Dietrich AJ, Olson AL, Sox CH, Winchell CW, Grant-Petersson J, Collison DW. Sun protection counseling for children: primary care practice patterns and effect of an intervention on clinicians. Arch Fam Med. 2000;9(2):155-9. [pmid: 10693733].
111 Gonzales R, Steiner JF, Lum A, Barrett PH Jr. Decreasing antibiotic use in ambulatory practice: impact of a multidimensional intervention on the treatment of uncomplicated acute bronchitis in adults. JAMA. 1999;281(16):1512-9. [pmid: 10227321].
112 Cummings SR, Richard RJ, Duncan CL, et al. Training physicians about smoking cessation: a controlled trial in private practice. J Gen Intern Med. 1989;4(6):482-9. [pmid: 2685206].
113 Cummings SR, Coates TJ, Richard RJ, et al. Training physicians in counseling about smoking cessation. A randomized trial of the “Quit for Life” program. Ann Intern Med. 1989;110(8):640-7. [pmid: 2930094].
114 Kottke TE, Brekke ML, Solberg LI, Hughes JR. A randomized trial to increase smoking intervention by physicians. Doctors Helping Smokers, Round I. JAMA. 1989;261(14):2101-6. [pmid: 2926945].
115 Lindsay-McIntyre E, Wilson D, Best JA, et al. The impact of a continuing education package for smoking cessation on physicians' clinical behavior and patient smoking. Res Med Educ. 1987;26:14-9. [pmid: 3454577].
116 Stross JK, Bole GG. Evaluation of an educational program for primary care practitioners, on the management of osteoarthritis. Arthritis Rheum. 1985;28(1):108-11. [pmid: 3966934].
117 Cummings SR, Richard RJ, Duncan CL, et al. Training physicians about smoking cessation: A controlled trial in private practices. J Gen Intern Med. 1989;4(6):482-9. [pmid: 2685206].
118 Margolis PA, Lannon CM, Stuart JM, Fried BJ, Keyes-Elstein L, Moore DE Jr. Practice based education to improve delivery systems for prevention in primary care: randomised trial. Br Med J. 2004;328(7436):388. [pmid: 14766718]. [pmcid: 341391].
119 McClellan WM, Millman L, Presley R, Couzins J, Flanders WD. Improved diabetes care by primary care physicians: results of a group-randomized evaluation of the Medicare Health Care Quality Improvement Program (HCQIP). J Clin Epidemiol. 2003;56(12):1210-7. [pmid: 14680672].
120 Clark NM, Gong M, Schork MA, et al. Impact of education for physicians on patient outcomes. Pediatrics. 1998;101(5):831-6. [pmid: 9565410].
121 Moran JA, Kirk P, Kopelow M. Measuring the effectiveness of a pilot continuing medical education program. Can Fam Physician. 1996;42:272-6. [pmid: 9222576]. [pmcid: 2146281].
122 Browner WS, Baron RB, Solkowitz S, Adler LJ, Gullion DS. Physician management of hypercholesterolemia. A randomized trial of continuing medical education. West J Med. 1994;161(6):572-8. [pmid: 7856157]. [pmcid: 1022738].
123 Bunting PS, Van Walraven C. Effect of a controlled feedback intervention on laboratory test ordering by community physicians. Clin Chem. 2004;50(2):321-6. [pmid: 14684622].
124 Ockene IS, Hebert JR, Ockene JK, Merriam PA, Hurley TG, Saperia GM. Effect of training and a structured office practice on physician-delivered nutrition counseling: the Worcester-Area Trial for Counseling in Hyperlipidemia (WATCH). Am J Prev Med. 1996;12(4):252-8. [pmid: 8874688].
125 Adams A, Ockene JK, Wheller EV, Hurley TG. Alcohol counseling: physicians will do it. J Gen Intern Med. 1998;13(10):692-8. [pmid: 9798817]. [pmcid: 1500899].
126 Hagen BF, Armstrong-Esther C, Quail P, et al. Neuroleptic and benzodiazepine use in long-term care in urban and rural Alberta: characteristics and results of an education intervention to ensure appropriate use. Int Psychogeriatr. 2005;17(4):631-52. [pmid: 16246262].
127 Solomon DH, Katz JN, La Tourette AM, Coblyn JS. Multifaceted intervention to improve rheumatologists' management of glucocorticoid-induced osteoporosis: a randomized controlled trial. Arthritis Rheum. 2004;51(3):383-7. [pmid: 15188323].
128 Pazirandeh M. Does patient partnership in continuing medical education (CME) improve the outcome in osteoporosis management?. J Contin Educ Health Prof. 2002;22(3):142-51. [pmid: 12227236].
129 Thom DH. Training physicians to increase patient trust. J Eval Clin Pract. 2000;6(3):245-53. [pmid: 11083035].
130 Schectman JM, Kanwal NK, Schroth WS, Elinsky EG. The effect of an education and feedback intervention on group-model and network-model health maintenance organization physician prescribing behavior. Med Care. 1995;33(2):139-44. [pmid: 7837822].
131 Casebeer LL, Klapow JC, Centor RM, et al. An intervention to increase physicians' use of adherence-enhancing strategies in managing hypercholesterolemic patients. Acad Med. 1999;74(12):1334-9. [pmid: 10619013].
132 Gullion DS, And Others. Management of hypertension in private practice: a randomized controlled trial in continuing medical education. J Contin Educ Health Prof 1988;8(4):239–55.
133 Lin EH, Simon GE, Katzelnick DJ, Pearson SD. Does physician education on depression management improve treatment in primary care?. J Gen Intern Med. 2001;16(9):614-9. [pmid: 11556942]. [pmcid: 1495259].
134 Socolar RR, Raines B, Chen-Mok M, Runyan DK, Green C, Paterno S. Intervention to improve physician documentation and knowledge of child sexual abuse: a randomized, controlled trial. Pediatrics. 1998;101(5):817-24. [pmid: 9565408].
135 Brown R, Bratton SL, Cabana MD, Kaciroti N, Clark NM. Physician asthma education program improves outcomes for children of low-income families. Chest. 2004;126(2):369-74. [pmid: 15302719].
136 Sibley JC, Sackett DL, Neufeld V, Gerrard B, Rudnick KV, Fraser W. A randomized trial of continuing medical education. N Engl J Med. 1982;306(9):511-5. [pmid: 7057858].
137 Kim CS, Kristopaitis RJ, Stone E, Pelter M, Sandhu M, Weingarten SR. Physician education and report cards: do they make the grade? Results from a randomized controlled trial. Am J Med. 1999;107(6):556-60. [pmid: 10625023].
138 Levinson W, Roter D. The effects of two continuing medical education programs on communication skills of practicing primary care physicians. J Gen Intern Med. 1993;8(6):318-24. [pmid: 8320576].
139 Schectman JM, Elinsky EG, Pawlson LG. Effect of education and feedback on thyroid function testing strategies of primary care clinicians. Arch Intern Med. 1991;151(11):2163-6. [pmid: 1683220].
140 Beaulieu MD, Rivard M, Hudon E, Beaudoin C, Saucier D, Remondin M. Comparative trial of a short workshop designed to enhance appropriate use of screening tests by family physicians. Can Med Assoc J. 2002;167(11):1241-6. [pmid: 12451077]. [pmcid: 134133].
141 Tziraki C, Graubard BI, Manley M, Kosary C, Moler JE, Edwards BK. Effect of training on adoption of cancer prevention nutrition-related activities by primary care practices: results of a randomized, controlled study. J Gen Intern Med. 2000;15(3):155-62. [pmid: 10718895]. [pmcid: 1495352].
142 Gifford DR, Holloway RG, Frankel MR, et al. Improving adherence to dementia guidelines through education and opinion leaders. A randomized, controlled trial. Ann Intern Med. 1999;131(4):237-46. [pmid: 10454944].
143 Pimlott NJ, Hux JE, Wilson LM, Kahan M, Li C, Rosser WW. Educating physicians to reduce benzodiazepine use by elderly patients: a randomized controlled trial. Can Med Assoc J. 2003;168(7):835-9. [pmid: 12668540]. [pmcid: 151988].
144 McBride P, Underbakke G, Plane MB, et al. Improving prevention systems in primary care practices: the Health Education and Research Trial (HEART). J Fam Pract. 2000;49(2):115-25. [pmid: 10718687].
145 Howe HL, Lehnherr M, Katterhagen JG. Effects of physician outreach programs on rural-urban differences in breast cancer management. J Rural Health. 1997;13(2):109-17. [pmid: 10169317].
146 Goldstein MK, Lavori P, Coleman R, Advani A, Hoffman BB. Improving adherence to guidelines for hypertension drug prescribing: cluster-randomized controlled trial of general versus patient-specific recommendations. Am J Manag Care. 2005;11(11):677-85. [pmid: 16268751].
147 Allison JJ, Kiefe CI, Wall T, et al. Multicomponent Internet continuing medical education to promote chlamydia screening. Am J Prev Med. 2005;28(3):285-90. [pmid: 15766617].
148 Myers RE, Turner B, Weinberg D, et al. Impact of a physician-oriented intervention on follow-up in colorectal cancer screening. Prev Med. 2004;38(4):375-81. [pmid: 15020170].
149 Fick DM, Maclean JR, Rodriguez NA, et al. A randomized study to decrease the use of potentially inappropriate medications among community-dwelling older adults in a southeastern managed care organization. Am J Manag Care. 2004;10(11 Pt 1):761-8. [pmid: 15623266].
150 Peterson L, Tremblay G, Ewigman B, Popkey C. The parental daily diary. A sensitive measure of the process of change in a child maltreatment prevention program. Behav Modif. 2002;26(5):627-47. [pmid: 12375378].
151 Wells KB, Sherbourne C, Schoenbaum M, et al. Impact of disseminating quality improvement programs for depression in managed primary care: a randomized controlled trial. JAMA. 2000;283(2):212-20. [pmid: 10634337].
152 Worrall G, Angel J, Chaulk P, Clarke C, Robbins M. Effectiveness of an educational strategy to improve family physicians' detection and management of depression: a randomized controlled trial. Can Med Assoc J. 1999;161(1):37-40. [pmid: 10420862]. [pmcid: 1232647].
153 Derebery VJ, Giang GM, Saracino G, Fogarty WT. Evaluation of the impact of a low back pain educational intervention on physicians' practice patterns and patients' outcomes. J Occup Environ Med. 2002;44(10):977-84. [pmid: 12391778].
154 Wilson DM, Taylor DW, Gilbert JR, et al. A randomized trial of a family physician intervention for smoking cessation. JAMA. 1988;260(11):1570-4. [pmid: 3411737].
155 McMahon SM, McKenna P, Hodgins JL. An application of continuing medical education to decrease excessive lengths of stay. J Med Educ. 1988;63(5):364-71. [pmid: 3361587].
156 Messina CR, Lane DS, Grimson R. Effectiveness of women's telephone counseling and physician education to improve mammography screening among women who underuse mammography. Ann Behav Med. 2002;24(4):279-89. [pmid: 12434939].
157 Goldwater SH, Milkovich G, Morrison AJ Jr, Lindgren B. Comparison of therapeutic interchange with standard educational tools for influencing fluoroquinolone prescribing. Am J Health Syst Pharm. 2001;58(18):1740-5. [pmid: 11571817].
158 Gaffan J, Dacre J, Jones A. Educating undergraduate medical students about oncology: a literature review. J Clin Oncol. 2006;24(12):1932-9. [pmid: 16622269].
159 Ravert P. An integrative review of computer-based simulation in the education process (Structured abstract). Comput Inform Nurs. 2002;20(5):203-8. [pmid: 12352106].
160 Spangler JG, George G, Foley KL, Crandall SJ. Tobacco intervention training: current efforts and gaps in US medical schools. JAMA. 2002;288(9):1102-9. [pmid: 12204079].
161 Mazmanian PE, Johnson RE, Zhang A, Boothby J, Yeatts EJ. Effects of a signature on rates of change: a randomized controlled trial involving continuing education and the commitment-to-change model. Acad Med. 2001;76(6):642-6. [pmid: 11401812].
162 Schaafsma F, Hulshof C, van Dijk F, Verbeek J. Information demands of occupational health physicians and their attitude towards evidence-based medicine. Scand J Work Environ Health. 2004;30(4):327-30. [pmid: 15458017].
163 Pereles L, Lockyer J, Hogan D, Gondocz T, Parboosingh J. Effectiveness of commitment contracts in continuing medical education. Acad Med. 1996;71(4):394. [pmid: 8645410].
164 Downing SM. Reliability: on the reproducibility of assessment data. Med Educ. 2004;38(9):1006-12. [pmid: 15327684].
165 McGaghie WC, Issenberg SB, Petrusa ER, Scalese RJ. Effect of practice on standardised learning outcomes in simulation-based medical education. Med Educ. 2006;40(8):792-7. [pmid: 16869926].