# Executive Summary

## Introduction

Continuing medical education (CME) is defined as educational activities that serve to maintain, develop, or increase the knowledge, skills, performance, and relationships a physician uses to provide services for patients, the public, or the profession. Despite the broad range of CME aimed at educating practicing physicians, researchers have found that physicians commonly overuse, under use, and misuse therapeutic and diagnostic interventions. It has been suggested that CME may not be effective enough to significantly narrow the gap between what is done in clinical practice and what should be done based on current evidence. Understanding what CME tools and techniques are most effective in disseminating and retaining medical knowledge is critical to improving the effectiveness of CME and thus diminishing the gap between evidence and practice.

To date, relatively little has been done to comprehensively and systematically synthesize evidence regarding the effectiveness of CME and the comparative effectiveness of differing instructional designs for CME in terms of impact on knowledge, attitudes, skills, practice behavior, and clinical practice outcomes. Review of evidence elucidating the value of CME (and ways the activities could be improved, if appropriate) could yield tremendous value to policy makers and professional organizations seeking to make recommendations regarding the optimal delivery of medical care.

The American College of Chest Physicians (ACCP) recognized the potential value of identifying and synthesizing the evidence in this area, and nominated this topic to the Evidence-based Practice Center (EPC) Program of the Agency for Healthcare Research and Quality (AHRQ). In response to this request by the ACCP, the Johns Hopkins EPC performed a systematic review to address the following key questions (KQ) pertaining to the effectiveness of CME:

- KQ1 Is there evidence that particular methods of delivering CME are more effective in: a) imparting knowledge to physicians, b) changing physician attitudes, c) acquiring skills, d) changing physician practice behavior, or e) changing clinical practice outcomes?
- KQ2 Do changes in knowledge, attitudes, skills, practice behavior, or clinical practice outcomes produced by CME persist over time (greater than or equal to 30 days)?
- KQ3 What is the evidence from systematic reviews about the effectiveness of simulation methods in medical education outside of CME?
- KQ4 Which characteristics of the audience by themselves or in combination with other characteristics influence the effectiveness of certain educational techniques?
- KQ5 Which external factors by themselves or in combination with other factors reinforce the effects of CME in changing behavior?
- KQ6 What is the reported validity and reliability of the methods that have been used for measuring the effects of CME in terms of: a) imparting knowledge, b) changing attitudes, c) acquiring skills, d) changing practice behavior, or e) changing clinical practice outcomes?

## Methods

To answer these questions, we identified primary literature on the effectiveness of CME and systematic reviews on the effectiveness of simulation techniques in medical education by running searches through February 2006 of the following databases: MEDLINE^®^, EMBASE^®^, the Cochrane Database of Systematic Reviews, The Cochrane Central Register of Controlled Trials (CENTRAL), the Cochrane Database of Abstracts of Reviews of Effects (DARE), PsycINFO^©^, and the Educational Resource Information Center (ERIC^®^). Additionally, we searched by hand the references of included articles and the table of contents of selected journals from February 2005 through February 2006.

Two independent reviewers conducted title scans in a parallel fashion. If either reviewer felt that a title was potentially eligible, it was promoted to abstract review. The abstract review phase was designed to identify studies reporting on the effects of CME or simulation on clinical practice in terms of knowledge, attitudes, skills, practice behaviors, or clinical outcomes. Abstracts were promoted to full article review if both reviewers agreed the abstract met our specific inclusion criteria.

Each included article underwent double review by our investigators for data abstraction and assessment of study quality. For all articles containing original data, reviewers extracted information on study characteristics (e.g., study participants, sample size, study setting, evaluation methods, and study design), CME characteristics, and outcomes. We assessed which of 16 CME methods were employed (see Table 1 in full report), such as lecture, discussion group, academic detailing, etc. - most incorporated more than one method. We also rated interventions on the extent to which the CME activity incorporated 9 adult learning principles, such as enabling learners to be active contributors to their learning, relating the curriculum to learner's current experiences, etc. The study quality form was based on the Jadad criteria. For reviews that applied to KQ 3, reviewers abstracted information on: characteristics of the review; outcomes evaluated and type of objective; meta-analyses conducted; summary of results; conclusions; and quality of the review.

Table 1 Definitions of media methods

Media method | Definition
Live | Any CME activity that is conducted in-person
Computer-based, off-line | Any CME activity that is conducted on the computer, but is not conveyed through the Internet (e.g., CD-ROM)
Internet, real-time (e.g., streaming) | Any CME activity that is conducted real-time via the Internet
Internet, not real-time | Any CME activity that is conducted via the Internet, but is not conducted in real-time
Video | Any CME activity that uses a videotape to convey its message
Audio | Any CME activity that uses an audiotape to convey its message
Handheld | Any CME activity that involves handheld materials (e.g., laminated card)
Print | Any CME activity that is conducted via educational printed materials or readings

We graded the quantity, quality, and consistency of the available evidence addressing KQs 1, 2, and 3 by adapting an evidence grading scheme recommended by the GRADE Working Group. We applied evidence grades to bodies of evidence on each type of objective (i.e., knowledge, attitudes, skills, practice behaviors, and clinical outcomes).

## Results

### Key Question 1: Is there evidence that particular methods of delivering CME are more effective in: a) imparting knowledge to physicians, b) changing physician attitudes, c) acquiring skills, d) changing physician practice behavior, or e) changing clinical practice outcomes?

### Key Question 2: Do changes in knowledge, attitudes, skills, practice behavior, or clinical practice outcomes produced by CME persist over time (greater than or equal to 30 days)?

#### Knowledge Outcomes

- A total of 39 studies addressed 41 knowledge objectives. Only 28 of those studies had a control group.
- Seventy-eight percent of the 28 studies with an adequate control group demonstrated that CME activities were effective at improving knowledge with the majority (68 percent) of these studies demonstrating long-term improvements in knowledge.
- The studies were heterogeneous, making it difficult to determine how results differed according to media type, educational technique, or number of exposures.
- The only recognized trends regarding differences by media type were that combine multimedia interventions (e.g., use of live and print media) were better than a single media intervention and that print interventions were either not beneficial or very weak in their ability to improve knowledge. We defined “media” as the method through which the CME activity is delivered.
- When these studies were reviewed according to educational technique, it appeared that multiple techniques that most commonly included case-based learning were more likely to improve knowledge when compared to a single technique. Case-based learning is an educational technique where actual or authored clinical cases are created to highlight learning objectives; clinical material is presented and followed with questions usually determined by the instructor.
- The evidence also suggested that multiple exposures produced better knowledge gains than a single exposure to content. Exposure was defined as one session versus more than one. An additional session could have used print media, computer media, a repeat live performance, or audio tape.

#### Attitudinal Outcomes

- A total of 35 studies addressed 45 attitude objectives. Thirty one of the studies had a control group.
- Seventy-one percent of the 31 studies with an adequate control group demonstrated that CME activities were effective at improving attitudes, such as attitudes regarding use of screening tests or clinical management options. The majority (68 percent) of these studies demonstrated long-term improvements in attitudes.
- The studies were heterogeneous, again making it difficult to determine how results differed according to media type, educational technique, or number of exposures.
- The only recognized trends regarding differences by media type were that multimedia interventions were better than a single media intervention and that print interventions were either not beneficial or very weak in their ability to improve attitudes.
- The only recognized trend regarding differences by educational technique was that use of multiple techniques that most commonly include case-based learning seemed to be more likely to improve attitudes than use of a single technique.
- The evidence suggested a trend toward multiple exposures being of greater benefit for attitudinal change then a single exposure, although it must be pointed out that all seven studies that evaluated a single exposure indeed demonstrated improvements in attitudes.

#### Skill Outcomes

- Twelve (80 percent) of the 15 studies that reported skill outcomes involved cognitive skills (i.e., ability to apply knowledge), with the remaining three involving psychomotor skills (i.e., procedures or physical examination techniques). Little can be said about the effectiveness of CME for psychomotor skills given the paucity of data in this area.
- Seven (47 percent) of the 15 studies reporting skill outcomes had an evaluation beyond 30 days after the CME activity. Six of seven studies addressed the long-term effect of CME on cognitive skills and five of the six demonstrated a positive effect.
- Given the dominance of live methods (seven live, four print, two video, two audio, three Internet/computer) among the studies that met their skill objectives, the data suggested that live methods had the greatest impact on the effectiveness of CME regarding skill-related outcomes. Given the paucity of data and the varied results, little can be said about the relative effectiveness of other CME media methods on skills. Based on the limited data, it is difficult to draw conclusions on particular media methods that have an impact on skill long-term.
- Given the limited number of studies, the wide variety of techniques described, and the conflicting results, it is difficult to draw conclusions about the educational techniques that have the greatest short- and long-term effects on skills.
- Most of the studies that met their skill objectives had multiple exposures to the CME activity as did most of the studies that evaluated the long-term effect on skills.

#### Practice Behavior Outcomes

- A total of 105 studies evaluated the impact of CME on short- and long-term physician practice behavior objectives, and 61 (58 percent) of the studies met practice objectives. Fifty studies with evaluation duration greater than 30 days met objectives, suggesting not only short-term, but also long-term CME effectiveness.
- Most studies that evaluated the impact of different types of CME media found that use of single live media had both a short- and long-term effect on practice behavior objectives, and that single print media is ineffective. Most of the studies suggested that multimedia-based CME have both a short- and long-term effect on practice behavior objectives.
- Of the studies evaluating the short- and long-term impact of different types of CME techniques on practice behavior objectives, most reported mixed results for a single technique, and overall effectiveness for use of multiple techniques. The use of multiple techniques may be advantageous over the use of a single technique.
- Most studies evaluating the short- and long-term impact of different volumes of exposure to CME on practice behavior objectives suggested that both single and multiple exposures are effective overall.

#### Clinical Outcomes

- Thirty-seven studies evaluated the impact of CME on clinical outcomes.
- Only one of the 37 studies measured short-term clinical outcomes and it suggested an inconclusive effect. Three of the studies did not report the time at which clinical outcomes were measured.
- Of the 33 studies that measured long-term clinical outcomes, 14 (42 percent) were successful in demonstrating a beneficial effect of CME.
- When evaluating the impact of different types of CME media on long-term clinical outcomes, the use of multiple media was more effective than use of single media in six of the seven studies that made this comparison.
- Of the five studies that compared clinical outcomes with use of single versus multiple educational techniques in CME, three showed that multiple techniques were superior to a single technique.
- In four (57 percent) of the seven studies that evaluated the impact of a single CME exposure on clinical outcomes, the CME objective was met. However, insufficient data were available on whether multiple CME exposures produce better clinical outcomes than single exposure CME.

### Key Question 3: What is the evidence from systematic reviews about the effectiveness of simulation methods in medical education outside of CME?

- Eight reviews evaluated the role of simulation in skill acquisition, while two reviews evaluated the role of simulators in knowledge acquisition. Simulation methods used in these reviews included computer simulations (e.g., learning cardiovascular physiology), virtual reality (e.g., learning laparoscopic procedures), standardized patients (e.g., learning effective communication), and manikins (e.g., learning physical diagnosis).
- Overall, the direction of evidence pointed to the effectiveness of simulation training, especially in psychomotor skills (i.e., procedures or physical examination techniques) and communication skills.
- The strength of the evidence was considered low, due to the small number of appropriate studies, the scarcity of quantitative data, and a number of study limitations.

### Key Question 4: Which characteristics of the audience by themselves or in combination with other characteristics influence the effectiveness of certain educational techniques?

- Thirteen studies examined the influence of audience characteristics on the educational intervention. These included such characteristics as age, gender, practice setting, and years in practice, among others.
- The small and heterogeneous studies available did not allow us to reach definitive conclusions regarding the influence of audience characteristics on the effectiveness of CME.

### Key Question 5: Which external factors by themselves or in combination with other factors reinforce the effects of CME in changing behavior?

- Five studies examined the influence of external factors on the educational intervention. The small and heterogeneous studies available did not allow us to reach definitive conclusions regarding the influence of external factors on the effectiveness of CME.

### Key Question 6: What is the reported validity and reliability of the methods that have been used for measuring the effects of CME in terms of: a) imparting knowledge, b) changing attitudes, c) acquiring skills, d) changing practice behavior, or e) changing clinical practice outcomes?

- Forty-five of 136 articles (33 percent) reported the validity and/or reliability within the study population of at least one evaluation method for assessing the effectiveness of CME, for a total of 61 methods. Validity refers to the degree to which a method truly measures what it is intended to measure. Reliability refers to the consistency or reproducibility of measurements.
- Of the 61 evaluation methods with validity or reliability reported, 29 evaluation methods were drawn from previous studies, and 24 were created for the current studies. For eight methods, the source was unclear. Authors frequently did not report reliability testing within the new study population for methods found to be reliable in other populations.
- Of 61 evaluation methods with validity or reliability reported, 16 (26 percent) included descriptions of validity alone, 28 (46 percent) included descriptions of reliability alone, and nine (15 percent) had descriptions of both validity and reliability. For six methods (10 percent), the methods were described as valid and/or reliable, but the specific type of validity or reliability was not reported.
- The most common type of outcome evaluated by valid and/or reliable evaluation methods involved practice behaviors, for 31 out of 61 methods (51 percent). Knowledge or cognitive skills were evaluated by 15 methods (24 percent). Attitudes were evaluated by seven methods (12 percent). Skills were evaluated by 11 methods (18 percent). Clinical outcomes (with or without practice behaviors) were evaluated by 8 methods (13 percent).
- Among these 61 methods, content validity (i.e., the degree to which an instrument accurately represents the skill or characteristic it was designed to measure) was the most commonly reported type of validity (27 percent).
- Among these 61 methods, inter-rater reliability (28 percent) and internal consistency (23 percent) were the most common types of reliability reported. Inter-rater reliability is the degree to which measurements are the same when obtained by different persons. Internal consistency is a measure of how well items reflecting the same construct yield similar results.

## Discussion

### Conclusions

Overall, despite the generally low quality of the evidence, most of the studies reviewed suggested that CME is effective, at least to some degree, in not only achieving, but also in maintaining the objectives studied. Despite the wide variety of CME techniques, media, and exposures used, and the heterogeneity of the studies, we found common themes among studies which applied across objectives. For example, when assessing the effectiveness of CME across domains, print media seemed to be less effective than live media, and multimedia activities generally seemed more effective than single media. In addition, interactive techniques seem to be more effective than non-interactive ones, and multiple exposures to the CME activity seem to be more effective than a single exposure. Thus, the evidence supports consideration of these attributes of effective educational interventions when designing a CME course.

We evaluated the effect of simulation methods in medical education by conducting a review of systematic reviews. Although we found that simulation training generally was effective, especially in the dissemination of psychomotor skills (e.g., procedures or physical examination techniques), studies which examined simulation did not review outcomes along the entire continuum of domains (i.e., knowledge through clinical outcomes), and were heterogeneous enough that few other conclusions could be drawn.

We also studied whether certain internal (audience) and external characteristics or factors may affect the effectiveness of CME. We found that the small and heterogeneous studies available did not allow us to reach definitive conclusions regarding the influence of audience characteristics or external factors on the effectiveness of CME.

### Limitations

This review has several important limitations. The heterogeneous nature of the studies precludes a quantitative summary of the effectiveness of CME. The educational interventions studied targeted different types of audiences, using multiple types of objectives across diverse content areas. This makes it difficult to generalize results from one field of CME to another.

Furthermore, we cannot draw firm conclusions about the effectiveness of CME because of the generally low quality of study designs, the variable quality of reporting in studies, and the lack of valid and reliable CME evaluation tools. Although we used a comprehensive search strategy, we cannot rule out some degree of publication bias. The review does point out a lack of standardization of approaches to CME research in general, including the lack of standardization for definitions of controls. The CME literature in general lacks standardization of terminology related to media type, educational techniques, and exposure volume, which makes it difficult to determine the impact of these factors on the effectiveness of CME.

### Future Research Implications

- Educators should develop strategies for identifying and prioritizing the gaps in our knowledge about CME that should be the focus of further research.
- More randomized controlled studies of CME should be performed with clear definition of intervention and control groups and measurement of effectiveness at multiple points post-intervention. Such studies should focus on high priority areas given the resource limitations that educators face in conducting research on CME.
- To advance such research on CME, leaders in medical education could develop a national agenda on what is needed most to improve the effectiveness of CME.
- In developing a national agenda for research on CME, educational leaders should establish a clear definition of what constitutes CME. For example, does quality improvement or practice improvement alone constitute CME?
- Future research on CME should include development of more standardized approaches to describe CME interventions, media, techniques, and exposure volumes.
- Further studies should examine emerging methods of CME such as Internet-based CME that could be available to clinicians at the point of care.
- Future research on CME should be based on a sound conceptual model of what influences the effectiveness of CME.