# Acknowledgments

The Evidence-based Practice Center thanks Karen Robinson for her assistance in developing the search strategies; Lori Bash, Gabriel Lai, Rachel Millstein, and Chidinma Ibe for their assistance with article reviewing and data entry; Renee Wilson, Brenda Zacharko, and Laura Barnes for their assistance with final preparations of the report.