# Discussion

## Conclusions

We conducted a systematic review of the medical literature to evaluate the effectiveness of CME in improving knowledge, attitudes, skills, physician behavior and clinical outcomes. Overall, despite the generally low quality of the evidence, most of the studies reviewed suggest that CME is effective, at least to some degree, in not only achieving, but also in maintaining the objectives studied. Despite the wide variety of CME techniques, media, exposures used, and despite the heterogeneity of the studies reviewed, we found common themes among studies which applied across objectives. For example, when assessing the effectiveness of CME across domains, print media seem to be less effective than live media, and multimedia generally seem to be more effective than single media. In addition, interactive techniques seem to be more effective than non-interactive ones, and multiple exposures to the CME activity seem to be more effective than single exposure. Thus, the evidence supports consideration of these attributes of effective educational interventions when designing a CME course.

To ascertain whether broader lessons could be drawn from the non-CME medical education realm, we evaluated the effect of simulation methods in medical education by conducting a review of systematic reviews. Although we found that simulation training generally was effective, especially in the dissemination of psychomotor skills (e.g., procedures or physical examination techniques), studies which examined simulation did not review outcomes along the entire continuum of domains (i.e., knowledge through clinical outcomes), and were heterogeneous enough that few other conclusions could be drawn.

We also studied whether certain internal (audience) and external characteristics or factors, special to the environment, the participants or the course, may affect the effectiveness of CME. We found that the small and heterogeneous studies available did not allow us to reach definitive conclusions regarding the influence of audience characteristics or external factors on the effectiveness of CME. This is an area where further study might yield useful results in asking whether it might be important to marry the CME activity offered with those particular characteristics which might enhance its effectiveness and value.

## Limitations

This evidence report has a number of limitations. First, the heterogeneous nature of the studies inhibits a quantitative summary of the effectiveness of CME. There is a lack of standardization of the definition of CME or associated performance improvement. The educational interventions studied targeted different types of audiences, using multiple types of objectives, across diverse content areas. Thus, comparing the effectiveness of educational methods and techniques across studies is challenging. Even if multiple studies shared comparable objectives, we found that authors did not use standardized reporting of results - such as effect sizes - prohibiting a quantitative meta-analysis of the results. Given these limitations, we had to pursue a qualitative synthesis of the available data.

Second, the generally low quality of study designs limits our ability to draw firm conclusions about the effectiveness of CME. Although we limited the review to studies with comparison groups, including a large number of randomized control trials, many studies lacked adequate descriptions of randomization methods or techniques for adjusting for baseline group differences. Moreover, too many of the articles we studied were published with comparison groups but did not have a control group, which did not allow us to evaluate effectiveness. In addition, only one-fifth of the studies described blinding of those evaluating the outcomes, leaving open the potential for biased assessment.

Third, the quality of reporting was variable. Authors rarely described the study design and the interventions in enough detail to allow reproducibility. In particular, studies rarely described specific learning objectives, prohibiting assessment of whether objectives matched appropriately to the evaluation methods/outcomes.

Fourth, the lack of valid and reliable CME evaluation tools leaves open the possibility of overestimation or underestimation of the effectiveness of CME. Most studies lacked psychometric data regarding their evaluation methods. Thus, the evaluation methods may not have truly assessed the outcomes targeted by the educational interventions. In addition, evaluation methods with poor reliability may fail to detect actual improvements in outcomes.

Fifth, our search strategy may be subject to some publication bias. Our search was limited to published English-language articles about educational studies within the United States and Canada. Our review does not include studies from other countries where high quality CME studies have been conducted. As indicated in the Methods chapter, this methodological choice was made because the medical education systems in other countries are very different from the system in the United States, thereby limiting the applicability of such studies to CME in the United States. Also, educational studies with negative findings are less likely to be published, potentially leading to overestimation of the effectiveness of CME.

Sixth, there is a lack of standardization of approaches to CME research in general, i.e., no Phase 1, Phase 2, Phase 3-like process that crafts an organized approach to how aims are set up and how comparative groups are organized. This includes the lack of standardization for definitions of controls.

Seventh, there is general lack of standardization of terminology related to media, techniques, exposure volume, etc, which makes studying the impact of different methods, techniques, exposures etc. on the effectiveness of CME difficult.

Finally, several limitations were specific to particular key questions:

For Key Questions 1 and 2, this report does not systematically review the effectiveness of quality improvement interventions. Although we included quality improvement studies if they included a physician education component, our search strategy did not systematically target all quality improvement studies. Thus, we cannot draw definitive conclusions comparing the effectiveness of physician education in quality improvement interventions versus quality improvement interventions more generally.

Moreover, our conclusions are limited secondary to the heterogeneity of studies included along multiple domains. In addition, many of the studies lacked a clear control group, which did not allow effectiveness of CME to be determined, but only different effectiveness across different interventions.

For Key Question 3, conclusions are limited due to the weaknesses of the systematic reviews available, the poor quality of many of the included studies, the heterogeneity of included studies, and the rapidly evolving nature of computerized simulation.

For Key Questions 4 and 5, there was lack of standard definitions of internal and/or external factors that might impact CME. In addition, conclusions are limited due to small sample sizes prohibiting analysis based on within-group characteristics and infrequent collection of data on external and internal motivating factors. In addition, lack of standardization of tools to assess the efficacy of CME inhibited our ability to draw firm conclusions.

For Key Question 6, conclusions are limited due to inconsistent reporting of validity and reliability for evaluation methods drawn from previous studies; we may have missed some valid or reliable evaluation methods that were not described as “valid” or “reliable” and for which psychometric data was not reported.

Additional limitations for Key Question 3 include:

a) With the exception of Hmelo,^28^ these reviews were quite recent (2002-2006), and point to evolving educational methods. Virtual reality in 2001 may be difficult to compare to virtual reality in 2006. The computer assisted instruction described in the review by Hmelo^28^ is already dated.
b) No review included tests for publication bias, which would be highly anticipated with any new technology.
c) Simulation can include a variety of tasks and procedures, with varying lengths and complexities. Some studies included partial task simulators with complex surgical and endoscopic procedures; pooling such disparate skills may be inappropriate.
d) One of the major advantages of simulation over standard medical education training for procedures should be the opportunity to practice and receive feedback in a shorter period of time. No study explored this important contributor to effectiveness, i.e., the frequency and intensity of the simulation method and whether there is a “dose-response” effect with the use of simulation and the outcome of clinical skills competence. This aspect was assessed by a systematic review published after our literature search which found an association between hours of practice on high-fidelity simulators and standardized learning outcomes.^165^
e) There is no consensus on the appropriate outcome measures for effectiveness of simulation. Haque,^26^ Sutherland,^31^ Gerson,^30^ Aucar,^29^ and Issenberg^27^ all included validity studies within their reviews, but heterogeneity of tasks and simulators again makes it difficult to pool results.
f) Although nearly every review included a careful description of search methodology, most fell short in nearly every quality measure of a systematic review. The exception, Issenberg^27^ is an example of a high quality systematic review of an educational topic; the authors unfortunately did not address the outcome of interest to Key Question 3.
g) For Key Question 3, systematic reviews that addressed the use of simulation in CME educational activities were excluded as this aspect was covered by our other Key Questions. It is possible that systematic reviews of the efficacy of simulation in CME activities may reach a different conclusion.

## Future Research Implications

We believe that assessing those factors that make CME more or less effective will be important for the planning of effective CME activities in the future. Although the overall quality of the studies was low, there were a few important trends. CME appears to be generally effective not only in the acquisition or achievement of knowledge, attitudes, skills, behaviors, and clinical practice outcomes, but also in their retention, and there are certain techniques, methods or exposures which seemed to be better than others. Unfortunately, most studies did not describe multiple evaluation points after the intervention, which did not allow us to determine at what point the CME effect, when persistent, became extinguishable and might have needed reinforcement. To enable future systematic reviews of CME, study researchers should refer to an excellent review by Reed et al, which summarizes guidelines for standardization in the conduct and reporting of educational interventions.^11^

Simulation, as a teaching tool, has the potential to affect patient safety and clinical outcomes, but no study included in this review used a patient-based clinical outcome as a measure of effectiveness. Future research should seek to determine the impact of simulation in improving clinical outcomes.

We believe that educators should develop strategies for identifying and prioritizing the gaps in our knowledge about CME that should be the focus of additional research. Future research should include high quality randomized controlled studies of CME with clear intervention and control groups and measurement of effectiveness at multiple points post-intervention. Such studies should focus on high priority areas given the resource constraints that educators typically face in conducting research on CME. Educators will need to use a variety of study designs, including qualitative research methods, because it will not be feasible to perform randomized controlled trials on many of the issues. Indeed, it will be difficult to rely too heavily on randomized controlled trials given the difficulty of creating and maintaining effective control groups.

To advance research on CME, leaders in medical education could develop a national agenda on what is needed to improve the effectiveness of CME. Such an agenda should include a clear definition of what constitutes CME. For example, whether quality improvement or practice improvement alone should have been included in our evaluation presented a dilemma. We decided that there needed to be a well-defined educational intervention for us to include quality improvement or practice improvement studies in our review of the effectiveness of CME. The agenda for future research should include development of more standardized approaches to the description of CME interventions, media, techniques, and exposure volumes. Ideally, the agenda would be based on a sound conceptual model of what influences the effectiveness of CME, including participating physician perspectives. Given the large amount of time, effort and money invested in CME, it seems reasonable to invest in a national consensus conference that could help to lay the foundation for a comprehensive research agenda for CME. In addition, greater resources should be devoted to funding educational researchers to design higher quality CME studies as well as the tools to evaluate CME outcomes.