# Results

## Results of Review of Primary Literature

A summary of the search results for the primary literature review is presented in Figure 1. From the search, we retrieved 59,116 unique citations. After reviewing the titles and abstracts, 659 seemed eligible for further review and the full articles were retrieved. A total of 136 primary literature articles are included in this review.

Figure 1. Summary of literature search and review process for primary literature (number of articles)

## Results of Review of Systematic Reviews

A summary of the search results for the review of systematic reviews is presented in Figure 2. The search yielded 1617 unique citations. After reviewing the titles and abstracts, 43 seemed eligible for review and they were retrieved for further review. A total of nine systematic review articles are included in this review.

Figure 2. Summary of literature search and review process for systematic reviews (number of articles)

## Summary of Study Characteristics and Evaluation Methods

Over two-thirds (68 percent) of the studies were randomized controlled trials; the remaining studies were predominantly non-randomized controlled trials (see Appendix F^*^Evidence Table 1). An evaluation was conducted both before and after the intervention in 76 percent of the randomized controlled trials and 88 percent of the non-randomized trials.

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/cmetp.htm

Participant questionnaire was the most frequently used evaluation method (59 percent of the studies). Of those that used a participant questionnaire, over two-thirds (69 percent) used a written questionnaire. A few studies administered the questionnaire via computer (5 studies), orally (5), or over the phone (7). About half (47 percent) of the studies used a performance audit to evaluate the CME program. Performance audits were usually conducted through chart review (39 studies) and health plan databases (18). Patient questionnaires were used in 39 studies. Twenty studies included a qualitative evaluation. Seventeen studies evaluated the CME program through observer assessment. Most of these studies used a live standardized patient to assess the observer (11 studies).

## Summary of Study Participants and Study Setting

The CME participants in most of the studies were exclusively fully-trained physicians (see Appendix F, Evidence Table 2). Other CME participants in the other studies most often included nurse practitioners, physician assistants, or nurses. Family medicine (73 studies), internal medicine (58 studies), general medicine (32 studies), pediatrics (21 studies), and primary care (18 studies) were the most common specialties included in the studies. Most study participants worked in private practice (52 studies), for health plans (32 studies), or in hospitals (19 studies). Many of the studies did not report on other characteristics of the study participants. Gender, age and years of training/experience were reported in 50 percent, 28 percent, and 34 percent of studies.

One-third of the studies did not report the setting of the CME activity. In 52 studies, the CME activity occurred in the practice setting. The CME activity was not linked to a physical setting in 27 settings. Government agencies sponsored about 40 percent of the studies. Pharmaceutical agencies, professional societies, and insurance/health plan companies sponsored about 10 percent of the studies each. In about two-thirds of the studies, some type of physician, the majority of which were academic, taught the CME activity. The type of educator was not mentioned in about one-quarter of the studies.

## Summary of CME Activity Characteristics

Table 4 provides an overview of the characteristics of the CME activities evaluated (for details of the characteristics of CME activities, see Appendix F^*^Evidence Table 3). Fifty studies evaluated a single media method. The most common single media method used in the CME activity was live (29 studies). Print media was evaluated in 14 studies and the Internet in 6 studies. Nearly half of the studies used multiple media methods in the CME activities they were evaluating. Eighteen studies compared using a single media method to using multiple media methods. The type of media was not reported in one study.

Table 4 Summary of CME Activity Characteristics

Type of CME activity | Number (%) of studies
Media method
Single media used in CME activity | 50 (37)
Live only media | 29 (21)
Print only media | 14 (10)
Internet only media | 6 (4)
Other type of single media | 4 (3)
Multiple media used in CME activity | 67 (49)
Single vs. multiple media used in CME activity | 18 (13)
Type of media not reported | 1 (1)
Educational technique
Single technique used in CME activity | 13 (10)
Multiple techniques used in CME activity | 95 (70)
Single vs. multiple techniques used in CME activity | 25 (18)
Type of technique not reported | 3 (2)
Amount of exposure
Exposed to CME activity once | 44 (32)
Exposed to CME activity multiple times | 69 (51)
One vs. multiple exposures to CME activity | 12 (9)
Other amount of exposure | 7 (5)
Amount of exposure not reported | 4 (3)

Most (70 percent) of the studies used multiple educational techniques in the CME activity. Twenty-five studies compared using a single educational technique to using multiple educational techniques. Thirteen studies evaluated a single technique. Six articles evaluated reading only,^13^–^18^ two evaluated only academic detailing,^19^,^20^ and one evaluated each of the following: problem-based learning,^21^ conference calls,^22^ feedback,^23^ lecture,^24^ and lecture versus case-based learning.^25^

The participants were exposed to the CME activity only once in about a third of the studies and multiple times in about half. Twelve studies compared participants who were exposed once to a CME activity to participants who were exposed multiple times.

The CME activities were designed for individuals in 90 studies and practice settings/teams in 24 studies. For 17 studies, the CME activities were designed for both individuals and practice settings/teams. The CME activity was reported as being accredited in about a quarter (31 studies) of the studies.

In 41 studies, the CME activity was a part of a quality improvement project. CME activities that were a part of quality improvement projects used multiple media methods significantly more often than CME activities with no quality improvement project (63% versus 43%; p=0.03). CME activities with quality improvement projects were also significantly less likely to use single live media (10% versus 26%; p=0.03). CME activities with and without quality improvement projects were similar to each other in terms of educational techniques and amount of exposure (data not shown).

## Study Quality of Primary Literature

More than two-thirds of the trials were randomized (see Appendix F, Evidence Table 4). Just over half of these trials described their randomization techniques adequately, while five included descriptions of suboptimal randomization schemes. Because participants in a study of an educational intervention cannot be blinded to the intervention, we evaluated the trials for evidence that the outcomes evaluation was blinded. Approximately one-fifth of the trials described a blinded evaluation, with the majority of these including adequate descriptions of the blinding technique. Only one-quarter of the trials described losses to follow-up or reasons for withdrawal. Nearly two-thirds of the trials described power calculations to detect outcomes, but one-quarter of these were not adequately powered.

Based on our quality scoring system described in the Methods chapter, over three-quarters of the trials were rated at two points or less:

- 8 studies achieved a score of 5
- 11 studies achieved a score of 4
- 12 studies achieved a score of 3
- 38 studies achieved a score of 2
- 29 studies achieved a score of 1
- 36 studies achieved a score of 0.

## Quality of the Systematic Reviews

All reviews, except one,^26^ described search methods in sufficient detail to allow replication of the reviews (see Appendix F, Evidence Table 5). All reviews used one or more electronic databases and hand-searching to identify relevant articles. However, only three reviews^26^–^28^ supplemented their search by soliciting expert opinion to identify relevant articles. Two systematic reviews^29^,^30^ did not report study inclusion (and/or exclusion) criteria and one review^28^ did not report inclusion criteria in enough detail to allow replication.

Only two reviews performed quality assessment of the studies included in the review using a validated quality scale.^27^,^30^ In addition, one review^31^ provided a descriptive assessment of study quality. Evaluation for publication bias was not reported by any review. All reviews, except one, synthesized evidence qualitatively. One review,^26^ that combined individual study results quantitatively to generate a summary effect size, used both fixed-effects and random-effects models.

Four reviews^26^,^27^,^30^,^31^ discussed the variation in the results of the original studies in a qualitative manner, one additional study^29^ discussed it only partially, and four studies did not discuss the variations in the results of the original studies. Qualitative evaluation of heterogeneity, either by subgroup analyses or meta-regression, was not performed by any of the reviews included in our study.

## Reporting of Adult Learning Principles

Only 13 percent of trials were rated as “good” in enabling learners to be active contributors to their learning, while about half of trials were rated as fair (see Appendix F, Evidence Table 6). More than three-quarters of the trials were rated as “good” in relating to learners' current work or life experiences. Only 12 percent of the trials were rated as “good” in tailoring their curricula to learners' current or past experiences, and almost half were rated as “poor.” Only 6 percent of the trials were rated as “good” in allowing learners to identify their own learning goals and direct their education, and over 80 percent were rated as “poor.” About 10 percent of trials were rated as “good” in allowing learners to practice what they learned in simulated activities, providing support to self-directed learners, and receiving feedback from teachers or peers during active learning. Two-thirds were rated as “poor” in these areas. Less than 10 percent of trials were rated as “good” in allowing learners to reflect on their learning, while three-quarters of trials were rated as “poor.” Only four trials were rated as “good” in allowing learners to observe the faculty role-model behaviors, while nearly 90 percent of trials were rated as “poor.”

A notable example of a trial that received high ratings for all adult learning principles was Gerrity et al.^32^

## Key Question 1: Is there evidence that particular methods of delivering CME are more effective in: a) imparting knowledge to physicians, b) changing physician attitudes, c) acquiring skills, d) changing physician practice behavior, or e) changing clinical practice outcomes?

## Key Question 2: Do changes in knowledge, attitudes, skills, practice behavior, or clinical practice outcomes produced by CME persist over time (greater than or equal to 30 days)?

### Knowledge Outcomes

Short-term and long-term effects of CME on knowledge (See Appendix F, Evidence Table 7).A total of 39 studies addressed 41 knowledge objectives.^17^,^19^,^25^,^32^–^67^ Eleven studies that addressed 12 objectives had a comparison group, but no control group and thus could not be utilized to determine whether or not the intervention was effective at knowledge transfer.^17^,^25^,^58^–^61^,^63^–^67^ This left 28 studies addressing 29 objectives. These studies were classified by the outcome of the objective into those in which the objective was met, objective not met, or those with mixed results. In addition, the 28 studies were classified into three groups by the duration of knowledge acquisition/retention into those studies in which the duration was not clearly reported, studies that addressed short-term knowledge changes and long-term knowledge changes.

A total of 22 studies addressing 23 objectives demonstrated improvements in knowledge.^19^,^33^–^53^ This represents 79% of the 28 studies with an adequate control group. Of these, 6 studies^33^–^38^ addressing 6 objectives did not clearly report the duration of evaluation, 1 study^39^ addressing 1 objective demonstrated short-term improvement in knowledge, and 15 studies addressing 16 objectives demonstrated long-term improvements in knowledge. The studies were too heterogeneous too identify any global similarities, but any specific information related to the type of media, educational technique or exposure volume will be addressed in those subsequent sections.

Four studies addressing four objectives failed to show improvements in knowledge.^32^,^54^–^56^ No study demonstrated a regression in knowledge. Of these four studies, one study^32^ did not clearly report on the duration of evaluation while the three remaining studies evaluated long-term knowledge changes. No study was identified that evaluated short-term knowledge and failed to show a change in knowledge. Of the three studies that considered long-term outcomes, the study by Elliott et al demonstrated trends toward improved knowledge but these slight improvements lacked statistical significance.^55^ In the remaining two studies, one failed to show improvements in knowledge regarding bioterrorist attacks through the voluntary participation in a web-based educational program and the other failed to show an improvement in knowledge regarding blood pressure control after a mailed CME program.

Two studies addressing two objectives demonstrated mixed results.^57^,^62^ One study did not clearly report on the duration of evaluation and one reported on long-term effects. The study that did not clearly report duration evaluated the impact of an educational intervention aimed at medical care evaluation committees and demonstrated a statistical improvement in only one of the three committees.^57^ The study by Chodosh et al considered an evaluation nine months after the intervention. In this study, more intervention group physicians answered knowledge-related questions on capacity determination for patients with possible dementia, but found no differences between intervention group and control group on questions regarding dementia evaluation, patient safety, or depression treatment.

In summary, 78% of the studies with an adequate control group demonstrated that CME activities were effective at improving knowledge with the majority (68%) of these studies demonstrating long-term improvements in knowledge.

Short-term and long-term effects of CME media methods on knowledge. Studies were classified by objectives met and evaluation duration as described above and by media utilized for the educational intervention. The media classifications included multi-media, single media and single versus multi-media.

As stated in the above section, 22 studies addressing 23 objectives demonstrated improvements in knowledge. Seven studies addressing eight objectives evaluated a single media intervention.^39^,^40^,^43^,^45^,^48^,^50^,^53^,^56^ Three of the studies utilized the internet and the remaining four utilized live media. The three studies that utilized the internet demonstrated improved short-term knowledge in one study^39^ and long-term knowledge in two studies.^43^,^50^ All four of the studies that utilized live media demonstrated long-term improvements in knowledge. Twelve studies addressing 12 objectives utilized multimedia interventions to demonstrate knowledge benefits.^19^,^33^–^37^,^41^,^42^,^46^,^49^,^51^,^52^ Five studies did not clearly report on the duration and seven studies demonstrated long-term improvements in knowledge. Three studies compared a single media-based intervention to a multimedia intervention.^38^,^44^,^47^ All three studies included at least one concurrent control group that only utilized print material and in all three cases multi-media outperformed the print-based single media intervention group.

The four studies that did not demonstrate improvements in knowledge utilized single media (print) in one study^56^ that evaluated long-term knowledge, multimedia (live, audio and print) in one study^32^ in which evaluation duration was not clearly defined, multimedia (live and print) in one study^55^ that considered long-term knowledge changes, and one study^54^ that compared single to multi-media for long-term benefits. In this study the comparison was between a live intervention and a live internet with non-real time reading material.

Of the two studies that demonstrated mixed results, one study^57^ utilized a single media intervention (live) and the other study^62^ utilized multimedia intervention (live internet with not real time print).

When grouped solely by media classification, 9 studies addressing 10 objectives used a single media with 7 demonstrating benefits, 15 studies addressing 15 objectives considered multi-media interventions with 12 demonstrating benefits, and 4 studies addressing 4 objectives compared single to multi-media with 3 of these studies demonstrating that multi-media interventions had greater benefit.

Given the heterogeneity of the studies the only recognized trends were that multimedia seems better than a single media intervention and that print interventions are either not beneficial or very weak in their ability to lead to improved knowledge.

Short-term and long-term effects of CME educational techniques on knowledge.Studies were classified by objectives met and evaluation duration as described above and by technique utilized for the educational intervention. The technique classifications included multiple techniques, single technique and single versus multiple techniques. Two of the studies that have not been previously included because of a lack of a control group can be utilized in this section because the concurrent comparison group did indeed utilize a different technique permitting some head to head comparisons.^25^,^66^ This means that for this section there are 30 studies addressing 31 objectives.

Only one study that met its objectives utilized a single technique, academic detailing, and this study demonstrated improvements in long-term knowledge.^19^ Eighteen studies addressing 18 objectives utilized multiple techniques to improve knowledge.^33^–^37^,^39^,^41^–^46^,^48^–^53^ Five studies^33^–^37^ that demonstrated improved knowledge did not clearly report the duration, 1 study^39^ demonstrated short-term knowledge improvement and 12 studies demonstrated long-term knowledge improvements. The majority of the studies that demonstrated improvement but did not clearly report the duration included case-based learning as a technique in combination with techniques ranging from discussion groups to independent reading. Of the 12 studies that demonstrated long-term improvements in knowledge the majority integrated multiple techniques and most commonly combined case-based learning with discussion groups with independent reading, several utilized standard lectures with readings, and some technique combinations ranged from lecture with a standardized patient to lecture with team-based training. Three studies addressing four objectives compared a single technique versus multiple techniques demonstrated improvements in knowledge.^38^,^40^,^47^ One study did not clearly report duration and two studies addressing three objectives demonstrated long-term knowledge improvements. The study that did not clearly report duration demonstrated a greater benefit to the combination of case-based learning with readings when compared to readings alone.^38^ One study that addressed two objectives compared problem-based learning to the combination of lecture and discussion groups and demonstrated that that problem-based learning group was more effective regarding knowledge of diagnosis and management of headache. The other study compared discussion groups with readings to readings alone and the combination was more effective at increasing knowledge regarding compliance adherence.

Four studies of four objectives did not demonstrate improved knowledge.^32^,^54^–^56^ One study that utilized multiple techniques that included lecture, discussion groups, role playing and feedback failed to demonstrate improved knowledge and did not clearly report the duration.^32^ Two studies failed to demonstrate improvements in knowledge despite utilizing multiple techniques.^55^,^56^ One combined lecture with case-based learning with discussion groups and readings and failed to show improvements in pain knowledge, while the other combined readings with chart cue materials and failed to show improvements in knowledge of hypertension. One study compared a single technique, lecture to a combination of techniques that included lecture with case-based learning and readings and failed to show an improvement in knowledge of bioterrorism.

The two studies that were added to this section deserve a greater explanation. Greenberg et al compared lecture to case-based learning and the case-based learners demonstrated improvements in post-test questions regarding common pediatric problems as compared to 29% improvement in the lecture group.^25^ Unfortunately, these improvements seen in the case-based group were not significant at six and nine months after the intervention. Heale et al compared three groups, one receiving lectures, one case-based learning with discussion groups, and the final group received problem-based learning.^66^ This study also failed to demonstrate benefits of any technique either in short or long-term knowledge. Thus these two studies, when added to the four above studies that did not demonstrate improvements means a total of six studies did not show improved knowledge.

One of the two studies that demonstrated mixed results did not clearly report duration while the other considered long-term knowledge improvements.^57^,^62^ The study^57^ that did not report duration compared a combination of case-based learning with discussion groups to control while the other compared lecture with discussion group to control.

When grouped solely by technique classification then two studies addressing two objectives utilized a single technique with one study showing improvements through the use of academic detailing and one showing no knowledge improvement through the use of readings alone. Twenty-three studies addressing 23 objectives utilized multiple techniques with 18 demonstrating benefits, 3 no benefits, and 2 mixed results. Five studies addressing six objectives compared single versus multiple techniques. Two studies addressing two objectives demonstrated benefits of multiple techniques as compared to single, one study addressing two objectives demonstrated benefits to single technique(problem-based learning) compared to multiple and two studies addressing two objectives did not demonstrate any benefit of single as compared to multiple techniques.

The outcomes from this section are also heterogeneous but it does appear that multiple techniques that most commonly include case-based learning seem to be more likely to be associated with improvements in knowledge.

Short-term and long-term effects of the amount of exposure on knowledge. Studies were classified by objectives met and evaluation duration as described above and by exposure volume for the educational intervention. The exposure volume classifications included multiple exposures, single exposure and single versus multiple exposures. The two studies added in the previous section do not apply to this section given the lack of control groups. In addition, one additional study^38^ did not adequately describe the exposure and thus is excluded from analysis in this section leaving 27 studies addressing 28 objectives.

There were 21 studies addressing 22 objectives which demonstrated an improvement in knowledge.^19^,^33^–^37^,^39^–^53^ Five studies addressing five objectives evaluated a single exposure volume with one study^36^ not clearly reporting the duration and four studies^44^,^45^,^48^,^53^ demonstrating long-term improvements. Three of these considered knowledge at 6 months after intervention and one at 24 months after intervention. Twelve studies addressing 12 objectives utilized multiple exposure volumes. Three studies did not clearly report duration,^33^,^35^,^37^ one study demonstrated short-term knowledge gains,^39^ and the final eight studies all demonstrated long-term knowledge gains.^19^,^41^,^43^,^46^,^49^–^52^ The shortest time interval to evaluation in these long-term beneficial studies was 3 months and the longest was 15 months. Four studies addressing five objectives compared a single exposure to multiple exposures and demonstrated knowledge gains. One study that did not clearly report duration demonstrated that multiple exposures were better than a single exposure at improving knowledge of office-based dermatologic procedures.^34^ The other three studies addressing four objectives all demonstrated that multiple exposures were better than a single exposure at improving knowledge.^40^,^42^,^47^

Four studies addressing four objectives did not demonstrate knowledge improvements. No study was identified that evaluated a single exposure only. Three studies evaluated multiple exposures with one^32^ not clearly reporting the duration and the other two^55^,^56^ failing to demonstrate long-term knowledge improvements. One study that compared single versus multiple exposures did not show any difference from baseline knowledge at one and six months after intervention in either group.^54^

No studies were identified that utilized a single exposure only or compared a single versus multiple that demonstrated mixed results. Two studies demonstrated mixed results and both utilized multiple exposures.^57^,^62^ One study^57^ did not clearly report on duration and the other study demonstrated mixed results at the nine month evaluation.

When grouped solely by exposure volume then all five studies that evaluated a single exposure demonstrated improved knowledge. Twelve of the 17 studies that utilized multiple exposures demonstrated knowledge improvements with an additional 2 demonstrating mixed results. The majority (67%) of these were able to demonstrate long-term knowledge benefits. Of the five studies that compared a single exposure to multiple exposures, four (80%) demonstrated a greater benefit to multiple exposures as compared to a single exposure.

In summary, despite the heterogeneity of these studies it appears that despite the fact that all five studies that utilized a single exposure demonstrated benefit the head-to-head comparison studies imply that when possible multiple exposures produces better knowledge gains.

Summary of the effects of CME on knowledge. The heterogeneity of the studies precludes firm conclusions, but the trends demonstrated that CME is effective at producing both short-term and long-term knowledge gains and that when possible, multimedia, multiple techniques, and multiple exposures should be used.

Quality of the evidence for the short-term and long-term effects of CME on knowledge (see Appendix F^*^, Evidence Table 8). Taking into consideration the quantity and quality, and consistency of evidence on the effectiveness of CME on knowledge, we graded the strength of evidence as very low.

### Attitude Outcomes

Short-term and long-term effects of CME on physician attitudes (See Appendix F, Evidence Table 9).A total of 35 studies addressed 45 attitude objectives.^13^,^34^–^37^,^39^,^40^,^42^,^47^,^50^,^52^,^53^,^55^,^58^,^59^,^62^–^64^,^66^,^68^–^83^ Eight studies that addressed 11 objectives had a comparison group, but no control group and thus could not be utilized to determine whether or not the intervention was effective at attitudinal change.^58^,^59^,^63^,^64^,^66^,^79^,^80^,^83^ One additional study that addressed two objectives could not be utilized as results were not reported by groups and thus its results were unclear and it was also not included.^82^ This left 26 studies addressing 32 objectives. These studies were classified by the outcome of the objective into those in which the objective was met, objective not met, or those with mixed results. In addition, the 26 studies were classified into three groups by the duration of attitudinal change into those studies in which the duration was not clearly reported, studies that addressed short-term attitudinal changes and long-term attitudinal changes.

A total of 22 studies addressing 26 objectives demonstrated improvements in attitude.^13^,^34^–^36^,^39^,^40^,^42^,^47^,^50^,^52^,^53^,^68^–^78^ This represents 71% of the 31 studies with an adequate control group. Of these, six studies addressing seven objectives did not clearly report the duration of evaluation,^13^,^34^–^36^,^68^,^69^ one study addressing two objectives demonstrated short-term improvement in attitudes,^39^ and 15 studies addressing 17 objectives demonstrated long-term improvements in attitude.^40^,^42^,^47^,^50^,^52^,^53^,^70^–^78^ The studies were too heterogeneous too identify any global similarities, but any specific information related to the type of media, educational technique or exposure volume will be addressed in those subsequent sections.

Four studies addressing four objectives failed to show improvements in attitude.^37^,^52^,^55^,^62^ No study demonstrated a regression in attitude. Of these four studies, one study^37^ did not clearly report on the duration of evaluation while the three remaining studies evaluated long-term attitudinal changes. No study was identified that evaluated short-term attitudes and failed to show a change in attitudes. Of the three studies that considered long-term outcomes, the study by Elliott et al demonstrated trends toward improved attitudes but these slight improvements lacked statistical significance.^55^ In the remaining two studies, one failed to show improvements in attitudes regarding providers' perceptions of quality of care nine months after intervention.^62^ The other failed to show an improvement in attitude regarding efficacy of cholesterol lowering practices.^52^

Two studies addressing two objectives demonstrated mixed results.^62^,^81^ Both studies reported on long-term effects. The study by Chodosh et al considered an evaluation nine months after the intervention. In this study, more intervention group physicians endorsed the statement, “Older patients with dementia are difficult to manage in primary care,” but no other differences in attitudes regarding dementia were identified.^62^ The study by Norris et al utilized an evaluation six months after intervention and noted that intervention group providers had significant improvements in three of ten tested attitudes, including they felt by self report that they were more likely to counsel patients regarding physical activity than control providers.^81^

In summary, 85 percent of the studies with an adequate control group demonstrated that CME activities were effective at improving attitudes with the majority (68%) of these studies demonstrating long-term improvements in attitudes.

Short-term and long-term effects of CME media methods on physician attitudes.Studies were classified by objectives met and evaluation duration as described above and by media utilized for the educational intervention. The media classifications included multi-media, single media and single versus multi-media.

As stated in the above section, 22 studies addressing 26 objectives demonstrated improvements in attitudes. Seven studies addressing eight objectives evaluated a single media intervention.^13^,^39^,^40^,^50^,^53^,^71^,^72^ Two of the studies^39^,^50^ utilized the internet, one^13^ utilized a computer-based program and the remaining four utilized print media.^40^,^53^,^71^,^72^ The two studies addressing three objectives that utilized the internet demonstrated improved short-term attitudes in one study and long-term attitudes in the other. All four of the studies that utilized print media demonstrated long-term improvements in attitudes. The one study that utilized computer-based education for its intervention did not clearly report the duration. Twelve studies addressing 15 objectives utilized multi-media interventions to demonstrate attitudinal benefits.^34^–^36^,^42^,^52^,^68^,^69^,^73^,^75^–^78^ Five studies addressing six objectives did not clearly report on the duration and seven studies addressing nine objectives demonstrated long-term improvements in attitudes. Three studies compared a single media-based intervention to a multi-media intervention.^47^,^70^,^74^ All three studies included at least one concurrent control group that only utilized print material and in all three cases multi-media outperformed the print-based single media intervention group. All three studies showed long-term improvements in attitudes.

The four studies that did not demonstrate improvements in attitude all utilized multimedia.^37^,^52^,^55^,^62^ One study combined live with print and did not clearly report on duration.^37^ The other 3 studies considered long-term attitudinal changes at 9 months in one study and 15 months in the other 2 studies. The study that considered outcomes at nine months utilized a combination of live internet with print material while the other two studies combined live with print in one and live with video and print in the other.

Both of the two studies that demonstrated mixed results utilized multimedia approaches.^62^,^79^ One study utilized live internet with print material and the other study utilized live in conjunction with print and a followup phone call.

When grouped solely by media classification, then 7 studies addressing 8 objectives utilized a single media with all 7 demonstrating attitudinal benefits, 18 studies addressing 26 objectives considered multimedia interventions with 12 demonstrating benefits, and 3 studies addressing 3 objectives compared single to multi-media with all 3 of these studies demonstrating that multimedia interventions had greater benefit.

Given the heterogeneity of the studies the only recognized trends were that multimedia appears better than a single media intervention and that print interventions are either not beneficial or very weak in their ability to lead to improve attitudes.

Short-term and long-term effects of CME educational techniques on physician attitudes. Studies were classified by objectives met and evaluation duration as described above and by technique utilized for the educational intervention. The technique classifications included multiple techniques, single technique and single versus multiple techniques. One study that had not been previously included because of a lack of a control group can be utilized in this section because the concurrent comparison group did indeed utilize a different technique permitting some head to head comparisons.^66^ This means that for this section there are 23 studies addressing 27 objectives.

Only one study that met its objectives utilized a single technique, reading, and this study did not clearly report duration.^13^ Seventeen studies addressing 21 objectives utilized multiple techniques to improve attitudes. Five studies^34^–^36^,^68^,^69^ addressing 6 objectives that demonstrated improved attitudes did not clearly report the duration, 1 study^39^ addressing 2 objectives demonstrated short-term attitudinal improvement and 11 studies^42^,^50^,^52^,^53^,^71^–^73^,^75^–^78^ addressing 13 objectives demonstrated long-term attitudinal improvements.

The majority of the studies that demonstrated improvement but did not clearly report the duration included case-based learning as a technique in combination with techniques ranging from discussion groups to independent reading. Of the 11 studies that demonstrated long-term improvements in attitude the majority integrated multiple techniques and most commonly combined case-based learning with discussion groups with independent reading, several utilized standard lectures with readings, and some technique combinations ranged from lecture with a standardized patient to lecture with team-based training. Four studies addressing four objectives compared a single technique versus multiple techniques demonstrated improvements in attitudes.^40^,^47^,^70^,^74^ All four studies demonstrated long-term knowledge improvements. Three of these four studies utilized readings as the sole technique and one utilized a discussion group. All four studies demonstrated that multiple techniques were better than single techniques.

Four studies of four objectives did not demonstrate improved attitudes.^37^,^52^,^55^,^62^ One study that utilized multiple techniques that included live and print failed to demonstrate improved attitudes and did not clearly report the duration.^37^ Two studies failed to demonstrate improvements in attitudes despite utilizing multiple techniques.^52^,^62^ One combined lecture with discussion group and failed to show improvements in provider perceptions about quality of care for patients with dementia, while the other combined case-based learning with discussion with readings, with standardized patients and failed to show improvements in attitudes regarding cholesterol lowering practices. Only one study compared a single technique versus multiple and failed to show an improvement in provider attitudes regarding pain.^55^

The one study that was added to this section deserves a greater explanation. Heale et al^66^ compared three groups, one receiving lectures, one case-based learning with discussion groups, and the final group received problem-based learning. This study demonstrated improvements in attitudes that were greatest in the problem-based learning participants.

Both studies that demonstrated mixed results assessed long-term attitudinal change^62^,^81^ and both utilized multiple techniques. These included lecture with a point-of-care opinion leader in one study and lecture with discussion groups in the other.

When grouped solely by technique classification then one study addressing one objective utilized a single technique and it demonstrated attitudinal improvement. Twenty-two studies addressing 26 objectives utilized multiple techniques with 17 demonstrating benefits, 3 no benefits, and 2 mixed results. Five studies addressing five objectives compared single versus multiple techniques. Four studies demonstrated greater attitudinal change with the utilization of multiple techniques as compared to a single technique and one study showed no improvement.

The outcomes from this section are also heterogeneous but it does appear that multiple techniques that most commonly include case-based learning seem to be more likely to be associated with improvements in attitudes.

Short-term and long-term effects of the amount of exposure on physician attitudes.Studies were classified by objectives met and evaluation duration as described above and by exposure volume for the educational intervention. The exposure volume classifications included multiple exposures, single exposure and single versus multiple exposures. The one study added in the previous section does not apply to this section given the lack of control group. In addition, one additional study^58^ did not adequately describe the exposure and thus is excluded from analysis in this section leaving 24 studies addressing 25 objectives.

There were 22 studies addressing 25 objectives which demonstrated an improvement in attitude.^13^,^34^–^36^,^39^,^40^,^42^,^47^,^50^,^52^,^53^,^68^–^78^ Seven studies addressing eight objectives evaluated a single exposure volume with two studies^36^,^68^ not clearly reporting the duration and five studies^53^,^70^,^71^,^74^,^77^ addressing six objectives demonstrating long-term improvements. Eleven studies addressing 12 objectives utilized multiple exposure volumes. Three studies^13^,^35^,^69^ did not clearly report duration, one study^39^ demonstrated short-term knowledge gains, and the final seven studies^50^,^52^,^72^,^73^,^75^,^76^,^78^ addressing eight objectives all demonstrated long-term knowledge gains. Four studies addressing five objectives compared a single exposure to multiple exposures and demonstrated attitudinal improvements.^34^,^40^,^42^,^47^ One study^34^ addressing two objectives did not clearly report duration, while the remaining three studies all demonstrated long-term improvements in attitudes.

Four studies addressing four objectives did not demonstrate attitude improvements. No study was identified that evaluated a single exposure only or that performed a comparison between single and multiple exposures. Three studies evaluated multiple exposures with one^37^ not clearly reporting the duration and the other two^55^,^62^ failing to demonstrate long-term knowledge improvements.

No studies were identified that utilized a single exposure only or compared a single versus multiple that demonstrated mixed results. Two studies demonstrated mixed results and both utilized multiple exposures.^62^,^81^ Both studies assessed long-term attitudes.

When grouped solely by exposure volume then all seven studies that evaluated a single exposure demonstrated improved attitudes. Eleven of the 17 studies that utilized multiple exposures demonstrated attitudinal improvements with an additional two demonstrating mixed results. The majority (64%) of these were able to demonstrate long-term attitudinal benefits. Of the four studies that compared a single exposure to multiple exposures all demonstrated a greater benefit to multiple exposures as compared to a single exposure.

In summary, despite the heterogeneity of these studies it appears that there is a trend toward multiple exposures being of greater benefit for attitudinal change then a single exposure, although it must be pointed out that all seven studies that evaluated a single exposure indeed demonstrated improvements in attitudes.

Summary of the effects of CME on physician attitudes.The heterogeneity of the studies precludes firm conclusions, but the trends demonstrated that CME is effective at producing both short-term and long-term attitudinal gains and that when possible, use of multimedia, multiple techniques, and multiple exposures should produce better attitudinal outcomes.

Quality of the evidence for the short-term and long-term effects of CME attitudes (see Appendix F, Evidence Table 8).Taking into consideration the quantity and quality, and consistency of evidence on the effectiveness of CME on attitudes, we graded the strength of evidence as very low.

### Skills Outcomes

Short-term effects of CME on skills (See Appendix F, Evidence Table 10).Skill-related outcomes were categorized as either cognitive or psychomotor. The skills reported were varied including cognitive skills such as diagnostic accuracy for psychiatric conditions,^36^ or communication skills with patients.^84^ Psychomotor skills included examples such as performing a physical exam,^60^ or doing a joint injection.^80^ A total of 15 studies reported skill outcomes, with a total of 18 skill outcomes.^13^,^32^,^33^,^36^,^40^,^49^,^60^,^77^,^80^,^84^–^89^ Twelve of the 15 studies that reported skill outcomes were cognitive skills,^13^,^32^,^33^,^36^,^40^,^49^,^77^,^84^–^88^ with the remaining three being psychomotor skills.^60^,^72^,^80^

Of those 15 studies, 10 had skill outcomes that met the objectives of the study.^32^,^33^,^36^,^40^,^49^,^72^,^84^–^87^ One study had three skill outcomes that all met the objectives,^84^ and another study had two reported skill outcomes that met the objectives.^33^ The remaining studies each had one skill outcome. Two studies had skill outcomes that did not achieve the study objectives,^13^,^77^ and one study had mixed results that did not clearly meet the study objectives.^88^ Two studies compared different methods and techniques of CME without a separate control group that did not receive CME;^60^,^80^ therefore, the overall effectiveness of CME cannot be discerned from these studies. Given that 10 out of 13 studies that included control groups and reported on skills (13 out of 16 outcomes) met the objectives and given the varied nature of the studies, the literature does indicate that CME is effective in this area, particularly at developing cognitive skills. Little can be said about the effectiveness of CME for psychomotor skills given the paucity of data in this area.

Long-term effects of CME on skills (See Appendix F, Evidence Table 10).Seven of the 15 studies reporting skill outcomes had an evaluation beyond 30 days after the CME activity.^40^ ^49^ ^72^ ^77^ ^84^ ^86^ ^90^ Six of the studies addressing long-term skill outcomes addressed cognitive skills,^40^ ^49^ ^77^ ^84^ ^86^ ^90^ while one addressed psychomotor skills.^72^ Of those seven studies, six met the objectives regarding long-term skill outcomes,^40^ ^49^ ^72^ ^84^ ^86^ ^90^ while one did not meet its objectives.^77^ The one study that did not meet its objectives regarding long-term skill outcomes addressed cognitive skills.^77^ Overall, the data supports the positive effect of CME on long-term skill outcomes.

Short-term effects of CME media methods on skills.The media methods of CME that were included in the studies that met the study objectives regarding skills included seven that used live media,^32^,^33^,^36^,^40^,^49^,^72^,^84^ four that included print materials,^32^,^33^,^49^,^85^ two that included video methods,^32^,^36^ two that included audio methods,^32^,^49^ two that used the Internet (not real time),^86^,^87^ and one that used computers (off-line).^33^ However, in several cases the same media methods were used in all experimental arms and therefore no conclusions can be drawn from the study outcomes applying to specific CME methods. This situation applied to live methods in one study,^40^ audio methods in one study,^49^ and print materials in two studies.^49^,^85^ In addition, one study was not clear about which groups received particular methods including live, print, and computer (off-line) media.^33^ The studies that did not clearly meet skills objectives included live,^77^ ^88^ video,^77^ ^88^ and computer (off-line) methods.^13^ Two studies directly compared different methods of CME but did not include a control group without CME.^60^,^80^ One of these studies showed no difference between print, computer (off-line), and live methods.^80^ However, another study showed that live methods were superior to video and print combined.^60^ Given this result and the dominance of live methods among the studies that met their skills objectives, the data suggests that live methods have the greatest impact on the effectiveness of CME regarding skills outcomes. Given the paucity of data and the varied results, little can be said about the relative effectiveness of other CME media methods on affecting skills.

Long-term effects of CME media methods on skills.The six studies that addressed long-term skill outcomes beyond 30 days and met their skills objectives used a variety of media methods including four using live methods,^40^,^49^,^72^,^91^ two using print materials,^49^,^85^ one using audio methods,^49^ and one using the Internet (not real time).^86^ However, the one study that used audio methods had audio in all experimental arms,^49^ the two that used print media did so in all groups,^49^,^85^ and one of the four that used live methods did so in all groups.^40^ Therefore, the experimental effect on long-term outcomes in studies that met their skills objectives was seen only for three studies using live media,^49^,^72^,^84^ and one study that used the Internet (not real time).^86^ The one study that did not meet its objectives regarding long-term skill outcomes used live and video as the methods.^77^ The studies that directly compared different methods of CME did not address long-term skill outcomes.^60 80^ Based on the limited data, it is difficult to draw conclusions on particular media methods of CME that have a greater or lesser impact on long-term skill outcomes.

Short-term effects of CME educational techniques on skills.Varied educational techniques were used in the studies that met their objectives regarding short-term skill outcomes. These included lectures in six studies,^32^,^36^,^40^,^49^,^72^,^84^ discussion groups in five studies,^32^,^49^,^72^,^84^,^85^ readings in five studies,^32^,^33^,^49^,^85^,^86^ case-based learning in four studies,^36^,^49^,^86^,^87^ feedback in three studies,^32^,^49^,^86^ role play in three studies,^32^,^72^,^84^ and clinical experiences in two studies.^32^,^72^ Listserv,^85^ programmed learning,^86^ problem-based learning,^40^ audio-taped encounters,^72^ and standardized patients,^84^ were seen in one study each in the studies that met their skills objectives. Of note, readings were used as a technique in both experimental and control groups in one study.^85^ In the studies where the skills objectives were not clearly met by the outcomes, the following techniques were used: demonstration and lecture in two studies,^77^,^88^ and readings,^13^ discussion groups,^88^ feedback,^88^ programmed learning,^88^ and role play^88^ in one study each. Two studies that did not include a control group compared the techniques of readings versus readings with demonstration versus mentor/preceptor with simulation.^80^ No difference was seen with these different techniques. In another study without a control group, the techniques of demonstration and simulation were compared with demonstration and simulation plus feedback.^60^ The group that included feedback was significantly better when skills acquisition was assessed. Finally, two of the studies that met their objectives regarding skills and included control groups did a comparison of individual techniques of delivering CME. One study compared problem-based learning with lecture, and problem-based learning was significantly better.^40^ Another study compared discussion groups and readings to discussion groups and readings with feedback.^85^ In this study, feedback had no additional effect. Given the limited number of studies, the wide variety of techniques described, and the conflicting results, it is difficult to draw conclusions about the educational techniques that have the greatest and least effect on skills.

Long-term effects of CME educational techniques on skills.The educational techniques used in the studies that met the study objectives regarding long-term skill outcomes included discussion groups in four studies,^49^,^72^,^84^,^85^ lectures in four studies,^40^,^49^,^72^,^84^ readings in three studies,^49^,^85^,^86^ role play in two studies,^72^,^84^ case-based learning in two studies,^49^,^86^ and feedback in two studies.^49^,^86^ The techniques of clinical experiences,^72^ listserv,^85^ programmed learning,^86^ problem-based learning,^40^ audio-taped encounters,^72^ and standardized patients,^84^ were seen in one study each that met skills retention objectives. The one study that did not meet its objectives regarding long-term skill outcomes used the techniques of demonstration, lecture, and simulation.^77^ The two studies that compared different techniques in CME without a control group did not address long-term skill outcomes.^60^,^80^ However, in two studies that did have a control group, one showed that problem based learning is superior to lectures in long-term skill outcomes,^40^ but the other showed no advantage of feedback over demonstration and readings alone.^85^ Given the limited number of studies and the varied techniques, it is difficult to draw conclusions about the educational techniques that that have a greater or lesser effect on long-term skill outcomes.

Short-term effects of the amount of exposure on skills.The majority of the studies that met their skills objectives had multiple exposures to the CME activity. Seven of these studies used multiple exposures,^32^,^40^,^49^,^72^,^84^–^86^ while one used a single exposure.^36^ It was unclear how many exposures there were in two of the studies whose skills outcomes met the study objectives.^33^,^87^ The studies that did not meet the skills objectives included two that used a single exposure,^77^,^88^ and one that used multiple exposures.^13^ These results suggest that multiple exposures to CME for skills objectives is superior to a single exposure.

Long-term effects of the amount of exposure on skills.All six of the studies that addressed long-term skill outcomes and met the study objectives used multiple exposures to CME.^40^,^49^,^72^,^84^–^86^ The one study that did not meet its study objectives regarding long-term skill outcomes used a single exposure.^77^ These results support multiple exposures as having a greater impact on long-term skill outcomes.

Quality of the evidence for the short-term and long-term effects of CME on skills (see Appendix F^*^, Evidence Table 8).Taking into consideration the quantity and quality, and consistency of evidence on the effectiveness of CME on skills, we graded the strength of evidence as low.

### Practice Behavior Outcomes

Short-term and long-term effects of CME on practice behavior (See Appendix F, Evidence Table 11).A total of 105 studies evaluated the short- and long-term impact of CME activity on 135 practice behavior objectives. Of the 105 studies, 61 studies met 70 practice behavior objectives. Ten of these, reporting on 11 objectives, met objectives but did not report evaluation duration, leaving us unable to determine whether the effect of CME was short-term or long-term.^15^,^32^,^35^,^36^,^68^,^69^,^79^,^87^,^92^,^93^ Four of these studies reported improvement with regard to medication prescribing, and three reported improvement with regard to screening test referrals. One study with evaluation duration of 30 days or less met objectives in three out of six smoking cessation and documentation behaviors.^94^

Fifty studies with evaluation duration greater than 30 days met 58 objectives, suggesting long-term retention of CME effectiveness.^19^,^44^–^49^,^52^,^53^,^62^,^70^,^72^,^75^–^78^,^81^,^82^,^82^,^95^–^125^ Among these, evaluation duration ranged from 6 months or less after the educational intervention (17 studies) to 1 year or greater (30 studies).

A wide mix of objectives was studied. For example, 12 objectives were related to medication prescribing, eight were related to screening standards, 14 were related to physician counseling behaviors (mostly smoking cessation, but also dietary counseling, sexual practices counseling, etc.), 11 were related to guideline adherence, and the remainder were related to physician behaviors pertaining to other topics.

Twenty nine total studies, reporting on 38 objectives, did not meet objectives. Of these, twenty four studies reporting on 33 objectives were evaluated at greater than 30 days.^14^,^16^,^43^,^56^,^70^,^73^,^74^,^96^,^99^,^101^,^119^,^122^,^126^–^137^ Two studies with evaluation duration of 30 days or less did not meet objectives.^18^,^138^ Three studies did not report evaluation duration and did not meet objectives.^13^,^57^,^139^

Nine studies, evaluating 9 objectives, showed mixed results in terms of their objectives being met.^20^,^42^,^71^,^73^,^88^,^137^,^140^–^142^ One study was unclear as to whether it met objectives.^101^ Fourteen studies, evaluating 17 objectives lacked a control group and therefore did not allow us to assess effectiveness.^23^–^25^,^59^,^64^–^67^,^83^,^143^–^147^

Overall, CME interventions were effective in the short- and long-term achievement of practice behavior objectives.

Short-term and long-term effects of CME media methods on practice behavior. The different types of media evaluated included single-media live presentations (20 studies), single-media print materials (9 studies), internet (1 study), other single media (2 studies), multimedia (57 studies), and also single versus multimedia comparisons (15 studies).

Of 20 studies using single live media, 10 studies met 11 objectives, three studies did not meet objectives, three studies showed mixed results and four studies did not have a control group. Of these 20 studies, nine studies with evaluation duration of greater than 30 days met 10 objectives,^45^,^48^,^53^,^72^,^82^,^102^,^107^,^121^,^125^ suggesting that the use of single live media had a favorable long-term effect on practice behavior objectives. One study had an evaluation duration of 30 days or less and met objectives using single live media.^94^ Three studies using single live media reported evaluation duration greater than 30 days but showed mixed results.^20^,^71^,^140^ Four studies lacked a control group, and no meaningful conclusions could be drawn with regard to the comparative effectiveness of single live media.^24^,^25^,^64^,^66^ Three studies did not meet practice behavior objectives using single live media. Of these, one did not report evaluation duration,^57^ one reported evaluation duration of 30 days or less,^138^ and one reported evaluation duration greater than 30 days.^133^

Out of nine studies with ten objectives that examined the impact of single print media, only one met objectives,^15^ but it did not report evaluation duration. One study did not meet objectives using single print media and did not report evaluation duration.^139^ One study with evaluation duration of 30 days or less did not meet objectives using single print media.^18^ Four studies (five objectives) with evaluation duration greater than 30 days did not meet objectives using single print media.^14^,^56^,^130^,^134^ Two studies using single print media reported evaluation duration greater than 30 days, but lacked a control group and no meaningful conclusions could be drawn with regard to the comparative effectiveness of single print media.^23^,^143^ The evidence suggests that single print media is not effective in the short- or long-term achievement of practice behavior objectives.

The only study using single internet media reported an evaluation duration greater than 30 days and it was unclear whether it met objectives.^43^ One study did not meet objectives using other single media and did not report evaluation duration.^13^ One study using other single media did not report evaluation duration and lacked a control group.^147^ One study with evaluation duration greater than 30 days did not report the media used and lacked a control group.^145^

Out of 57 studies (78 total objectives) using multimedia, 40 studies met 47 objectives, 14 studies did not meet 19 objectives, 4 studies showed mixed results, and 4 studies lacked a control group. Of the 40 studies which met objectives, 31 studies with 37 objectives were evaluated at greater than 30 days suggesting that multimedia-based CME has a favorable long-term effect on practice behaviors.^19^,^46^,^49^,^52^,^62^,^75^–^78^,^81^,^95^,^98^,^99^,^101^,^103^,^104^,^106^,^108^–^110^,^112^,^113^,^116^–^120^,^122^–^124^,^148^ Nine studies met 10 objectives using multimedia but did not report evaluation duration.^32^,^35^,^36^,^68^,^69^,^79^,^87^,^92^,^93^ One study using multimedia did not report evaluation duration; it also lacked a control group.^146^ Four studies using multimedia reported an evaluation duration greater than 30 days, and showed mixed results.^42^,^73^,^88^,^142^ Three studies (six objectives) with evaluation duration greater than 30 days lacked a control group and precluded meaningful conclusions.^65^,^83^,^144^ Fourteen studies with 19 objectives with evaluation duration greater than 30 days did not meet objectives using multimedia.^16^,^73^,^99^,^101^,^119^,^122^,^126^–^129^,^131^,^132^,^135^,^136^ The evidence suggests that multimedia may have a positive short- and long-term effect on practice behavior objectives.

Out of 15 studies comparing single media and multimedia, 10 studies met 11 objectives and all were evaluated at an interval of greater than 30 days after the educational intervention,^44^,^47^,^70^,^96^,^97^,^100^,^105^,^111^,^114^,^115^ suggesting that both single media and multimedia have a positive short and long-term effect on practice behavior objectives, and that multimedia have an advantageous effect. One study comparing single media and multimedia did not report evaluation duration and lacked a control group.^59^ Two studies comparing single media and multimedia reported evaluation duration greater than 30 days and showed mixed results.^137^,^141^ One study reported evaluation duration greater than 30 days, but lacked a control group.^67^ Four studies with evaluation duration greater than 30 days did not meet seven objectives.^70^,^74^,^96^,^137^

One study did not report the type of media used, reported evaluation duration greater than 30 days, lacked a control group, and was inconclusive about meeting objectives.^145^

The evidence suggests that both single media and multimedia may have positive short- and long-term effects on practice behavior, with use of multimedia being advantageous.

Short-term and long-term effects of CME educational techniques on practice behavior.A total of 11 studies reporting on 12 objectives evaluated the impact of a single technique on practice behavior objectives. One study met objectives using a single technique but did not report evaluation duration.^15^ One study with evaluation duration of 30 days or less met objectives using a single technique.^94^ One study with evaluation duration greater than 30 days met objectives using a single technique.^19^ One study did not report evaluation duration and did not meet objectives using a single technique.^13^ One study with evaluation duration of 30 days or less did not meet objectives using a single technique.^18^ Two studies with evaluation duration of greater than 30 days did not meet objectives using a single technique.^14^,^16^ One study was judged inconclusive because of mixed results.^20^ Three studies using a single technique reported evaluation duration of greater than 30 days, but lacked a control group.^23^–^25^ Two of these three studies did not reach statistical significance. This suggests that a using a single technique may not have a short- or long-term positive effect on practice behavior objectives.

A total of 76 studies with 98 objectives evaluated the short- and long-term impact of multiple techniques on practice behavior objectives. Eight studies met 11 objectives using multiple techniques but did not report evaluation duration^32^,^35^,^36^,^68^,^69^,^79^,^92^,^93^ and thus did not allow us to distinguish between short- and long-term effects of CME. Thirty-nine studies with evaluation duration greater than 30 days met 45 objectives using multiple techniques.^44^–^46^,^48^,^49^,^52^,^53^,^62^,^72^,^76^–^78^,^81^,^82^,^82^,^95^,^98^,^99^,^101^–^113^,^116^–^120^,^122^–^124^

Two studies did not report evaluation duration and did not meet objectives using multiple techniques.^57^,^139^ One study with evaluation duration of 30 days or less did not meet objectives using multiple techniques.^138^ Sixteen studies with evaluation duration of greater than 30 days reporting on 22 objectives did not meet objectives using multiple techniques.^43^,^56^,^73^,^101^,^119^,^122^,^126^–^129^,^131^–^136^

One study using multiple techniques did not report evaluation duration and lacked a control group.^146^ One study using multiple techniques did not report evaluation duration and showed mixed results.^149^ Seven studies reporting on 10 objectives using multiple techniques reported an evaluation duration of greater than 30 days but lacked a control group.^64^,^65^,^67^,^83^,^143^–^145^ Six studies showed mixed results.^42^,^71^,^73^,^88^,^140^,^142^ One of the six showed a positive effect which was lost 6 months after the intervention.^73^

The evidence suggests that the use of multiple techniques in CME may have an overall positive short- and/or long-term effect on practice behavior objectives.

A total of 18 studies reporting on 24 objectives compared the use of single and multiple educational techniques in CME.^47^,^59^,^66^,^70^,^74^,^87^,^96^,^97^,^100^,^114^,^115^,^121^,^125^,^130^,^137^,^141^,^147^,^148^ Ten studies with evaluation duration greater than 30 days met 12 objectives comparing single and multiple techniques,^47^,^70^,^96^,^97^,^100^,^114^,^115^,^121^,^125^,^148^ and indicated that multiple techniques may have an advantageous short- and long-term effect on practice behavior objectives. Two studies using single versus multiple techniques did not report evaluation duration and neither had a control group, precluding further meaningful conclusions.^59^,^147^ Two studies using single versus multiple techniques reported an evaluation duration of greater than 30 days and showed mixed results,^137^,^141^ One study with evaluation duration greater than 30 days lacked a control group. Five studies with evaluation duration of greater than 30 days reporting on eight objectives did not meet objectives and thus were unable to identify a difference when using single versus multiple techniques.^70^,^74^,^96^,^130^,^137^

Short-term and long-term effects of the amount of exposure on practice behavior.A total of 37 studies reporting on 41 objectives evaluated the impact of single exposure to the CME activity. Two studies met objectives using single exposure, but did not report evaluation duration.^36^,^68^ One study with evaluation duration of 30 days or less met objectives using a single exposure to the CME activity.^94^ Sixteen studies with evaluation duration greater than 30 days met 18 objectives using single exposure to the CME activity.^44^,^45^,^48^,^53^,^70^,^77^,^82^,^98^,^100^,^102^–^104^,^106^,^107^,^111^,^114^ This suggests that single CME exposure may have a positive short- and long-term effect on practice behavior objectives. Two studies with evaluation duration of 30 days or less did not meet objectives using single exposure to the CME activity.^18^,^138^ Only six studies with evaluation duration greater than 30 days did not meet objectives using single exposure to the CME activity.^14^,^16^,^70^,^74^,^128^,^129^ Five studies with evaluation duration greater than 30 days lacked a control group,^24^,^25^,^64^–^66^ although one of the five did not meet objectives for either intervention group.^24^ Six studies with evaluation duration greater than 30 days showed mixed results.^20^,^71^,^88^,^140^–^142^

A total of 55 studies (72 objectives) evaluated the impact of multiple exposures to the CME activity. Five studies met objectives using multiple exposures to the CME activity, but did not report evaluation duration.^15^,^32^,^35^,^69^,^93^ Thirty studies with evaluation duration greater than 30 days met 36 objectives using multiple exposures to the CME activity.^19^,^46^,^49^,^52^,^62^,^72^,^75^,^76^,^78^,^81^,^95^,^97^,^99^,^101^,^105^,^108^–^110^,^112^,^113^,^115^–^121^,^123^,^125^,^148^ One study using multiple exposures to the CME activity did not report evaluation duration and lacked a control group.^147^ Five studies of evaluation duration greater than 30 days lacked a control group^24^,^25^,^64^–^66^ whereas two studies showed mixed results.^73^,^137^ No meaningful conclusions could be drawn from these studies. Two studies did not meet objectives using multiple exposures to the CME activity, and did not report evaluation duration.^13^,^57^ Sixteen studies with evaluation duration greater than 30 days did not meet 21 objectives using multiple exposures to the CME activity.^43^,^56^,^73^,^99^,^101^,^119^,^126^,^127^,^130^,^132^–^137^,^150^ Overall, we conclude that multiple exposure volume to the CME activity may have positive short- and long-term effects on practice behaviors.

A total of eight studies reporting on 17 objectives did a head-to-head comparison between single and multiple exposures.^42^,^47^,^59^,^79^,^83^,^96^,^122^,^144^ Whereas four of these studies indicated that multiple exposures may be better than single exposure, six showed mixed or negative results, thus not allowing us to draw any strong conclusions. One study met objectives using single versus multiple exposures to the CME activity, but did not report evaluation duration.^79^ Three studies with evaluation duration greater than 30 days met objectives using single versus multiple exposures to the CME activity.^47^,^96^,^122^

One study using single versus multiple exposures to CME activity did not report evaluation duration and had no control group.^59^ Two studies using single versus multiple exposures to CME activity reported evaluation duration greater than 30 days but did not have a control group.^83^,^144^ No meaningful conclusions could be drawn from these studies. One study using single versus multiple exposures to CME activity reported evaluation duration greater than 30 days and showed mixed results.^42^

Two studies with evaluation duration greater than 30 days did not meet objectives using single versus multiple exposures to the CME activity.^96^,^122^

One study did not meet objectives and did not report exposure to CME activity or evaluation duration.^139^

Two studies met objectives using other exposures to the CME activity, but did not report evaluation duration.^87^,^92^ One study with evaluation duration greater than 30 days met objectives using other exposures to the CME activity.^124^ One study using other exposure to CME activity did not report evaluation duration and lacked a control group.^146^

Quality of the evidence for the short-term and long-term effects of CME on practice behavior (see Appendix F, Evidence Table 8).Taking into consideration the quantity and quality, and consistency of evidence on the effectiveness of CME on practice behaviors, we graded the strength of evidence as very low.

### Clinical Outcomes

Short-term effects of CME on clinical outcomes (See Appendix F, Evidence Table 12).Only one study measured the short-term effects of CME on clinical outcomes, i.e., less than 30 days after the educational intervention.^18^ This study reported on the effect of printed CME on adherence to beta-blocker use, and was successful in achieving the stated objective of the intervention. However, the effects of CME were evaluated in non-equivalent patient groups, rendering the results of the study inconclusive. Three additional studies did not clearly report the time at which clinical outcomes were measured.^32^,^33^,^151^ Of these, two reported that the desired objective of the intervention was met,^33^,^151^ and a third showed mixed results.^32^ The first of these studies reported on a direct measure of health status: depression. In that study, depression was improved to a greater degree among patients of physicians who had received a quality improvement intervention that included CME in the form of academic detailing, discussion groups, printed materials, and feedback, than among a control group.^151^ However, the effect of CME was difficult to separate from the effect of the quality improvement component. The second study addressed antimicrobial drug use with a complex statewide intervention that targeted education directly at patients as well as their physicians; this made the actual effect of the CME component difficult to estimate.^33^ The third study evaluated a multi-modality depression education program and found significantly improved patient satisfaction among women, but not among men.^32^

Long-term effects of CME on clinical outcomes.Thirty-three studies, reporting on 42 clinical outcomes, measured the long-term effect of CME, i.e., more than 30 days following the educational intervention.^22^,^43^,^47^,^55^,^56^,^65^,^72^–^75^,^77^,^78^,^81^,^84^,^95^,^99^,^109^,^111^–^115^,^117^,^120^,^131^,^132^,^135^,^137^,^152^–^156^ Fourteen of these studies were successful in achieving the desired effect of the CME intervention on clinical outcomes.^22^,^43^,^47^,^74^,^78^,^84^,^95^,^109^,^111^,^115^,^152^–^155^ One study showed mixed results, impacting frequency of office visits but not emergency room visits or hospitalizations.^120^ In the remaining 23 studies, either no effect of CME was observed, or the effect was uncertain due to ambiguous results or problems in study design. Of the 14 studies that did show a long-term effect, six reported on direct measures of health status of the target patient population. These outcomes were arthritis pain and disability,^95^ depression,^22^,^152^ general health and function,^109^ emotional distress,^84^ and lost work due to back pain.^153^ Eight studies reported on health-related behaviors or attitudes. These outcomes were: percent of patients taking medication,^152^ patient adherence with antibiotics,^47^ patient satisfaction with care,^74^ frequency of physician visits,^111^ hospitalizations,^78^ hospital length of stay,^155^ and smoking cessation rates.^115^,^154^ One study reported a mixed outcome, “quality of practice,” which combined direct measures of patient health status, such as whether the blood pressure was below 130/80 mm Hg, with behavioral or physician-related outcomes, such as whether the physician had recorded a family history of diabetes.^43^

Short-term effects of CME media methods on clinical outcomes. Only one study was available to assess the relative effectiveness of different types of media (live, print, internet, or multiple) on short-term clinical outcomes (less than 30 days). In this study, a print intervention improved adherence with beta-blocker use.^18^ Five studies did not report on duration of clinical outcome.^32^ ^33^ ^146^ ^151^ ^157^ Thus, no conclusions could be drawn about the differential effectiveness of CME media in the short term.

Long-term effects of CME media methods on clinical outcomes. Of the studies that had information about the effectiveness of different single media forms of CME on long-term clinical outcomes, five used a live CME intervention;^72^,^84^,^152^,^154^,^155^ four of these five achieved the stated goal of the study. Two studies used print media and neither achieved its objective.^56^,^157^ Another used Internet-based CME and did achieve its objective.^43^ Most of the studies, however, used multiple CME media. Twenty-two studies used multiple media CME in comparison to a control.^55^,^65^,^73^,^73^,^75^,^75^,^77^,^78^,^81^,^95^,^99^,^109^,^112^,^113^,^117^,^120^,^120^,^131^,^131^,^132^,^135^,^156^ In four of these, the study achieved its stated aim. Seven studies compared multiple media CME to single media CME.^47^,^74^,^111^,^114^,^115^,^137^,^153^ Six of these achieved the stated aim; each found multiple media CME to be more effective than single media in improving clinical outcomes.

Short-term effects of CME educational techniques on clinical outcomes. A total of 15 different educational techniques were identified in the studies that reported clinical outcomes: readings, conference calls, academic detailing, discussion groups, lectures, point of care CME, feedback, physician visits, case-based learning, role-play, standardized patients, demonstrations, clinical experiences, simulation, and problem-based learning. Only one CME technique was evaluated singly in comparison to control for short-term clinical outcomes: provision of educational readings was associated with increased use of beta-blockers.^18^

Long-term effects of CME educational techniques on clinical outcomes. Only one study evaluated the effect of a single CME technique in comparison to control for long-term clinical outcomes. In this study, the use of conference calls was associated with improvements in depression.^22^ With only one such study, no conclusions could be drawn regarding the comparative effectiveness of single CME techniques on long-term clinical outcomes. Most of the studies evaluated used multiple CME techniques. Thirty-eight studies reported on the use of multiple simultaneous CME techniques in comparison to control. Twelve of these reported that the desired clinical outcome of the CME intervention was achieved.^43^,^47^,^74^,^78^,^84^,^95^,^109^,^111^,^115^,^152^,^153^,^155^ Two studies yielded mixed results, i.e., some of the outcomes showed improvement while others did not.^120^,^151^ No individual CME techniques were common to the studies that did or did not achieve their stated objective; thus, one cannot draw any conclusions regarding the differential effectiveness of specific educational techniques. Five studies compared single to multiple CME interventions.^47^,^74^,^115^,^137^,^152^ In three of the five studies, the use of multiple simultaneous CME techniques was superior to the use of a single CME technique (readings).

Short-term effects of the amount of exposure on clinical outcomes. Only one study assessed the short-term effect of CME on clinical outcomes (less than 30 days). In this study, a one-time print intervention improved adherence with beta-blocker use.^18^ Five studies did not report on duration of clinical outcome,^32^,^33^,^146^,^151^,^157^ and all other studies reported long-term outcomes. Thus, no conclusions could be drawn about the differential effectiveness of amount of CME exposure (one-time vs. multiple exposures) on short term outcomes.

Long-term effects of the amount of exposure on clinical outcomes. Seven studies evaluated the long-term effect of a single CME exposure on clinical outcomes.^65^,^74^,^77^,^111^,^114^,^152^,^154^ Four of these studies reported that the CME objective had been met.^74^,^111^,^152^,^154^ In one study, the objective was not met.^114^ Of the remaining two studies, one lacked a well-defined control group^65^ and one yielded unclear results.^77^ Most studies employed multiple CME exposures. In 24 studies, the multiple CME exposures were compared to a control with no CME.^22^,^43^,^55^,^56^,^72^,^73^,^75^,^75^,^78^,^81^,^84^,^95^,^99^,^109^,^112^,^113^,^115^,^117^,^120^,^131^,^132^,^135^,^137^,^156^ In seven of the studies, the objectives were met.^22^,^43^,^78^,^84^,^95^,^109^,^115^ In 16 studies, the objectives were not met or it was unclear if they were met.^55^,^56^,^72^,^73^,^75^,^75^,^81^,^99^,^112^,^113^,^117^,^131^,^132^,^135^,^137^,^156^ One study produced mixed results, as described above.^120^ In one study, a single printed CME intervention and a combination of printed material plus tutorial were compared with control.^47^ While the CME intervention was deemed successful in changing clinical outcomes, the use of multiple CME exposures (tutorial plus reading) outperformed a single CME exposure (reading alone) in only 2 of 5 outcomes studied. In summary, both one-time and multiple exposure CME interventions have produced changes in clinical outcomes in about half of the studies, but it is unclear whether multiple exposure CME produces better results than one-time CME.

Quality of the evidence for the short-term and long-term effects of CME on clinical outcomes (see Appendix F, Evidence Table 8). Taking into consideration the quantity and quality, and consistency of evidence on the effectiveness of CME on skills, we graded the strength of evidence as low.

## Key Question 3: What is the evidence from systematic reviews about the effectiveness of simulation methods in medical education outside of CME?

### Characteristics of the Systematic Reviews

The nine systematic reviews that met the inclusion criteria were a heterogeneous group (see Appendix F^*^Evidence Table 13). All included systematic reviews were published between 1990 and 2006. Eight of the reviews evaluated the role of simulation in skill acquisition, while two reviews^28^,^158^ evaluated the role of simulators in knowledge acquisition. Out of the eight reviews that evaluated the role of simulation in skill acquisition, five reviews^26^,^29^–^31^,^159^ addressed the effectiveness of simulation in training procedural or surgical skills, two reviews^158^,^160^ addressed the effectiveness of simulation in training on communication skills, and two reviews^158^,^159^ examined the effectiveness of simulation in training on physical examination skills. One study^27^ addressed the general features and uses of high-fidelity simulation in effective learning. Five reviews^26^,^27^,^31^,^159^,^160^ clearly stated the study question to allow replication of the results, while four other reviews^28^–^30^,^159^ only partially stated the study question.

Types of simulation studied. A wide variety of simulation-based methods were identified in these reviews. Two reviews^26^,^30^ included studies that had evaluated virtual reality, two reviews^31^,^159^ included studies with full simulation, three reviews^28^,^158^,^160^ included studies with standardized patients or role play, five reviews^29^–^31^,^158^,^159^ included studies with partial task simulation, and six reviews^28^–^31^,^158^,^159^ included studies with computer simulation. All reviews had studies that compared simulation-based training with another type of simulation-based training, other educational intervention, standard training, no education, or no training.

Study populations and study designs. Three reviews^26^,^158^,^160^ restricted inclusion criteria to studies that had enrolled only medical students or physicians-in-training. Other reviews also included studies that enrolled, in addition to medical students and physicians-in-training, fully-trained physicians, nurses, allied health professionals, and non-medical personnel. One review^31^ included only randomized controlled trials, while other reviews included non-randomized controlled trials and prospective trials in addition to randomized controlled trials.

### Effectiveness of Simulation in Teaching Procedural Skills

Since the reviews often included a variety of studies, depending on the focus of the review, each systematic review was further broken down by the number of studies which addressed the effectiveness of simulation as an educational method (see Table 5 and Appendix F, Evidence Table 14).

Table 5 Quantity and direction of evidence for effectiveness of simulation

Learning objectives | Number of reviews which addressed learning objective | Number of studies which addressed effectiveness of simulation as an educational method | Direction of evidence
Psychomotor Skills | 6^26^,^29^–^31^,^158^,^159^ | 63 | Favors simulation
Communication Skills | 2^158^,^160^ | 14 | Favors simulation
Cognitive Skills | 2^28^,^159^ | 37 | Mixed results

Three reviews evaluated the effectiveness of virtual reality in teaching surgical skills. In virtual reality, the surgical field is represented in three dimensions which may help in learning more accurate surgical planning and procedures. One meta-analysis^26^ found that training in a virtual reality environment significantly decreases the total amount of time required for task completion. There was also a trend toward a decreased error rate which did not reach a statistically significant level. Another systematic review^29^ found four studies that evaluated the role of virtual reality in training surgical techniques. Two studies in this review found improvement in surgical skills after training with a virtual reality simulator while two other studies found no significant improvement after training with virtual reality simulators. A third systematic review^31^ found that trainees trained on computer simulation perform better than those who received no training, however, studies found an inconsistent benefit of computer simulation if simulation-trained students were compared with those who received standard training. This systematic review found only one study in which computer simulation was found to be superior to a physical training model. On the other hand, this review found that physical or model simulation may be superior to no training and standard training as instructions from mentors or manuals.

Video simulation was studied in one review.^31^ Video simulation was not superior to standard training or no training, and there was insufficient evidence to support the superiority of computer simulation to video simulation.

One review^30^ evaluated the effectiveness of simulators for training in gastrointestinal endoscopy and concluded that flexible sigmoidoscopy can be applied for clinical training of residents and fellows for better patient comfort only. However, this review did not find enough evidence to support the use of simulators for clinical training in gastrointestinal endoscopy to improve clinical outcomes.

Another review^159^ found one study with a cross-over design that reported a better post-test score (on a 22-object written test) of the anesthesia residents who were trained on a simulator as compared to those who were not trained.

### Effectiveness of Simulation in Teaching Physical Examination

Two systematic reviews evaluated the effectiveness of simulation in teaching physical examination. One review^158^ found that use of standardized patients to teach breast examination to medical students was associated with better performance in a clinical skills examination. This review further found that use of standardized patients or breast examination models was associated with improved ability of the students to detect breast lumps. The second review^159^ found that use of a patient simulator was associated with improved practical skills as measured on a post-test examination.

### Effectiveness of Simulation in Teaching Communication Skills

Two reviews evaluated the effectiveness of simulation in teaching communication skills. One review^158^ found that when students were taught communication skills by patients with cancer, including training for giving bad news, students were more likely to respond empathetically to patients and better able to communicate bad news than students who were not taught communication skills by patients with cancer. This review further found that role-playing may be important in teaching oncology-specific communication skills as well as in communicating bad news. The second review^160^ found that use of standardized patients and role-play was effective in teaching medical students smoking cessation counseling skills. This review further found that the use of standardized patients in teaching tobacco cessation skills to medical students was associated with increased confidence of students in their smoking cessation counseling skills.

### Effectiveness of Simulation in Knowledge Acquisition

We found two reviews^28^,^159^ that addressed the effectiveness of simulation in knowledge acquisition. Hmelo^28^ found that computer assisted models are effective in teaching pathophysiologic principles to medical students. The pooled effect size, which measures the combined magnitude of the effect of intervention across 33 studies, was 0.63 for use of computer assisted learning (in favor of simulation). One study included in Ravert^159^ looked at computer-based trauma simulation to teach trauma management; individual-study effect sizes ranged from -0.04 to 0.35 (did not favor simulation or were neutral). This review^159^ did not report on the pooled effect size.

### Features of High-Fidelity Simulators for Effective Learning

One review^27^ systematically evaluated the features of high-fidelity simulators essential for effective learning. This review found that the following features of a high-fidelity simulator were important for effective learning: should provide feedback during learning experience, allow repetitive practice, can integrate in overall curriculum, has increasing levels of difficulty, is adaptable to multiple learning strategies, can allow clinical variation in a simulated environment, provides controlled environment to make and detect mistakes without consequences, provides individualized and standardized learning, defines outcomes clearly, and must have face validity-realism of simulator.

### Summary

Overall the direction of evidence points to the effectiveness of simulation training, especially in psychomotor skills (e.g., procedures or physical examination techniques) and communication skills, but the strength of the evidence was considered low, due to the small number of appropriate studies, the scarcity of quantitative data, and other limitations. Several factors may be responsible for the inadequate quality of evidence in support of this method. In our view the most important factor is the lack of widely-accepted and standardized methods to quantify the competency in procedural or communication skills. In addition, the high cost of simulation methods and difficulty in introducing clinical realism in a simulated environment are other factors that may be responsible for inadequate quality of evidence in this field.

## Key Question 4: Which characteristics of the audience by themselves or in combination with other characteristics influence the effectiveness of certain educational techniques?

## Key Question 5: Which external factors by themselves or in combination with other factors reinforce the effects of CME in changing behavior?

We sought to evaluate the impact of both internal audience characteristics and external factors on the effectiveness of CME. Certain audiences may respond differently to an educational intervention, and it would be important to determine the most effective means to educate these subgroups. Specifically, we were interested in whether certain audience characteristics, such as gender and years in practice, might influence the effectiveness of certain educational techniques. Likewise, we wished to determine whether the presence of specific external factors or incentives might affect the short-term and long-term outcomes of CME activities. Both types of factors could impact future CME course design. Table 6 contains a list of the relevant internal and external factors that we considered.

Table 6 Internal audience characteristics and external factors examined in the review

Internal Audience Characteristics | External Factors
- Age; - Gender; - Practice setting; - Years in practice; - Specialty; - Foreign vs. U.S. medical graduate; - Country of practice; - Personal motivation; - Non-monetary rewards/motivations; - Learning satisfaction; - Knowledge enhancement | - Regulation; - State licensing board; - Professional boards; - Hospital credentialing; - External audits; - Monetary/financial rewards; - Academic advancement; - Provision of tools; - Public demand/expectations; - CME credit

### Audience Characteristics

Thirteen studies examined the influence of audience characteristics on the educational intervention that was evaluated.^33^,^39^,^53^,^61^,^69^,^70^,^79^,^80^,^92^,^101^,^105^,^140^,^161^ In only one of these studies was evaluation of these characteristics considered the primary goal of the paper.^105^Evidence Table 15 contains a description of the studies reviewed, grouped by the audience characteristic examined. We excluded characteristics that were unique to individual outcome measures (e.g., Medicaid practice size, nursing home practice size) and instead focused on features of the audience that were evaluated more frequently (see Table 6). We also specifically searched for articles that described personal motivation factors (e.g., knowledge enhancement and non-monetary rewards) in their analysis but could not find any.

Six studies examined the effect of years in practice on the educational intervention.^33^,^53^,^79^,^80^,^92^,^140^ Beaulieu, et al. suggested that physicians with less than 11 years of experience ordered fewer unnecessary screening tests than those with more experience, however, these results were not stratified by the educational technique actually employed by individual physicians.^140^ Two other studies suggested that physicians with greater experience who underwent educational interventions had improvements in attitudes^33^ and self-reported practice behavior.^53^ However, none of the studies examined revealed a relationship between years in practice and acquiring knowledge, acquiring skills, or changing practice outcomes. Similarly, age had no influence on the outcomes of educational interventions in the 6 studies that reported on the effects of age.^39^,^79^,^80^,^101^,^105^,^161^

Of the five studies^39^,^53^,^79^,^80^,^161^ that analyzed the effect of gender, only one showed a significant association. Leopold, et al. showed that women improved more than men in confidence with an objective performance of knee joint injections after an educational intervention consisting of printed material, hands-on instruction, or video instruction.^80^ Only one paper described the influence of race on the effectiveness of the educational intervention.^79^ Grady, et al. suggested that non-whites who underwent a presentation on mammography screening followed by cue enhancement (i.e., chart stickers and clinic posters) improved their screening rates more than whites.^79^ This study also suggested that the intervention had a greater effect on solo practitioners compared to those in other practice settings. Three studies that examined the influence of board certification on educational outcomes primarily focused on internists and family practitioners and failed to show an association between certification and the desired outcome.^53^,^79^,^105^

Conclusions and Limitations. We cannot reach definitive conclusions regarding the influence of audience characteristics on the effectiveness of specific educational techniques due to the heterogeneity of the educational interventions and characteristics examined. Furthermore, there are very limited data regarding any specific characteristic and the overall quality of the existing data on these questions are suboptimal.

### External Factors

The literature is limited about the role of external factors, by themselves or in combination with other factors, in reinforcing the effects of CME on changing behavior. Very few studies explicitly stated that such factors were examined independently or collected data regarding these factors. Only one study rigorously examined external factors as a primary outcome.^79^ Grady et al. studied whether token monetary rewards in addition to an educational intervention and chart cues increased the rate of mammography referral. While chart cues were effective in increasing mammogram referral and completion rates, the addition of a token monetary incentive provided no added benefit.

The offering of CME credit would not intuitively appear to be an external motivating factor for behavior change. Yet, two studies specifically examined the role of offering CME credit for this purpose, so it was included in our analysis. Both of these studies looked at results in association with earning CME credit for the educational activity.^106^,^156^ Chassin and colleagues examined in a subgroup analysis the effect of offering CME credit for attendance at educational programs designed to decrease inappropriate x-ray pelvimetry rates in 64 study hospitals.^162^ They found no significant difference among intervention participants with respect to the offering of CME credit; both groups had a comparable decrease in pelvimetry use. Messina et al. found a potential association of offering CME credit for a physician educational program with an increase in the use of screening mammography in women who had never undergone mammography, but it did not reach statistical significance. The trend did not hold true for previous mammogram users.^156^ These findings may be because CME credit may be an inducement to attend a CME activity but may not be sufficient to engage the participant in active learning.

Some CME courses utilize the signature of a “commitment-to-change” statement as an external motivating factor to improve clinical outcomes. Two studies examined the effectiveness of such a practice.^161^,^163^ Mazmanian and colleagues randomized 110 physicians to signature versus non-signature groups. While they found that those expressing an intent to change were more likely to change practice behavior (as documented by self-report on a follow-up survey), the act of signing such a commitment-to-change statement had no effect.^161^ In a much smaller study of 16 physicians attending a geriatrics course, Pereles et al. found that the physicians who were asked to make written commitments for practice changes (n=7) made more changes than controls at both one and three months followup. The results are of unclear statistical significance given the small study numbers.^163^

Conclusions and Limitations. There are several barriers to collecting data on external factors. First, it is methodologically difficult to offer incentives (such as CME credit or financial reward) in a controlled fashion. Second, most evaluation of external factors is based on self-report. Finally, small study sizes often preclude a valid analysis of external factors in subgroup analyses due to lack of adequate power. Consequently, it is difficult to draw conclusions regarding the effectiveness of external factors in enhancing CME effects on behavior.

## Key Question 6: What is the reported validity and reliability of the methods that have been used for measuring the effects of CME in terms of a) imparting knowledge, b) changing attitudes, c) acquiring skills, d) changing practice behavior, or e) changing clinical practice outcomes?

### Background

Valid and reliable evaluation tools are necessary to demonstrate the effectiveness of CME interventions. The validity of the evaluation method is “the degree to which the method truly measures what it is intended to measure.”^11^ A valid evaluation method accurately measures achievement of the stated objective of the educational intervention, whether it involves knowledge, attitudes, skills, practice behaviors, or clinical outcomes. The reliability of the evaluation method is “the consistency or reproducibility of measurements.”^11^ A reliable evaluation method allows educators to have confidence in their assessments of learning across multiple measurements. As one measurement expert emphasizes, “small amounts of unreliability may cause misclassification errors and large score differences on retesting.”^164^

An evaluation method may be statistically reliable without being valid for the objective intended by the investigators. However, a method cannot be valid without being reasonably reliable. Thus, Downing argues that “reliability is a necessary but not sufficient condition for validity, and reliability is a major source of validity for all assessments.”^164^

An educational study may employ a newly created evaluation method or one that previously has been shown to be valid and/or reliable in another study population. The creation of a new evaluation method consumes time and resources for pilot testing, cognitive testing, and psychometric analyses to determine the validity and reliable of the new method. However, a previously used method may not be a valid measure for a new educational intervention if it does not map appropriately to the stated objective. Also, the reliability of a method changes as it is applied in different populations and ideally should be re-measured each time.

### Results

We found reports of the validity and/or reliability of at least one evaluation method in 46 out of 136 total articles (33.8 percent). Among these 46 articles, 11 reported on the validity and/or reliability of more than one method: eight studies described two methods;^42^,^43^,^48^,^52^,^60^,^72^,^137^,^144^ two studies described three methods;^55^,^84^ and one study described four methods.^32^ Thus, 61 evaluation methods were accompanied by validity or reliability data. For the results below, percentages are based on the total number of methods - rather than articles - since some articles reported on multiple methods.

Among these 61 evaluation methods, 30 (49.2 percent) were drawn from previous studies and 28 (45.9 percent) were created for the current studies. For 3 methods (4.9 percent), it was not clearly reported whether the method was newly created or previously used. For 22 of the 30 previously used methods, the authors reported that reliability had been assessed: 13 within the current study population, 8 within previous study populations, and 1 within current and previous study populations. However, only 14 methods were presented with specific statistical data to support this reliability. For 12 of the 30 newly created methods, the authors reported that pilot and/or cognitive testing was performed.

Appendix F^*^, Evidence Table 16 presents the 61 evaluation methods, organized by type of outcome.

Knowledge or cognitive skills were evaluated by 15 methods (24.5 percent).

Attitudes were evaluated by seven methods (11.5 percent). Two methods focused exclusively on attitudes, while five methods evaluated a combination of attitudes and knowledge / cognitive skills.

Skills (communication, psychomotor, or procedural) were evaluated by 11 methods (18.0 percent). One method evaluated physical exam skills in an educational setting. A combination of skills (communication, psychomotor, or procedural) and practice behaviors were measured by 10 methods, using standardized patients to visit physicians at their practice setting or analyzing interactions with real patients.

Practice behaviors (without clinical outcomes) were evaluated by 20 methods (32.8 percent). Seven methods used self-report by physicians of their practice behaviors. Three methods used patients' report of their physicians' behaviors in their medical care. Ten used chart review of medical records and/or claims data.

Clinical outcomes (with or without practice behaviors) were evaluated by 8 methods (13.1 percent). Two studies used chart review. One used reports by patients or families of their attitudes. One study used patient satisfaction. Two studied patient reports of their own behavior — including medication adherence and participation in preventive screening — as the outcome. One study used patients' reports of preventative services provided by their physicians. Three used measures of the patient's health.

The following articles provide notable examples for reporting of the validity or reliability of educational outcome measures:

- [underlined: Knowledge or cognitive skills:] Fordis et al^42^ describes the development of a knowledge test for cholesterol management, including: content validation by experts; description of the test and response options; piloting and item number reduction; and high internal consistency reliability (Cronbach alpha = 0.79).
- [underlined: Attitudes:] Mann et al^52^ describes the development of a knowledge and attitudes test about cholesterol management, including: content validation by experts; need for >90 percent agreement on question inclusion and consistency; description of the test and response options; pilot testing with internal consistency testing in the pilot population (KR20 = 0.60); and test-retest reliability analysis using control group test scores.
- [underlined: Skills (communication, psychomotor, or procedural):] Roter et al^84^ describes a coding system to rate physicians' proficiency in managing standardized patients' emotional distress, including: blinding of coders; dichotomous coding system; and internal consistency reliability (Cronbach alpha = 0.20–0.62 for shorter scales, 0.76–0.81 for longer scales, and 0.62 for overall score).
- [underlined: Practice behaviors:] Sibley et al^136^ describes chart abstraction for quality of care, including: content validity of pre-determined criteria by experienced clinicians; rating system; training of blinded nurse-abstractors; and high interrater and intrarater reliability (kappa >0.8).
- [underlined: Clinical outcomes:] Roter et al^84^ describes use of the General Health Questionnaire-28 to detect emotional distress in patients, including: citation of original source for this previously validated questionnaire; repeated reliability testing with the study population, yielding high internal consistency (Cronbach alpha = 0.90–0.92).

Table 7 presents the number of evaluation methods for each type of validity or reliability, as well as tallies for each type of outcome within each validity or reliability. Of note, methods may capture more than one type of outcome and may be repeated in more than one column for each row. Of 61 evaluation methods with validity or reliability reported, 16 (26 percent) included descriptions of validity alone, 29 (48 percent) included descriptions of reliability alone, and ten (16 percent) had descriptions of both validity and reliability. For six methods (10 percent), the methods were described as valid and/or reliable, but the specific type of validity or reliability was not reported.

Table 7 Number of methods evaluated for each type of validity or reliability, organized by outcome type

Type of Validity | Definition* | # of Methods | Knowledge or cognitive skills^†^ | Attitudes^†^ | Skills (communication or psychomotor)^†^ | Practice Behaviors^†^ | Clinical Outcomes^†^
Content | Degree to which an instrument accurately represents the skill or characteristic it is designed to measure, based on people's experience and available knowledge | 16 | 15^21^,^32^,^36^,^38^,^40^,^42^,^46^,^48^,^51^–^54^,^57^,^85^,^142^ | 3^51^–^53^ | 0 | 2^53^,^136^ | 0
Concurrent criterion | Degree to which an instrument produces the same results as another accepted or proven instrument that measures the same variable | 8 | 1^142^ | 1^82^ | 1^25^ | 6^16^,^25^,^72^,^82^,^137^,^144^ | 2^47^,^137^
Predictive criterion | Degree to which a measure accurately predicts expected outcomes | 1 | 0 | 0 | 0 | 1^78^ | 0
Construct | Degree to which an instrument measures the theoretical construct it intends to measure | 5 | 3^36^,^43^,^85^ | 0 | 0 | 2^53^,^104^ | 0
Type of Reliability | Definition | # of Methods | Knowledge or cognitive skills^†^ | Attitudes^†^ | Skills (communication or psychomotor)^†^ | Practice Behaviors^†^ | Clinical Outcomes^†^
Internal consistency | How well items reflecting the same construct yield similar results | 19 | 12^36^,^40^,^42^,^45^,^48^,^49^,^52^,^53^,^55^,^63^,^64^,^85^ | 8^45^,^49^,^52^,^53^,^55^,^62^–^64^ | 2^32^,^84^ | 6^32^,^45^,^49^,^53^,^72^,^84^ | 3^55‡84^
Inter-rater | Degree to which measurements are the same when obtained by different persons | 16 | 1^85^ | 0 | 6^32^,^60^,^84^,^88^,^138^,^140^ | 13^32^,^42^,^76^,^84^,^88^,^108^,^118^,^132^,^134^,^136^,^138^,^140^,^144^ | 2^132^,^137^
Intra-rater | Degree to which measurements are the same when repeated by the same person | 2 | 0 | 0 | 0 | 2^48^,^136^ | 0
Equivalence | Degree to which alternate forms of the same measurement instrument produce the same results | 4 | 3^17^,^36^,^54^ | 0 | 0 | 1^53^ | 0
Test-retest | Degree to which the same test produces the same results when repeated under the same conditions | 5 | 3^52‡53^ | 2^52^,^53^ | 0 | 3^22^,^53^,^134^ | 0
Validity: not specifically reported | | 4 | 0 | 1^72^ | 3^32^,^43^,^72^ | 3^32^,^72^,^121^ | 1^81^
Reliability: not specifically reported | | 5 | 1^60^ | 0 | 1^32^ | 2^32^,^121^ | 1^81^

* Definitions were obtained from Reed, et al.^11^

† Methods referenced may target more than one type of outcome and are listed under each applicable column.

‡ Two assessment methods within the same article.

Validity was reported for 31 of 61 evaluation methods (50.8 percent). Content validity was reported for 16 methods. The specific “experts” who reviewed the assessment were reported for 11 of these 15 methods. Concurrent criterion validity was reported for 8 methods. Predictive criterion validity was reported for only 1 method, which involved a comparison between physicians' reports of asthma management behaviors and patients' reports of physician behaviors. Construct validity was reported for 5 methods, usually through “known-group validity” (establishing construct validity by demonstrating better scores among those with higher levels of training or clinical experience). High statistical validity was only demonstrated for two methods.^72^,^137^ Five methods were described as valid without specific details. Thus, the vast majority of CME studies offered no or limited psychometric data for the validity of their evaluation methods.

Reliability was reported for 43 of 61 evaluation methods (70.5 percent). Internal consistency reliability was reported for 19 methods, including 13 learner instruments, 1 observer instrument for audio-taped interactions, 1 standardized patient instrument, and 3 clinical patient instruments. Inter-rater reliability was reported for 16 methods, including 9 medical data abstractions and 6 skills assessments. Intra-rater reliability was assessed for 2 medical data abstraction studies. Equivalence reliability was reported for 4 methods, and test-retest reliability for 5 methods. Four methods were described as reliable without specific details. When reported, statistical tests yielded primarily modest evidence of reliability based on Cronbach-alpha, Kappa, or correlation statistics.

### Conclusions

- Forty-six of 136 articles (34 percent) reported the validity and/or reliability of at least one evaluation method for assessing the effectiveness of CME.
- Thirty methods were drawn from previous studies, and 28 were created for the current studies. For 3 methods, the source was unclear. Authors did not commonly report reliability testing within the new study population for methods found to be reliable in other populations.
- The most common type of outcome evaluated by valid and/or reliable evaluation methods involved practice behaviors, for 20 out of 61 methods (34 percent).
- Of 61 evaluation methods with validity or reliability reported, 16 (26 percent) included descriptions of validity alone, 29 (48 percent) included descriptions of reliability alone, and ten (16 percent) had descriptions of both validity and reliability. For six methods (10 percent), the methods were described as valid and/or reliable, but the specific type of validity or reliability was not reported.
- Among these 61 methods, content validity was the most commonly reported type of validity (26 percent).
- Among these 61 methods, internal consistency (31 percent) and inter-rater (28 percent) were the most common types of reliability reported.

Although many studies of the effectiveness of CME have considered the validity or reliability of their evaluation methods, relatively few studies have used methods that have strong evidence of both construct and criterion validity. In addition, relatively few studies have used evaluation methods that have strong evidence of each of the specific types of reliability (internal consistency, inter-rater, intra-rater, equivalence, and test-retest). We therefore conclude that the overall strength of evidence on the effectiveness of CME is limited by weaknesses in the evaluation methods that have been used. To strengthen the evidence base on the effectiveness of CME, it will be necessary to commit additional resources to the development of valid and reliable evaluation methods. This may be quite challenging because of the limited resources that generally are available to clinician-educators. Where appropriate, educators may save time and resources by using previously validated and reliable methods, but they must demonstrate the validity of these methods for their specific educational outcomes and the reliability of these methods for their particular study populations.