# Methods

The ACCP requested an evidence report to review and synthesize published literature regarding the effectiveness of CME, the comparative effectiveness of instructional designs for CME, and their impact on imparting knowledge, changing attitudes, acquiring skills, changing practice behavior, and changing clinical practice outcomes. Our EPC established a team and a work plan to develop the evidence report. The project consisted of recruiting technical experts, formulating and refining the specific questions, performing a comprehensive literature search, summarizing the state of the literature, constructing evidence tables, synthesizing the evidence, and submitting the report for peer review.

## Topic Development

The topic for this report was nominated in a public process. At the beginning of the project, we recruited a panel of external technical experts to give input on key steps including the selection and refinement of the questions to be examined. The panel included external experts who have strong expertise in CME (see Appendix A^a^).

a Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/cmetp.htm

We worked with the technical experts and representatives of AHRQ and ACCP to develop the Key Questions that are presented in the Scope and Key Questions section of Chapter 1 (Introduction). Based on the feedback from the technical experts, AHRQ, ACCP, and our team members, we expanded the preliminary questions to include knowledge, attitude, skills, practice behavior, and clinical outcomes and to address potential synergies between learning methods. We refined Key Question 3 to focus on the effectiveness of simulation methods used in medical education. Additionally, we added Key Question 6, which assesses the validity and reliability of tools used to evaluate the effectiveness of CME. The Key Questions focus on the effectiveness of CME in (1) imparting knowledge, (2) changing attitudes, (3) acquiring skills, (4) changing practice behaviors, or (5) changing clinical practice outcomes. We considered any test of physician or CME participant knowledge as knowledge. Attitudes were limited to physician or CME participant attitudes; attitudes could include physician attitudes toward a medical topic, physician comfort level, or satisfaction with the course. Skills were divided into cognitive skills (ability to apply knowledge) and psychomotor skills (e.g., procedures or physical examination techniques). Practice behavior referred to any type of physician behavior. We defined clinical outcomes as any change in patient health status, health-related behavior of patients, or attitudes of the patients about the physicians toward whom the CME intervention was directed. Thus, in addition to direct measures of health status such as blood pressure and fasting blood glucose, we also included indirect measures such as patient satisfaction, medication adherence, and smoking cessation.

## Search Strategy

Searching the literature included the steps of identifying reference sources, formulating a search strategy for each source, and executing and documenting each search. Additionally, we searched for medical subject heading (MeSH) terms that were relevant to CME. We used a systematic approach for searching the literature, with specific eligibility criteria, to minimize the risk of bias in selecting articles for inclusion in the review. The systematic approach was intended to help identify gaps in the published literature.

Our comprehensive search plan included electronic and hand searching. Beginning in February of 2006 we ran searches of the following databases: MEDLINE^®^, EMBASE^®^, the Cochrane Database of Systematic Reviews, The Cochrane Central Register of Controlled Trials (CENTRAL), the Cochrane Database of Abstracts of Reviews of Effects (DARE), PsycINFO^©^, and the Educational Resource Information Center (ERIC^®^), to identify primary literature on the effectiveness of CME and systematic reviews on the effectiveness of simulation techniques in medical education.

Hand searching for possibly relevant citations took several forms. From our electronic search, we identified the 13 journals (see Appendix B^a^) that were most likely to publish articles on this topic (i.e., these journals had the highest number of abstracts and articles included in the review). We scanned the table of contents of each issue of these journals for relevant citations from February 2005 through February 2006. For the second form of hand searching, reviewers received eligible articles and flagged references of interest for the team to compare to the existing database.

Search strategies, specific to each database, were designed to enable the team to focus available resources on articles most likely to be relevant to the Key Questions. Initially, we developed a core strategy for MEDLINE^®^, accessed via PubMed^®^, based on an analysis of the MeSH terms and text words of key articles identified a priori. The PubMed^®^ strategy formed the basis for the strategies developed for the other electronic databases (see Appendix C^a^).

The results of the searches were downloaded and imported into ProCite^®^ version 5 (ISI ResearchSoft, Carlsbad, CA). We used the duplication scan feature in ProCite^®^ to delete citations already retrieved. From ProCite^®^, the articles were uploaded to SRS 3.0 (TrialStat! Corporation, Ottawa, Ontario, Canada), a Web-based software package developed for systematic review data management. Additionally, this database was used to store citations in portable document format (PDF) and to track the search results at title review, abstract review, article inclusion/exclusion, and data abstraction levels. A list of excluded articles is presented in Appendix D^a^.

## Study Selection

After the electronic databases were searched, citations were downloaded into ProCite®, and uploaded to the SRS 3.0 tracking system. The study team scanned all titles. Two independent reviewers conducted title scans in a parallel fashion. For a title to be eliminated at this level, both reviewers had to indicate that it was ineligible. If the two reviewers did not agree on the eligibility of an article, it was promoted to the next level (see Appendix E^a^, Title Review Form). The title review phase was designed to capture as many studies as possible reporting on the effectiveness of CME or as many systematic reviews reporting on the effectiveness of simulation in medical education. All titles that were thought to address the above effectiveness issues were promoted to the abstract review phase.

The abstract review phase was designed to identify studies reporting on the effects of CME or simulation in medical education on clinical practice in terms of knowledge, attitudes, skills, practice behaviors, or clinical outcomes. All articles with abstracts meeting these criteria were kept for further review. Abstracts were reviewed independently by two investigators. Abstracts concerning the effectiveness of CME were excluded if both investigators agreed that the article met one or more of the following exclusion criteria: (1) not written in English; (2) contained no human data; (3) no original data and did not apply to Key Question 3; (4) was a meeting abstract, editorial, commentary, or letter; (5) did not include at least 15 fully trained physicians or less than 50 percent of the CME participants were fully trained physicians and there was not a separate analysis for fully trained physicians; (6) did not include training or education; (7) did not evaluate an educational activity; (8) published prior to 1981; (9) not conducted in the United States or Canada; (10) did not apply to a Key Question; (11) did not include data from a concurrent or historical comparison group; or (12) involved quality improvement without an educational activity. Since CME accreditation from the Accreditation Council for Continuing Medication Education began in 1981, we decided to limit our review to studies published after that date. We decided to exclude studies not conducted in the United States or Canada because we felt that the medical education systems in other countries could be very different from and not relevant to CME in the United States. To qualify for Key Question 6, an abstract must also address at least one of the other key questions.

Abstracts concerning the effectiveness of simulation in medical education were excluded if both investigators agreed that the article met one or more of the following exclusion criteria: (1) not written in English; (2) contained no human data; (3) was not a systematic review (i.e., identified a question, described a search strategy, described eligibility criteria, and synthesized results either quantitatively or qualitatively); (4) was a meeting abstract, editorial, commentary, or letter; (5) did not include medical students or physicians-in-training; (6) did not include medical training or education; (7) did not evaluate an educational activity; (8) did not involve simulation, virtual reality, manikins, or standardized patients; (9) published prior to 1990; (10) did not apply to Key Question 3; (11) included only fully trained physicians or CME; or (12) did not report separately on the effects of simulation. The decision to limit our review to reviews published after 1990 was based partly on when simulation began to be used in medical education and partly on a desire to focus on reviews that are not too out-of-date. The cut-off date for inclusion in this review was February 2006. Differences in opinions regarding abstract inclusion or exclusion were resolved through consensus adjudication. At this level of inclusion/exclusion, the reviewers were also asked to identify which Key Questions the article might apply to if the article was eligible.

Because of the broad array of potentially eligible articles obtained at the abstract review phase, full articles initially selected for review underwent another independent parallel review by investigators to determine if they should be included for full data abstraction. At this phase of the review, investigators determined which of the Key Questions each article addressed (see Appendix E, Article Inclusion/Exclusion Form). If articles were still deemed to have applicable information, they were included in the final article review. Differences in opinions regarding article inclusion or exclusion were resolved through consensus adjudication.

## Data Extraction

The purpose of the article review was to confirm the relevance of each article to the research questions, to determine methodological characteristics pertaining to study quality, and to collect evidence that addressed the research questions. Articles eligible for full review could address one or more of the Key Questions. We used standardized forms for data extraction to minimize the risk of bias in how data were extracted from eligible studies and to maximize consistency in identifying all pertinent data available for synthesis. Additionally, we developed definitions and created examples, which were reviewed by the study team, to enhance the consistency of data extraction.

Each article underwent double review by study investigators for full data abstraction and assessment of study quality. For all data abstracted from studies, we used a sequential review process. In this process, the primary reviewer completed all data abstraction forms. The second reviewer confirmed the first reviewer's data abstraction forms for completeness and accuracy. Reviewer pairs were formed to include personnel with both clinical and methodological expertise. A third reviewer re-reviewed a random sample of articles by the first two reviewers to ensure consistency in the classification of the articles. Reviewers were not masked to the articles' authors, institution, or journal.^7^ In most instances, data were directly abstracted from the article. If possible, relevant data were also abstracted from figures. Differences in opinion were resolved through consensus adjudication. For assessments of study quality and the reporting of adult learning principles, each reviewer independently judged study quality and reporting and rated items on quality assessment and adult learning principles forms (see Appendix E, Data Abstraction Review Forms). The second reviewer provided the assessment of study quality and reporting of adult learning principles used in this report.

All information from the article review process was entered into the SRS 3.0 database by the individual completing the review. Reviewers entered comments into the system whenever applicable. The SRS 3.0 database was used to maintain and clean the data, as well as to create detailed evidence tables and summary tables (see Appendix F and Summary Tables).

### Data Abstracted to Assess the Effectiveness of CME (Key Questions 1 and 2)

For all articles containing original data, reviewers extracted information on general study characteristics, CME activity characteristics, and outcomes. The general study characteristics abstracted included study participants, sample size, study setting, evaluation methods, and study design. Data abstracted to the CME activity forms included: intervention or control; number assigned and number analyzed per group; description of group; timing of the educational exposure (i.e., single or multiple exposures); media utilized (i.e., the method through which the CME activity is delivered; see Table 1 for definitions); technique or educational method used (see Table 2 for definitions); whether the intervention was designed for individuals or practice settings; average time spent in the CME activity; average duration of the educational intervention; the number of days/week exposed to the CME activity; length of time from the end of the CME activity to the last evaluation period; whether the CME activity was accredited; and whether the CME activity was a part of a quality improvement project. Reviewers used the outcomes form to abstract data regarding: the main outcome measure; the type of objective (knowledge, attitudes, skills, practice behaviors, and clinical outcomes); whether the learning objectives were met; a qualitative summary of the results; and the author's overall conclusions. For whether learning objectives were met, reviewers were instructed to mark “yes” if most of the measures showed improvement, “no” if most of the measures showed a lack of improvement, “mixed results” if the results were mixed, “no control group” if there was not an appropriate control group to answer the question appropriately and “unclear” if the results were unclear.

Table 2 Definitions of techniques/educational methods

Technique/Educational method | Definition
Academic detailing | Detailing provided by an institution or hospital
Audience response systems | Addresses knowledge objectives. Used in combination with live lectures or discussion groups, these are computerized feedback tools that allow the teacher/instructor to pose a question to a large group and receive immediate feedback from each learner which is collated and presented on a screen. Instructor may choose to alter content based on audience response
Case-based learning | Addresses higher order knowledge and skill objectives. Actual or authored clinical cases are created to highlight learning objectives; clinical material is presented and followed with questions usually determined by the instructor
Clinical experiences | Addresses skill, knowledge and attitudinal objectives. Generally refers to a preceptorship or observership with an expert, as in attending a specialty clinic or operating room
Demonstration | Addresses skill and or knowledge (knows how) objectives; can be presented live, or with video or audio. Teacher determines amount and pace of content
Discussion group | Addresses knowledge, especially application or higher order knowledge, or affective objectives; usually requires preparation with readings, or another experience, such as viewing a videotape, or a role play. Can be facilitated by instructor, but group often determines content
Feedback | The provision of information about an individual's performance to learners
Lecture | Presentation of knowledge content; live, video, audio or slide presentation available online. Teacher/instructor determines amount and pace of content
Mentor/Preceptor | Addresses higher order cognitive, skill and affective objectives. Learner is paired with a mentor who may observe, review documentation of performance, advise, coach, and facilitate learning
Point of care | Addresses knowledge and higher order cognitive objectives (decision-making). Information which is provided at the time of clinical need, integrated into chart or electronic medical record
Problem-based learning or team-based learning | Addresses higher order knowledge objectives, metacognition and some skill (group work) objectives. A clinical scenario is presented to a team, who identify the learning objectives, assign information-seeking tasks, and return to share information and answer questions about the case. Can be facilitated or non-facilitated
Programmed learning | Addresses knowledge objectives. Content is delivered in sequential steps, which are tested with the learner, before moving to the next, usually more complicated step. Pace is determined by the learner, but objectives are set by the program (teacher). Can be delivered in text or online
Readings | Presentation of knowledge content or background for attitudinal objectives. Requires learner to complete; can be done at learner's pace. Teacher/instructor directed or self-directed (e.g., journals, newsletters, searching online)
Role play | Addresses skill, knowledge and affective objectives. Learners assume role of patients and/ or clinicians in practicing focused encounters around training problems, usually when standardized patients are unavailable. Encounter may be recorded and reviewed or followed with a discussion group. Rarely used as sole method of education
Simulation (other than standardized patient or role-play) | Addresses knowledge and skill objectives; ability to simulate potentially addresses higher order integrative objectives, such as responding to an emerging clinical situation, understanding the unfolding of a protein structure, working in teams. Technology can be used for simulation training of procedures, as in endoscopy virtual reality trainers or anesthesia simulators. Includes also models, such as joint injection and suture. Requires active participation of learner; can use multiple learners in some scenarios
Standardized patient | Addresses skill and some knowledge and affective objectives. Usually used for communication skills training and assessment, the standardized patient or simulated patient is trained in a specific patient scenario and presentation of a clinical problem. Encounter may be audio or videotaped and timed. Review offers opportunity for reflection and “replay” of the scenario
Writing/Authoring | Addresses knowledge and affective objectives. Can include authoring test items and participation in test development. Journaling is used frequently for affective objectives, and may be followed with discussion groups or review with a mentor

Additionally, each reviewer independently completed a study quality form and a reporting of adult learning principles form. The study quality form was based on the Jadad criteria^8^ to assess randomization, blinding, and withdrawals, and included additional questions regarding power calculations. On the reporting of adult learning principles form, reviewers assessed how well the article reported the extent to which the CME activity incorporated adult learning principles, such as enabling learners to be active contributors to their learning, relating the curriculum to learners' current experiences, and tailoring the curriculum to learners' past experiences (Romsai Boonyasai, personal communication). The questions on the reporting of adult learning principles form was derived from a review of adult education.^9^

### Data Abstracted from Systematic Reviews on the Effectiveness of Simulation in Medical Education (Key Question 3)

We abstracted data from systematic reviews that evaluated the effectiveness of simulation in medical education (see Appendix E, Data Abstraction Review Forms). Data from systematic review articles were abstracted regarding the types of simulation and comparisons included in the review; types of healthcare professionals included in the review; exclusion criteria; search strategies (types of searches and end date of search); number of articles in the review; outcomes evaluated and the type of objective; meta-analyses conducted; summary of results; subgroup analyses, sensitivity analyses, and meta-regressions conducted; and overall conclusions. Definitions for the types of simulations are presented in Table 3 (Elizabeth Hunt, MD, Director, JHH Simulation Center, personal communication).

Table 3 Definitions of simulation types

Simulation type | Definition
Full simulation | Whole room or whole patient simulations
Partial task simulation | The use of products to learn or practice a specific skill, such as intubation heads, central venous line chests, intraosseous line legs, or umbilical artery cannulation trainers
Computer simulation | The use of computer programs that allow the student to practice decision making skills, specific knowledge sets such as Advanced Cardiac Life Support (ACLS) trainers and trauma management trainers
Virtual reality | The use of advanced computerized technology to allow students to learn or practice how to perform cardiac catheterizations, colonoscopies, bronchoscopies, ureteroscopies, laparoscopic surgery, hysteroscopy, arthroscopy, ocular surgery, intravenous line placement, etc.
Standardized patient | The use of individuals trained to play the roles of patients, family members, or others to allow students to practice physical exam skills, history taking skills, communication skills, etc.
Role play | Participants play roles of patients, family members, or others to allow practice of communication skills, etc.

Each reviewer also independently completed a study quality form. The study quality form was based off of the QUORUM statement^10^ and assessed the reporting of the study question, search methods, inclusion/exclusion criteria, analysis, quality assessment, and conclusions. Additional questions regarding assessment of publication bias were included.

### Data Abstracted to Assess the Influence of Audience Characteristics and/or External Factors on the Effectiveness of CME (Key Questions 4 and 5)

For studies addressing the influence of audience characteristics and/or external factors (Key Questions 4 and 5), an audience characteristics/external factors form (see Appendix E, Data Abstraction Review Forms) was completed. Data abstracted to this form included the audience characteristic or external factor that was being analyzed, whether a primary goal of the study was to assess the effects of this audience characteristic or external factor, any covariates used in the analysis, and a qualitative summary of the results. Additionally, reviewers abstracted data regarding general study characteristics, CME activity characteristics, outcomes, study quality, and the reporting of adult learning principles.

### Data Abstracted to Assess the Validity and/or Reliability of Tools (Key Question 6)

Data regarding validity and reliability of methods used to assess the effectiveness of CME (Key Question 6) were abstracted to a validity/reliability of tools form (see Appendix E, Data Abstraction Review Forms). Articles need not have used the specific terms “validity” or “reliability” to be included in Key Question 6. If authors did not label the specific type of validity or reliability reported, we classified the type based on the definitions from Reed et al.^11^ Articles that used a previously validated/reliable method were included if the authors described the method as valid/reliable or described a process or statistic used for psychometric testing. Reviewers also abstracted data regarding general study characteristics, CME activity characteristics, outcomes, study quality, and the reporting of adult learning principles.

## Quality Assessment

Article quality was assessed differently for clinical trials and systematic reviews. The dual, independent review of article quality judged articles on several aspects of each study type's internal validity. Quality assessment of trials was based on the Jadad criteria^8^ and included: (1) appropriateness of the randomization scheme, (2) appropriateness of the blinding, and (3) description of withdrawals and drop-outs. For each trial, we created a score between 5 (high quality) and 0 (low quality). Two questions regarding power calculations were added to this form, however, the answers to these questions did not factor into the quality score.

The quality of each systematic review was assessed using criteria based off the QUORUM statement^10^: (1) whether the question being addressed by the review was clearly stated; (2) comprehensiveness of search methods used and described in the report; (3) whether inclusion/exclusion criteria were clearly defined and appropriate; (4) whether analyses were conducted to measure variability in efficacy; (5) whether study quality was assessed and done appropriately (using validated instruments); (6) whether differences in how outcomes were reported and analyzed across studies were taken into consideration; (7) whether the study methodology was reproducible; and (8) whether conclusions were supported by the data presented. Additional questions regarding assessment of publication bias were included.

## Data Synthesis

For each Key Question, we created a set of detailed evidence tables containing all information extracted from eligible studies. The investigators reviewed the tables and eliminated items that were rarely reported. For Key Questions 1 and 2, the results were categorized and sorted based on the media method used, educational technique used, and the amount of exposure. Media methods were categorized into single print media (i.e., the CME activity used only print methods), single live media, single Internet media, other single media, multiple media (i.e., the CME activity used more than 1 media methods), and single vs. multiple media (i.e., the CME activity for one group used only 1 media method and the CME activity for the another group used more than 1 media methods). Educational techniques were categorized into single educational techniques (i.e., the CME activity used only 1 educational technique), multiple educational techniques (i.e., the CME activity used more than 1 educational techniques), single vs. multiple, and other/not reported. The amount of exposure was categorized into single exposure (i.e., the CME participants were exposed to the activity on only 1 occasion), multiple exposures (i.e., the CME participants were exposed to the activity on multiple occasions), single vs. multiple exposures, and other/not reported. Investigators used the resulting versions of the evidence tables to prepare the text of the report and selected summary tables.

For Key Question 6, the data were grouped according to similar evaluation methods to facilitate evaluating validity and reliability of these methods.

## Data Entry and Quality Control

Initial data were abstracted by investigators and entered directly into Web-based data collection forms using SRS^®^ 3.0 (TrialStat! Corporation, Ottawa, Ontario, Canada). After a second reviewer reviewed data, adjudicated data were re-entered into the Web-based data collection forms by the second reviewer. Second reviewers were generally more experienced members of the research team, and one of their main priorities was to check the quality and consistency of the first reviewers' answers. In addition to the second reviewers checking the consistency and accuracy of the first reviewers, a lead investigator examined a random sample of the reviews to identify problems with the data abstraction. If problems were recognized in a reviewer's data abstraction, the problems were discussed at a meeting with the reviewers. In addition, research assistants used a system of random data checks to assure data abstraction accuracy.

## Rating the Body of Evidence

At the completion of our review, we graded the quantity, quality and consistency of the best available evidence addressing Key Questions 1, 2, and 3 by adapting an evidence grading scheme recommended by the GRADE Working Group.^12^ We applied evidence grades to bodies of evidence on each type of objective (i.e., knowledge, attitudes, skills, practice behaviors, and clinical outcomes). We assessed the strength of the study designs with randomized controlled trials considered best, followed by non-randomized controlled trials, and observational studies. To assess the quantity of evidence, we focused on the number of studies with the strongest design. We also assessed the quality and consistency of the best available evidence, including assessment of limitations to individual study quality (using individual quality scores), certainty regarding the directness of the observed effects in studies, precision and strength of findings, and availability (or lack thereof) of data to answer the Key Question. We classified evidence bodies pertaining to Key Questions 1, 2, and 3 into four basic categories: (1) “high” grade (indicating confidence that further research is very unlikely to change our confidence in the estimated effect in the abstracted literature); (2) “moderate” grade (indicating that further research is likely to have an important impact on our confidence in the estimates of effects and may change the estimates in the abstracted literature); (3) “low” grade (indicating further research is very likely to have an important impact on confidence in the estimates of effects and is likely to change the estimates in the abstracted literature); and (4) “very low” grade (indicating any estimate of effect is very uncertain). We did not grade the body of evidence for Key Questions 4 and 5 since this is a subset of Key Questions 1 and 2. Also, we did not grade the body of evidence for Key Question 6 since the grading criteria do not apply to our questions about the validity and reliability of educational assessment methods.

## Peer Review and Public Commentary

A draft of the completed report was sent to the technical experts and peer reviewers, as well as to the representatives of AHRQ and the Scientific Resource Center. In response to the comments of the technical experts, peer reviewers, and AHRQ, revisions were made to the evidence report, and a summary of the comments and their disposition was submitted to AHRQ.