# Introduction

Continuing medical education (CME) was initiated by the American Academy of General Practice, which has required CME for membership since 1947.^1^ The American Medical Association (AMA) presently defines continuing medical education as “educational activities that serve to maintain, develop, or increase the knowledge, skills, and professional performance and relationships a physician uses to provide services for patients, the public, or the profession.”^2^ The AMA defines the content of CME as “that body of knowledge and skills generally recognized and accepted by the profession as within the basic medical sciences, the discipline of clinical medicine, and the provision of health care to the public.”^2^ In 1971 New Mexico became the first state to require CME credit for relicensure. Physicians commonly spend an average of 50 hours per year in CME activities geared toward improving their performance and optimizing their care of patients. Participation in CME is not voluntary as, in 41 states, it is a requirement for continued physician licensure and is often a requirement for hospital credentials and participation in many managed care plans. This has led to the proliferation of CME offerings aimed at providing physicians with the CME credits they require.

Despite the broad range of CME offerings aimed at educating the nation's practicing physicians through the provision of up-to-date clinical information, researchers have found that physicians commonly overuse, underuse, and misuse therapeutic and diagnostic interventions.^3^ Some medical educators have suggested that CME may not be effective enough to significantly narrow the gap between what is done in clinical practice and what should be done based on current evidence. Understanding what CME tools and techniques are most effective in disseminating and retaining medical knowledge is critical to improving the effectiveness of CME and thus diminishing the gap between evidence and practice.

To date, relatively little has been done to comprehensively and systematically synthesize evidence regarding the effectiveness of CME and the comparative effectiveness of differing instructional designs for CME and their impact on knowledge, attitudes, skills, practice behavior, and clinical practice outcomes. Review of evidence elucidating the value of CME (and ways the activities could be improved, if appropriate) could yield tremendous value to policy makers and professional organizations seeking to make policy recommendations regarding the optimal delivery of medical care. Such a review could have particular significance in light of the American Board of Medical Specialties (ABMS) recently initiated robust Maintenance of Certification (MOC) program that requires evidence of self-directed learning which is commonly accomplished through attendance at CME activities.^4^ In addition, as the National Institutes of Health (NIH) and the Agency for Healthcare Research and Quality (AHRQ) place more emphasis on translating scientific knowledge into clinical practice,^5^ educators will need to apply evidence-based approaches to CME that will support translating knowledge into practice. Furthermore, the published literature demonstrates a large gap between recommended processes of care and those delivered.^6^ Effective CME is required to help fill that gap.

The American College of Chest Physicians (ACCP) recognized the potential value of identifying and synthesizing the evidence in this area, and nominated this topic to the Evidence-based Practice Center Program (EPC) of AHRQ. In response to this request by the ACCP, the Johns Hopkins EPC performed a systematic review to address the following key questions pertaining to the effectiveness of CME:

1 Is there evidence that particular methods of delivering CME are more effective in: a) imparting knowledge to physicians, b) changing physician attitudes, c) acquiring skills, d) changing physician practice behavior, or e) changing clinical practice outcomes?
2 Do changes in knowledge, attitudes, skills, practice behavior, or clinical practice outcomes produced by CME persist over time (greater than or equal to 30 days)?
3 What is the evidence from systematic reviews about the effectiveness of simulation methods in medical education outside of CME?
4 Which characteristics of the audience by themselves or in combination with other characteristics influence the effectiveness of certain educational techniques?
5 Which external factors by themselves or in combination with other factors reinforce the effects of CME in changing behavior?
6 What is the reported validity and reliability of the methods that have been used for measuring the effects of CME in terms of a) imparting knowledge, b) changing attitudes, c) acquiring skills, d) changing practice behavior, or e) changing clinical practice outcomes?