# Appendix F: Evidence Tables

Table 1 Evidence Table. Characteristics of study design and evaluation methods in studies assessing the effectiveness of continuing medical education

Author, year | Study design, when evaluation conducted | Participant questionnaire | Observer assessment | Performance audit | Patient assessment | Qualitative evaluation | Lowest response rate
| | Administered (A) | Skill assessed (S) | Conducted (C) | Evaluated (E)
| | Evaluated (E) | Observer (O)
| | Response options (R) | Format (F)
Adams, 1998^125^ | RCT, post intervention only | NA | NA | NA | E: Provider knowledge, skill, behavior | Yes | >80%
Allison, 2005^147^ | RCT, pre and post intervention | NA | NA | C: HEDIS | NA | NR | NR
Andersen, 1990^36^ | RCT, pre and post intervention | A: Written | NA | NA | NA | No | NR
| | E: Knowledge (objective)
| | R: Multiple-choice, dichotomous, Likert scale
Anderson, 1996^103^ | RCT, pre and post intervention | NA | NA | C: Prescription information collected through the Triplicate Prescription Program provided by the British Columbia College of Physicians and Surgeons | NA | NR | >80%
Beaulieu, 2002^140^ | RCT, post intervention only | NA | S: Procedural skills, communication skills | NA | NA | No | 40–59%
| | | O: Educational program representative
| | | F: Live standardized patient
Beaulieu, 2004^44^ | Non-RCT, pre and post intervention | A: NR | NA | C: Health plan database | NA | No | 40–59%
| | E: Knowledge (self-reported), behavior (self-assessed)
| | R: Multiple-choice
Bjornson, 1990^14^ | RCT, post intervention only | A: Written | NA | C: Health plan database | NA | NR | 40–59%
| | E: Knowledge (self-reported), attitude, intent to change behavior (self-assessed)
| | R: Likert scale
Block, 1988^37^ | Non-RCT, post intervention only | A: Written | NA | NA | NA | No | 60–79%
| | E: Knowledge (objective), attitude, behavior (self-assessed)
| | R: Multiple-choice, Likert scale
Bloomfield, 2005^68^ | Overall trial does not appear to be randomized, but one aspect, the provision of prompts was randomized, pre and post intervention | A: NR | NA | C: Chart review | NA | Yes | >80%
| | E: Attitude, behavior (self-assessed)
| | R: NR
Brown, 1999^72^ | RCT, pre and post intervention | A: Written | NA | NA | E: Provider knowledge, skill, behavior, satisfaction with provider | No | >80%
| | E: Satisfaction with curriculum, skill (self-assessed), behavior (self-assessed)
| | R: NR
Brown, 2004^135^ | RCT, pre and post intervention | NA | S: Procedural skills, communication skills | NA | E: Provider knowledge, skill, behavior | Yes | <40%
| | | O: Patients' parents
| | | F: Patients' parents live observation of interaction with physician and symptoms of patients
Browner, 1994^122^ | RCT, post intervention only | NA | NA | C: Chart review | NA | No | >80%
Bunting, 2004^123^ | Non-RCT, pre and post intervention | NA | NA | C: Health plan database | NA | No | >80%
Carney, 1995^88^ | RCT, post intervention only | A: Written | NA | NA | E: Standardized patient assessment using performance checklist | No | NR
| | E: Knowledge (objective)
| | R: NR
Casebeer, 1999^131^ | RCT, pre and post intervention | NA | S: Communication skills | C: Lipid profile | E: Patient knowledge, attitude, behavior | No | 60–79%
| | | O: Educational program representative
| | | F: Live standardized patient
Chan, 1999^21^ | RCT, pre and post intervention | A: Computer | NA | NA | NA | Yes | >80%
| | E: Knowledge (self-reported)
| | R: Multiple-choice
Chassin, 1986^106^ | RCT, pre and post intervention | NA | NA | C: Chart review | NA | No | >80%
Cherkin, 1991^83^ | Observational study, pre and post intervention | A: Written | NA | NA | NA | NR | NR
| | E: Knowledge (self-reported), attitude, skill (self-assessed), behavior (self-assessed)
| | R: NR
Chodosh, 2006^62^ | RCT, post intervention only | A: Written | NA | NA | NA | No | 40–59%
| | E: Knowledge (objective), attitude
| | R: Multiple-choice, dichotomous, Likert scale
Chung, 2004^54^ | RCT, pre and post intervention | A: NR | NA | NA | NA | No | 60–79%
| | E: Knowledge (self-reported), knowledge (objective)
| | R: Multiple-choice
Clark, 1998^120^ | RCT, pre and post intervention | A: Written | NA | NA | E: Provider knowledge, skill, behavior; parental knowledge of asthma management | No | >80%
| | E: Knowledge (self-reported), behavior (self-assessed)
| | R: NR
Clark, 2000^78^ | RCT, pre and post intervention | A: Written, sent by mail | NA | NA | E: Provider knowledge, skill, behavior; health care utilization: emergency department visits; physician office visits; hospitalizations; communication regarding asthma management | NR | 40–59%
| | E: Behavior (self-assessed), medication use, procedures encouraging self-management for patients
| | R: NR
Cohn, 2002^19^ | Non-RCT, pre and post intervention | A: NR | NA | NA | E: Provider knowledge, skill, behavior | No | 40–59%
| | E: Knowledge (objective), behavior (self-assessed)
| | R: NR
Costanza, 1992^35^ | Non-RCT, pre and post intervention | A: Written | NA | NA | NA | No | 60–79%
| | E: Knowledge (objective), attitude, behavior (self-assessed)
| | R: Likert scale, biographical data entered directly by physician
Cummings, 1989^112^ | RCT, pre and post intervention | A: Written | NA | NA | E: Patient knowledge, attitude, behavior; provider knowledge, skill, behavior | No | 60–79%
| | E: Attitude, behavior (self-assessed)
| | R: Multiple-choice, Likert scale
Cummings, 1989^113^ | RCT, pre and post intervention | A: Written | NA | NA | E: Patient knowledge, attitude, behavior; provider knowledge, skill, behavior | No | 40–59%
| | E: Satisfaction with curriculum, attitude, behavior (self-assessed)
| | R: Multiple-choice, Likert scale
Cummings, 1989^117^ | RCT, post intervention only | NA | NA | NA | E: Patient knowledge, attitude, behavior; provider knowledge, skill, behavior | No | 60–79%
Curran, 2000^34^ | RCT, pre and post intervention | A: Computer, by phone | NA | NA | NA | Yes | >80%
| | E: Satisfaction with curriculum, knowledge (self-reported), skill (self-assessed)
| | R: Multiple-choice, dichotomous, Likert scale, open-ended
Davis, 2004^101^ | Non-RCT, pre and post intervention | NA | NA | C: Health plan database | NA | Yes | 60–79%
Derebery, 2002^153^ | Non-RCT, pre and post intervention | A: Physicians answered questions about patient management as they were guided through cases and were given feedback about their responses | NA | C: Health plan database | NA | No | NR
| | E: Patient management
| | R: NR
Des Marchais, 1990^61^ | RCT, pre and post intervention | NA | NA | C: Interpersonal skill assessment scores | NA | NR | NR
Dietrich, 2000^110^ | RCT, pre and post intervention | A: Written | S: Observations of office availability and use of tools | NA | E: Provider knowledge, skill, behavior | No | 40–59%
| | E: Behavior (self-assessed) | O: Educational program representative
| | R: Likert scale | F: Observations of office
Dormuth, 2004^15^ | RCT, pre and post intervention | NA | NA | C: Health plan database | NA | No | NR
Doucet, 1998^40^ | Non-RCT, some evaluations conducted pre and post intervention and some conducted post intervention only | A: Written | NA | NA | NA | No | 60–79%
| | E: Satisfaction with curriculum, knowledge (objective), clinical reasoning assessed by “Key Feature Problems”
| | R: Multiple-choice, Likert scale
Elliott, 1997^55^ | RCT, pre and post intervention | A: Written, telephone | NA | NA | E: Amount of pain | No | 60–79%
| | E: Knowledge (objective), attitude
| | R: Dichotomous, Likert scale
Evans, 1986^56^ | RCT, post intervention only | A: Written | NA | C: Chart review | E: Patient knowledge, attitude, behavior; provider knowledge, skill, behavior; patient blood pressure | No | >80%
| | E: Knowledge (objective)
| | R: Multiple-choice
Fordis, 2005^42^ | RCT, pre and post intervention | A: Written, computer | NA | C: Chart review | NA | No | >80%
| | E: Knowledge (objective)
| | R: Multiple-choice
Frush, 2006^87^ | RCT, pre and post intervention | NA | S: (1) Dosing deviation from accepted dose range; (2) time requested to calculate medication doses during the management of the simulated pediatric stabilization scenario | NA | NA | No | >80%
| | | O: Pediatric emergency medicine specialist who served as the facilitator
| | | F: Artificial model
Gerbert, 2002^86^ | RCT, pre and post intervention | A: Computer | NA | NA | NA | No | <40%
| | E: Satisfaction with curriculum, knowledge (objective), attitude
| | R: NR
Gerrity, 1999^32^ | RCT, post intervention only | A: Written | S: Communication skills, diagnostic and treatment skills | NA | NA | No | 60–79%
| | E: Knowledge (objective) | O: Educational program representative
| | R: NR | F: Live standardized patient
Gerstein, 1999^53^ | Non-RCT, pre and post intervention | A: Written | NA | NA | NA | No | <40%
| | E: Knowledge (objective), attitude, behavior (self-assessed)
| | R: Multiple-choice, dichotomous, Likert scale
Gifford, 1996^46^ | RCT, post intervention only | A: Written | NA | NA | NA | No | 60–79%
| | E: Knowledge (objective), intensity of CME
| | R: Multiple-choice, Likert scale, open-ended
Gifford, 1999^142^ | RCT, post intervention only | A: Written | NA | C: Chart review | NA | Yes | >80%
| | E: Knowledge (objective), behavior (self-assessed)
| | R: NR
Goldberg, 2001^93^ | RCT, pre and post intervention | NA | NA | C: Health plan database | NA | Yes | NR
Goldstein, 2005^146^ | RCT, pre and post intervention | NA | NA | C: Chart review | NA | No | NR
Goldwater, 2001^157^ | Non-RCT, post intervention only | NA | S: Clinical outcomes | NA | NA | Yes | NR
| | | O: NR
| | | F: NR
Gonzales, 1999^111^ | Non-RCT, pre and post intervention | NA | NA | C: Chart review, health plan database | NA | NR | NR
Grady, 1997^79^ | RCT, pre and post intervention | A: Written | NA | C: Chart review | NA | No | NR
| | E: Satisfaction with curriculum, behavior (self-assessed)
| | R: Dichotomous, Likert scale
Greenberg, 1985^25^ | Non-RCT, some evaluations conducted pre and post intervention and some conducted post intervention only | A: Written | S: Communication skills, decision-making skills | C: Chart review | NA | No | <40%
| | E: Knowledge (objective) | O: Educational program representative
| | R: Multiple-choice | F: Live standardized patient
Gullion, 1988^132^ | RCT, pre and post intervention | NA | NA | C: Chart review | E: Patient knowledge, attitude, behavior; provider knowledge, skill, behavior; measured clinical outcomes: blood pressure and weight | No | >80%
Hagen, 2005^126^ | Non-RCT, pre and post intervention | NA | NA | C: Chart review, pharmacy database | NA | No | NR
Harris, 2002^39^ | RCT, pre and post intervention | A: NR | NA | NA | NA | No | 40–59%
| | E: Satisfaction with curriculum, knowledge (self-reported), attitude, skill (self-assessed), behavior (self-assessed)
| | R: Likert scale
Harris, 2005^75^ | RCT, some evaluations conducted pre and post intervention and some conducted post intervention only | A: Written | NA | C: Chart review | NA | Yes | 60–79%
| | E: Satisfaction with curriculum
| | R: Likert scale
Heale, 1988^66^ | RCT, post intervention only | A: Written | S: History, physician examination, investigations, communication with standardized patients in physician practice | NA | NA | NR | 40–59%
| | E: Satisfaction with curriculum, knowledge (objective) | O: Standardized patients
| | R: Multiple-choice, Likert scale | F: Live standardized patient
Herbert, 2004^102^ | RCT, pre and post intervention | NA | NA | C: Health plan database | NA | No | 40–59%
Hergenroeder, 2002^60^ | RCT, pre and post intervention | A: Written | S: Procedural skills | NA | NA | No | 60–79%
| | E: Satisfaction with curriculum, knowledge (objective), attitude | O: Trained standardized patient at baseline; study coordinator at followup exam
| | R: Comfort level and evaluation of intervention rated using Likert scale, knowledge questions not specified | F: Live standardized patient
Howe, 1997^145^ | Non-RCT, pre and post intervention | NA | NA | C: Chart review, Illinois Cancer Registry, and direct contact with treating physicians | NA | NR | >80%
Jennett, 1988^76^ | RCT, pre and post intervention | A: Written | NA | C: Chart review | NA | No | >80%
| | E: Satisfaction with curriculum
| | R: Likert scale
Juzych, 2005^92^ | Non-RCT, pre and post intervention | NA | NA | C: Chart review | NA | No | NR
Kemper, 2006^58^ | RCT, 2 × 2 factorial design, pre and post intervention | A: NR | NA | NA | NA | No | 60–79%
| | E: Knowledge (objective), attitude, communication
| | R: Multiple-choice, Likert scale
Kiang, 2005^33^ | Non-RCT, pre and post intervention | A: Written | NA | NA | NA | No | 60–79%
| | E: Knowledge (self-reported), attitude, clinical outcomes (self-assessed)
| | R: Dichotomous, Likert scale
Kim, 1999^137^ | RCT, pre and post intervention | NA | NA | C: Chart review | E: Provider knowledge, skill, behavior; satisfaction with provider | No | NR
Kottke, 1989^114^ | RCT, pre and post intervention | A: Oral, phone survey | NA | NA | E: Provider knowledge, skill, behavior | No | >80%
| | E: Attitude, behavior (self-assessed), clinical outcomes (self-assessed)
| | R: NR
Kronick, 2003^71^ | RCT, pre and post intervention | A: NR | NA | NA | NA | Yes | 60–79%
| | E: Satisfaction with curriculum, knowledge (self-reported), skill (self-assessed), behavior (self-assessed)
| | R: NR
Kutcher, 2002^65^ | Non-RCT, pre and post intervention | A: Written | NA | C: Chart review | NA | No | >80%
| | E: Knowledge (objective)
| | R: NR
Labelle, 2004^67^ | Non-RCT, pre and post intervention | A: Written | S: Procedural skills | NA | NA | NR | NR
| | E: Knowledge (objective), behavior (self-assessed) | O: NR
| | R: Multiple-choice, Likert scale, open-ended | F: Live standardized patient
Lane, 1991^69^ | RCT, pre and post intervention | A: Written | NA | NA | NA | No | 60–79%
| | E: Knowledge (self-reported), skill (self-assessed), behavior (self-assessed)
| | R: Dichotomous, Likert scale, self report of percentage of referrals
Lane, 2001^45^ | Non-RCT, pre and post intervention | A: Written | NA | C: Chart review | NA | No | 40–59%
| | E: Satisfaction with curriculum, knowledge (self-reported), behavior (self-assessed), clinical outcomes (self-assessed)
| | R: NR
Leopold, 2005^80^ | RCT, pre and post intervention | A: Written | S: Procedural skills | NA | NA | No | NR
| | E: Knowledge (self-reported), confidence | O: Educational program representative
| | R: Likert scale | F: Artificial model
Levinson, 1993^138^ | RCT, pre and post intervention | NA | S: Communication skills | NA | NA | NR | >80%
| | | O: Educational program representative
| | | F: Videotaped interaction with real patient
Lewis, 1993^70^ | Non-RCT, pre and post intervention | A: NR | NA | NA | E: Provider knowledge, skill, behavior | No | 60–79%
| | E: Satisfaction with curriculum, attitude
| | R: NR
Lin, 1997^73^ | Non-RCT, pre and post intervention | A: NR | NA | C: Chart review, pharmacy records | E: Patient knowledge, attitude, behavior; satisfaction with provider; measured symptoms of depression | No | 60–79%
| | E: Attitude
| | R: NR
Lin, 2001^133^ | RCT, pre and post intervention | NA | NA | C: Health plan database | NA | No | 60–79%
Lindsay-McIntyre, 1987^115^ | RCT, post intervention only | A: NR | NA | C: Chart review | E: Patient knowledge, attitude, behavior; provider knowledge, skill, behavior | No | NR
| | E: Satisfaction with curriculum
| | R: Likert scale
Lockyer, 2002^64^ | Unclear, pre and post intervention | A: NR | NA | NA | NA | No | 60–79%
| | E: Knowledge (objective), attitude, behavior (self-assessed)
| | R: Multiple-choice, dichotomous
Maclure, 1998^96^ | Non-RCT, pre and post intervention | NA | NA | C: Prescription filling records and billing information | NA | No | NR
Macrae, 2004^85^ | RCT, post intervention only | A: NR | NA | NA | NA | No | <40%
| | E: Skill (self-assessed), critical appraisal skills measured objectively
| | R: Likert scale, open-ended
Maiman, 1988^47^ | RCT, post intervention only | A: Written | NA | NA | E: Patient knowledge, attitude, behavior | Yes | >80%
| | E: Satisfaction with curriculum, knowledge (self-reported), behavior (self-assessed)
| | R: Dichotomous, Likert scale
Mann, 1997^52^ | RCT, pre and post intervention | A: NR | NA | NA | NA | No | NR
| | E: Knowledge (self-reported), knowledge (objective), attitude, behavior (self-assessed)
| | R: Dichotomous, Likert scale, not reported for all subsets of test
Margolis, 2004^118^ | RCT, pre and post intervention | A: NR | NA | C: Chart review | NA | No | >80%
| | E: NR
| | R: NR
Maxwell, 1984^57^ | Non-RCT, pre and post intervention | A: Written | NA | C: Chart review | NA | Yes | NR
| | E: Knowledge (objective)
| | R: Multiple-choice
Mazmanian, 1998^24^ | RCT, post intervention only | A: Written | NA | NA | NA | No | <40%
| | E: Satisfaction with curriculum, attitude
| | R: Likert scale
Mazmanian, 2001^161^ | RCT, post intervention only | A: Written | NA | NA | NA | Yes | 60–79%
| | E: Behavior (self-assessed), intent to change behavior (self-assessed), clinical outcomes (self-assessed)
| | R: Dichotomous, Likert scale, open-ended
McBride, 2000^144^ | RCT, pre and post intervention | A: Written | NA | C: Chart review | E: Patient knowledge, attitude, behavior | No | >80%
| | E: Knowledge (self-reported), attitude, behavior (self-assessed)
| | R: NR
McClellan, 2003^119^ | RCT, pre and post intervention | NA | NA | C: Health plan database | NA | No | NR
McMahon, 1988^155^ | Non-RCT, pre and post intervention | NA | NA | C: Hospital length of stay statistics | NA | No | NR
Mehler, 2005^99^ | RCT, pre and post intervention | NA | NA | C: Chart review | NA | No | NR
Meredith, 2000^51^ | RCT, pre and post intervention | A: Written | NA | NA | NA | No | 60–79%
| | E: Knowledge (objective)
| | R: Likert scale
Messina, 2002^156^ | Non-RCT, pre and post intervention | NA | NA | NA | E: Patient knowledge, attitude, behavior | Yes | 60–79%
Moran, 1996^121^ | Non-RCT, pre and post intervention | NA | NA | C: Chart review | NA | No | NR
Mukohara, 2005^13^ | RCT, pre and post intervention | A: Computer | NA | NA | NA | Yes | >80%
| | E: Amount or percentage devoted to finding answers or giving clinical guidance from published research evidence
| | R: Multiple-choice, open-ended
Myers, 2004^148^ | RCT, pre and post intervention | A: Written | NA | C: Chart review, patient specific internal chart audit form | NA | NR | <40%
| | E: Clinical outcomes (self-assessed)
| | R: Dichotomous, Open-ended
Norris, 2000^81^ | RCT, pre and post intervention | A: Written | NA | NA | E: Patient knowledge, attitude, behavior; provider knowledge, skill, behavior | No | >80%
| | E: Knowledge (self-reported), knowledge (objective), attitude, skill (self-assessed), behavior (self-assessed)
| | R: NR
Ockene, 1996^124^ | RCT, post intervention only | NA | NA | NA | E: Provider knowledge, skill, behavior | No | NR
Ozer, 2005^104^ | Non-RCT, pre and post intervention | NA | NA | NA | E: Provider knowledge, skill, behavior | No | >80%
Pazirandeh, 2002^128^ | Non-RCT, pre and post intervention | NA | NA | NA | E: Physician practices regarding clinical outcomes/ treatment | No | NR
Pereles, 1996^163^ | RCT, post intervention only | A: NR | NA | NA | NA | No | NR
| | E: Behavior (self-assessed)
| | R: NR
Perera, 1983^107^ | RCT, pre and post intervention | NA | NA | C: Chart review | NA | No | >80%
Pimlott, 2003^143^ | RCT, pre and post intervention | NA | NA | C: Health plan database | NA | No | <40%
Pinto, 1998^74^ | RCT, pre and post intervention | A: NR | NA | C: Physician self-report | E: Provider knowledge, skill, behavior; satisfaction with provider | No | 60–79%
| | E: Satisfaction with curriculum, skill (self-assessed), behavior (self-assessed)
| | R: Likert scale
Premi J, 1993^38^ | RCT, pre and post intervention | A: Written | NA | NA | NA | No | 60–79%
| | E: Knowledge (objective)
| | R: NR
Premi, 1994^41^ | Non-RCT, pre and post intervention | A: Written | NA | NA | NA | NR | 60–79%
| | E: Satisfaction with curriculum, knowledge (objective), behavior (self-assessed)
| | R: Dichotomous
Rabin, 1998^97^ | RCT, pre and post intervention | A: Telephone | S: Communication skills, inclusion of appropriate STD/HIV history-taking and counseling | NA | NA | No | 60–79%
| | E: Behavior (self-assessed) | O: Simulated patient instructor
| | R: NR | F: Live standardized patient
Rahme, 2005^100^ | RCT, 2 × 2 factorial design, pre and post intervention | NA | NA | C: Chart review | NA | No | NR
Ray, 1985^20^ | Non-RCT, pre and post intervention | NA | NA | C: Medicaid prescription records | NA | No | >80%
Ray, 2001^109^ | RCT, pre and post intervention | A: Oral, by phone | NA | NA | E: Patient pain, functioning, health | No | >80%
| | E: Patient pain, functioning, health
| | R: Likert scale
Rodney, 1986^77^ | Non-RCT, pre and post intervention | A: Written, phone interview | NA | NA | NA | No | 60–79%
| | E: Knowledge (objective), skill (self-assessed), behavior (self-assessed), clinical outcomes (self-assessed)
| | R: NR
Rosenthal, 2005^59^ | RCT, post intervention only | NA | NA | NA | E: Patient knowledge, attitude, behavior, satisfaction with provider | No | >80%
Rost, 2001^22^ | RCT, pre and post intervention | NA | NA | NA | E: Patient knowledge, attitude, behavior; whether the patients had received psychiatric care or not | No | >80%
Roter, 1995^84^ | RCT, post intervention only | A: Written | S: Communication skills | NA | E: Patient knowledge, attitude, behavior | No | NR
| | E: Skill (self-assessed), behavior (self-assessed) | O: Visits were audiotaped and then coded
| | R: Likert scale, open-ended | F: Live standardized patient
Schectman, 1991^139^ | Non-RCT, post intervention only | A: NR | NA | NA | NA | No | NR
| | E: Satisfaction with curriculum, behavior (self-assessed)
| | R: NR
Schectman, 1995^130^ | RCT, pre and post intervention | NA | NA | C: Health plan database | NA | No | NR
Schectman, 1996^16^ | Non-RCT, pre and post intervention | NA | NA | C: Health plan database | NA | Yes | >80%
Schectman, 2003^108^ | RCT, pre and post intervention | A: NR | NA | C: Chart review | E: Patient knowledge, attitude, behavior; satisfaction with provider; measures of clinical outcome | No | NR
| | E: Satisfaction with curriculum
| | R: NR
Schroy, 1999^82^ | Non-RCT, pre and post intervention | A: NR | NA | C: Review of appointment logs at the intervention neighborhood health centers (NHCs) as well as monitoring of off-site referrals for comparison NHCs | NA | No | 60–79%
| | E: Attitude, behavior (self-assessed), cues to action (such as chart or computerized reminders)
| | R: Dichotomous, Likert scale
Schwartzberg, 1997^98^ | Non-RCT, pre and post intervention | A: Written, telephone | NA | NA | NA | No | 40–59%
| | E: Knowledge (self-reported), attitude
| | R: Dichotomous, Likert scale, open-ended
Sharif, 2002^94^ | Non-RCT, pre and post intervention | NA | NA | C: Chart review | NA | No | >80%
Short, 2006^50^ | RCT, pre and post intervention | A: Written | NA | NA | NA | No | 40–59%
| | E: Knowledge (self-reported), knowledge (objective), attitude, behavior (self-assessed)
| | R: Multiple-choice, cases were linear with no alternative outcomes
Sibley, 1982^136^ | RCT, pre and post intervention | A: Written | NA | C: Chart review | NA | NR | >80%
| | E: Knowledge (objective)
| | R: NR
Slotnick, 1993^17^ | Non-RCT, post intervention only | A: Written | NA | NA | NA | Yes | >80%
| | E: Knowledge (objective)
| | R: NR
Socolar, 1998^134^ | RCT, pre and post intervention | A: Written | NA | C: Chart review | NA | No | 40–59%
| | E: Knowledge (objective)
| | R: Likert scale
Solomon, 2004^127^ | RCT, pre and post intervention | NA | NA | C: Chart review | NA | No | 60–79%
Soumerai, 1987^105^ | RCT, pre and post intervention | NA | NA | C: Health plan database | NA | Yes | >80%
Stein, 2001^95^ | RCT, pre and post intervention | NA | NA | NA | E: Provider knowledge, skill, behavior; patient health and pain | No | >80%
Stewart, 2005^43^ | RCT, pre and post intervention | A: Written | NA | C: Chart review | E: Provider knowledge, skill, behavior | No | NR
| | E: Knowledge (objective)
| | R: NR
Stross, 1985^116^ | RCT, pre and post intervention | NA | NA | C: Chart review | NA | No | NR
Terry, 1981^49^ | Non-RCT, pre and post intervention | A: Written | S: Communication skills, medical decision-making | NA | NA | NR | <40%
| | E: Knowledge (objective), attitude, behavior (self-assessed) | O: Educational program representative
| | R: Multiple-choice | F: Live standardized patient, audiotaped standardized patient interaction
Thom, 2000^129^ | Non-RCT, pre and post intervention | NA | NA | | E: Satisfaction with provider | NR | NR
Tziraki, 2000^141^ | RCT, post intervention only | A: Written | NA | NA | NA | No | 60–79%
| | E: Attitude, behavior (self-assessed)
| | R: NR
Wells, 2000^151^ | RCT, pre and post intervention | NA | NA | NA | E: Patient knowledge, attitude, behavior; patient health outcomes (depression, QOL); utilization; quality of care; employment | No | >80%
White, 1985^48^ | RCT, pre and post intervention | A: Written | NA | C: Chart review | NA | No | NR
| | E: Satisfaction with curriculum, knowledge (objective), attitude
| | R: Multiple-choice, dichotomous
White, 2004^63^ | RCT, pre and post intervention | A: Written | NA | NA | NA | Yes | >80%
| | E: Knowledge (objective)
| | R: Multiple-choice
Wilson, 1988^154^ | RCT, post intervention only | NA | NA | C: Chart review | E: Patient knowledge, attitude, behavior | No | >80%
Winickoff, 1984^23^ | RCT, pre and post intervention | NA | NA | C: Chart review, health plan database | NA | No | >80%
Worrall, 1999^152^ | RCT, pre and post intervention | NA | NA | NA | E: NR | NR | NR
Zuckerman, 2004^18^ | Non-RCT, pre and post intervention | NA | NA | C: Health plan database | NA | No | NR

CME = continuing medical education; HEDIS = Health Plan Employer Data and Information Set; NA = not applicable; NR = not reported; QOL = quality of life; RCT = randomized controlled trial; STD/HIV = sexually transmitted diseases/human immunodeficiency virus

Table 2 Evidence Table. Characteristics of study population and study setting in studies assessing the effectiveness of continuing medical education

Author, year | N (%) of fully trained physicians | Other health care professionals attending CME | Gender, n (%)Males (M) Females (F) | Mean age (age range) | Specialty of learners | Years from training, mean (range) | Comparable groups | Type of practice | Motivating factors | Physical setting of CME activity | External sponsors of CME activity
Adams, 1998^125^ | Overall: 21 | Physicians-in-training (residents or fellows), nurse practitioners | M overall: 12 | Overall: 37.8 | Internal medicine | Learners' graduation from medical school overall: 9.3 | Equivalent | University/ medical school faculty | NR | NR | Government
| | | F overall: 17
Allison, 2005^147^ | NR | None | F study group range: (35.4–41.1) | Study group range: 44.5–44.5 | Family medicine, general practice (NOS), internal medicine, pediatrics | NR | Equivalent | Private practice, health plan | NR | NR | Government
Andersen, 1990^36^ | Overall: 41 (100) | None | NR | NR | Family medicine, general practice (NOS), internal medicine | NR | NR | Private practice, health plan, county public health system | NR | Recreational/ resort, short seminar during dinner | Government
Anderson, 1996^103^ | Study group range: 15–17 (100%) | None | M study group range: 15–17 (100%) | Study group range: 50–52 | General practice (NOS) | Learners' graduation from medical school, study group range: 24–26 | Equivalent | NR | External audits, participation was voluntary, but those invited were high prescribers of regulated drugs | School/ institution | NR
Beaulieu, 2002^140^ | Overall: 108 (100) | None | M study group range: 19–38 (61–68) | Study group range: 41.6 | Family medicine | Years of experience, study group range: (<11–>20) | Minor differences | Private practice, community health center | NR | Practice setting | Pharmaceutical industry, government
| | | F study group range: 12–18 (32–39)
Beaulieu, 2004^44^ | Overall: 52 | Pharmacists | NR | NR | General practice (NOS) | NR | NR | NR | Educational credit | NR | Pharmaceutical industry, professsional society, insurance industry/ health plan
Bjornson, 1990^14^ | Overall: 576 (100%) | None | NR | NR | Family medicine, general practice (NOS), internal medicine | NR | Equivalent | NR | NR | Not linked to a physical setting | NR
Block, 1988^37^ | Overall: 64 (100) | None | NR | NR | Family medicine, internal medicine | NR | NR | Private practice | NR | School/ institution, practice setting | NHLBI Demonstration Project, government
Bloomfield, 2005^68^ | Overall: 92 (100) | None | NR | NR | Primary care physician (NOS) | NR | NR | Hospital staff, military/ government | NR | Practice setting | Government
Brown, 1999^72^ | Study group range: 19–25 (66–78) | Physician assistants, nurse practitioners, optometrists | M study group range: 19–20 (62–65) | Overall: (30 – 60) | Obstetrics and gynecology, pediatrics, primary care physician (NOS), surgery, medical specialists | NR | Equivalent | Health plan | NR | Practice setting | Pharmaceutical industry, professional society, insurance industry/ health plan
| | | F study group range: 10–12 (35–38)
Brown, 2004^135^ | Overall: 23 (100) | None | NR | NR | Pediatrics | NR | NR | Private practice | NR | NR | NR
Browner, 1994^122^ | Overall: (100) | None | M overall: (92) | NR | Family medicine, general practice (NOS), internal medicine | NR | NR | Private practice | NR | Practice setting | Government
| | | F overall: (8)
Bunting, 2004^123^ | Overall: 200 (100) | None | M study group range: 65–66 (69–72) | NR | Family medicine, general practice (NOS), internal medicine, obstetrics and gynecology, pediatrics, surgery, rheumatology, urology, nephrology, medical biochemistry | Learners' graduation from medical school, study group range: (less than 7 years before intervention->37 years before intervention) | Equivalent | NR | NR | Practice setting | NR
| | | F study group range: 26–29 (28–31)
Carney, 1995^88^ | 98 (100%) | None | M overall: (92–97) | Study group range: 43.7–44.5 | Family medicine, internal medicine | NR | Minor differences | Private practice | NR | Not linked to a physical setting | Government
| | | F overall: (3–8)
Casebeer, 1999^131^ | Overall: 28 (100) | None | NR | NR | Family medicine, general practice (NOS), internal medicine | NR | Equivalent | Private practice | NR | Practice setting | Pharmaceutical industry, Alliance for Continuing Medical Education
Chan, 1999^21^ | Overall: 23 (100) Study group range: 11–12 | None | M overall: (72) | Overall: 42.2 | Family medicine | Mean years in practice, overall: 13.5 study group range: 11.6–15.3 | Minor differences | NR | NR | Not linked to a physical setting | NR
| | | M study group range: (66.7–76.9) | Study group range: 40.4–43.8
Chassin, 1986^106^ | Overall: 1483 physicians (120 hospitals) (100) | None | NR | NR | Obstetrics and gynecology, all physicians with delivery privileges | NR | Large differences | University/ medical school faculty, hospital staff | Quality improvement | Practice setting | Government
Cherkin, 1991^83^ | NR | Physician assistants | M overall: 22 | NR | Family medicine, internal medicine | Median years of practice, study group range: 8–12 | NA | Private practice, health plan | Personal improvement, CME credit | Practice setting | NR
| | | F overall: 7
Chodosh, 2006^62^ | Study group range: 63–85 (88.5–90) | Physician assistants, nurse practitioners | M study group range: 40–55 (57.1–57.3) | NR | Family medicine, internal medicine | NR | Equivalent | Health plan | NR | Practice setting, not linked to a physical setting | Government
| | | F study group range: 30–41 (42.7–42.9)
Chung, 2004^54^ | Study group range: 15–21 (48–66) | Physicians-in-training (residents or fellows) | F overall: 29 | NR | Emergency medicine | NR | NR | Hospital staff | NR | Not linked to a physical setting | Government
Clark, 1998^120^ | NR | NR | M overall: 60 | Study group range: (30–39: 22%, 40–49: 37%, 50–59: 27%, over 60: 14%) | Pediatrics | NR | NR | NR | NR | NR | Government
| | | F overall: 40
Clark, 2000^78^ | Overall: (100) | NR | M overall: (60) | Overall: (30–39: 22%, 40–49: 37%, 50–59: 27% over 60: 14%) | Pediatrics | NR | Equivalent | NR | Personal improvement | NR | Lung division of the NHLBI and Arnold P. Gold Foundation
| | | F overall: (40)
Cohn, 2002^19^ | Overall: 13–21 (77–86) | NR | M study group range: (48–54) | NR | Obstetrics and gynecology | NR | Minor differences | NR | NR | Practice setting | Government
| | | F study group range: (46–52)
Costanza, 1992^35^ | Overall: 116 (100) | Support staff, radiologists, community women | M overall: (80.4–82.8) | NR | Family medicine, general practice (NOS), internal medicine, obstetrics and gynecology | Learners' graduation from medical school, study group: 34.9–36% up to 1965, 30–33.3% in 1966-76, 34-31.8% in 1977 or later | Large differences | Private practice, health plan | NR | NR | Government
| | | F overall: (19.6-17.2)
Cummings, 1989^112^ | Overall: 44 (100) | NR | M study group range:16–22 (80–92) | NR | Family medicine, internal medicine | NR | Minor differences | Private practice | San Francisco Medical Society endorsement, personal improvement, CME credit | School/ institution | NR
| | | F study group range: 2–4 (8–20)
Cummings, 1989^113^ | Overall: 81 (100) | None | M overall: 58 (100) | NR | Internal medicine | NR | Equivalent | Health plan | San Francisco Medical Society endorsement, personal improvement, CME credit | School/ institution | NR
| | | F overall: 23 (100)
Cummings, 1989^117^ | Overall: 59 (100) | None | M study group range: 16–22 (80–92) | NR | Family medicine, internal medicine | NR | Minor differences | Private practice | NR | Not linked to a physical setting | Government
| | | F study group range: 2–4 (8–20)
Curran, 2000^34^ | Overall: 52 (100) | None | M overall: 42 (81) | NR | Dermatology | Learners' completion of residency overall: (74.5% had 11+ years) | Equivalent | Private practice, health plan | NR | Not linked to a physical setting | NR
| | | F overall: 10 (19)
Davis, 2004^101^ | Overall: 54 (100) | None | NR | NR | Pediatrics | NR | NR | Health plan | Quality improvement, CME credit, monetary gain to charity of choice | Not linked to a physical setting | Pharmaceutical industry, insurance industry/ health plan
Derebery, 2002^153^ | Overall: 258 (100) | None | NR | NR | Occupational medicine physician | NR | NR | Large occupational health group | CME credit | Conference
Des Marchais, 1990^61^ | Overall: 25 (100) | None | NR | NR | Family medicine, psychiatry | NR | NA | University/ medical school faculty | NR | NR | Le Fonds d'education medicale, Unite de Recherche et de Development en Education Medicale
Dietrich, 2000^110^ | NR | Nurse practitioners | M study group range: (50–75) | Overall: 44 | Family medicine, internal medicine, pediatrics | Overall: 10 years in current practice | Minor differences | NR | NR | Practice setting, local hospital and clinic practice | Pharmaceutical industry, sunscreen industry, government
| | | F study group range: (25–50)
Dormuth, 2004^15^ | Study group range: 241–258 (100) | None | M study group range: (83–89) | Study group range: 45.6–46.2 | General practice (NOS) | NR | Equivalent | Health plan | NR | Not linked to a physical setting | Government
Doucet, 1998^40^ | Overall: 87 (100) | None | M overall: 35 | NR | Primary care physician (NOS) | NR | Large differences | NR | NR | NR | NR
| | | M study group range: (26 – 51)
| | | F overall: 52
| | | F study group range: (49 – 74)
Elliott, 1997^55^ | NR | Nurses | M overall: (90) | NR | Family medicine, general practice (NOS), internal medicine, surgery | Years in practice, overall: 15.3 | NR | NR | NR | NR | Government
| | | F overall: (10)
Evans CE, 1986^56^ | Overall: 76 (100) | None | NR | NR | Internal medicine, primary care physician (NOS) | NR | Equivalent | Private practice | NR | Not linked to a physical setting | Government
Fordis, 2005^42^ | Study group range: 44–49 (100) | None | M study group range: 22–29 (50–59) | NR | Family medicine, internal medicine, obstetrics and gynecology | Learners' graduation from medical school, median by study group: 17 years (1985), 13 years (1989) | Equivalent | Hospital staff | Monetary/ financial gain | NR | Pharmaceutical industry
| | | F study group range: 20–22 (41–50)
Frush, 2006^87^ | Overall: (70.5–74.4) | Nurses, paramedics | NR | NR | Emergency medicine, pediatrics | Learners' completion of residency, study group range: (5.7–5.8) | Equivalent | University/ medical school faculty, hospital staff | NR | Unclear for videotaped portion, not linked to a physical setting | Government
Gerbert, 2002^86^ | Overall: 71 (100) | None | M overall: (56%) | Overall: 40 | General practice (NOS), internal medicine, general internists | NR | Minor differences | University/ medical school faculty, private practice, hospital staff, military/ government | NR | Not linked to a physical setting | NR
| | | F overall: (44%)
Gerrity, 1999^32^ | Overall: 49 (100) | | M study group range: 14–15 (58–61) | Study group range: 45.4–47.7 | Family medicine, internal medicine, primary care physician (NOS) | Learners' graduation from medical school, study group range: 16.8–20 | Equivalent | Private practice, solo, specialty group, hospital-affiliated clinic | NR | NR | MacArthur Foundation
| | | F study group range: 9–11 (39–42)
Gerstein, 1999^53^ | Overall: 290 (100) | None | M study group range: 82 – 107 (60.5 – 72.6) | NR | Family medicine | Learners' graduation from medical school, overall: 16–21 | Large differences | Private practice | NR | NR | Pharmaceutical industry, government
| Study group range: 113–177 (100) | | F study group range: 31 – 70 (27.4 – 39.5)
Gifford, 1996^46^ | Overall: 492 (100) | None | M study group range: (85–89) | Study group range: 45.5–46.2 | Neurology | Number of years in practice, overall: 13 | Equivalent | University/ medical school faculty, private practice | NR | Not linked to a physical setting | Center for Study of Health-care Provider Behavior
| | | F study group range: (11–15)
Gifford, 1999^142^ | Overall: 417 (100) | None | M study group range: (78–85) | Study group range: 46–47 | Neurology | Years in practice, study group range: 11 – 14 | Equivalent | University/ medical school faculty, private practice, hospital staff, health plan | NR | NR | Professional society, government
| | | F study group range: (15–22)
Goldberg, 2001^93^ | NR | Administrative personnel | NR | NR | Neurology, surgery, orthopedic surgeons | NR | Equivalent | Private practice | Quality improvement | Not linked to a physical setting | NR
Goldstein, 2005^146^ | Overall: 36 | Nurse practitioners | NR | NR | NR | NR | Equivalent | Military/ government | NR | Practice setting | Government
Goldwater, 2001^157^ | NR | Nurses, pharmacists, hospital personnel | NR | NR | NR | NR | NR | Hospital staff | NR | Practice setting | NR
Gonzales, 1999^111^ | NR | Physician assistants, nurse practitioners, nurses | NR | NR | Family medicine, internal medicine | NR | Equivalent | Health plan | NR | Home/ personal, practice setting | RWJ, insurance industry/ health plan
Grady, 1997^79^ | NR | NR | M overall: (88.4) | Overall: 46.76 | Family medicine, general practice (NOS), internal medicine | Learners' completion of residency overall: 15.22 (1–45) | Large differences | Private practice | NR | Practice setting | Government
| | | F overall: (11.6)
Greenberg, 1985^25^ | Overall: 23 (100) | None | NR | NR | Pediatrics | NR | NR | Private practice | NR | Practice setting | NR
Gullion, 1988^132^ | Overall: 111 (100) | None | M overall: (96) | Overall: 46.3 | Family medicine, general practice (NOS), internal medicine | NR | NR | NR | NR | Not linked to a physical setting | Government
| | | F overall: (4)
Hagen, 2005^126^ | Overall: 33 | Nurses, pharmacists, family members | NR | NR | NR | NR | NR | Long term care facility | NR | Practice setting | Foundation
Harris, 2002^39^ | Overall: 65 (100) | None | M overall: (70) | Study group range: 42.6–43.7 | Emergency medicine, family medicine, internal medicine, pediatrics, orthopedics | Learners' graduation from medical school, study group range: 16.7–17.7 | Equivalent | NR | NR | Not linked to a physical setting | Government
| | | M study group range: (64.3–73)
| | | F overall: (30)
| | | F study group range: (27–35.4)
Harris, 2005^75^ | Study group range: 43–47 | None | M study group range: 27–30 (93.1–93.8) | NR | Family medicine | NR | Equivalent | NR | NR | Initial session at a dinner, but subsequent ones by phone conference | Pharmaceutical industry
Heale, 1988^66^ | Overall: 53 (100) | None | NR | NR | Family medicine | Years in practice, overall: 10.2 | NR | NR | NR | NR | NR
Herbert, 2004^102^ | Overall: 200 (100) | None | NR | NR | Family medicine | NR | Equivalent | Private practice | Already belonged to PBSG learning program, personal improvement | School/ institution | Professional society, insurance industry/ health plan
Hergenroeder, 2002^60^ | Overall: 75 (100) | None | M study group range: 20–23 (55–61) | NR | Pediatrics | Years after residency, study group range: 15.5–18 (1–48) | Equivalent | Health plan | NR | Practice setting | Medical device industry
| | | F study group range: 13–22 (39–45)
Howe, 1997^145^ | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Government
Jennett, 1988^76^ | Overall: 31 (100) | None | M overall: 25 | Overall: (35–60) | Family medicine | Learners' graduation from medical school, number in each decade: 5 -1950s, 6-1960s, 19- 1970s; all at least 2 years in active practice | Equivalent | Private practice | NR | Home/ personal, school/ institution | NR
| | | F overall: 6
Juzych, 2005^92^ | Study group range: 9–19 | Nurses, Pharmacists | NR | NR | Internal medicine, pediatrics | NR | NR | Health plan | NR | Practice setting | Pharmaceutical industry, General Motors Foundation, insurance industry/ health plan
Kemper, 2006^58^ | Overall: 374 (29.5) | Physician assistants, nurses, medical students, pharmacists, nutritionists, dietitians | M overall: (25.3) | Overall: 40.3 (27.4–53.2) | NR | NR | Equivalent | University/ medical school faculty | NR | Not linked to a physical setting | Government
Kiang, 2005^33^ | Study group range: 400–600 | Physician assistants, nurse practitioners | M study group range: (51–61) | Mean years in practice, study group range: 12.6–13.8 | Emergency medicine, family medicine, general practice (NOS), internal medicine, pediatrics | NR | Equivalent | All types of practices | Public demand/ patient expectations | NR | Professional society, government
Kim, 1999^137^ | Overall: 48 (100) | None | M study group range: (85–86%) | Study group range: 42–45 | Family medicine, internal medicine, subspecialists with large proportion of primary care | Overall: 10 years employed in health plan (mean) study group: range 4–32 years employed in health plan | Equivalent | Health plan | NR | Practice setting | Insurance industry/ health plan
Kottke, 1989^114^ | Overall: NR | None | M overall: 66 (86) | Study group range: 37.9 – 44.3 | Family medicine | NR | Equivalent | NR | NR | NR | NR
| | | F overall: 10 (14)
Kronick, 2003^71^ | Overall: 81 (100) | None | M study group range: 30–31 (75–75.6) | NR | Family medicine | Year starting first practice, study group range: 1980 - 1984 | Minor differences | Private practice | NR | Practice setting | NR
| | | F study group range: 10 (24.4–25)
Kutcher, 2002^65^ | Overall: 68 | None | M study group range: 16–19 (46–63) | Overall: (31 and up) | Family medicine | Duration of practice, study group range: (20–25) | Minor differences | Private practice | Personal improvement, voluntary | NR | Government
| | | F study group range: 11–19 (37–54)
Labelle, 2004^67^ | Overall: 40 (100) | None | NR | NR | General practice (NOS) | NR | NR | NR | NR | NR | Pharmaceutical industry, professional society
Lane, 1991^69^ | NR | Medical students, other health professional student | NR | NR | Family medicine, general practice (NOS), obstetrics and gynecology | NR | Equivalent | Private practice, 14% not in private practice, but practice description not provided | NR | NR | Government
Lane, 2001^45^ | Overall: 282 (100) | None | M study group range: 106–135 (82.8–88.3) | Study group range by age category: </=44: 44–49 (33.3–36.7), >=65: 9–18 (7.5–12.2) | Family medicine, internal medicine, obstetrics and gynecology | Learners' graduation from medical school) study group range: (21–30) | Minor differences | Private practice, hospital staff, public health center | Quality improvement | Home/ personal, practice setting | NR
| | | F study group range: 19–22 (11.7–17.2)
Leopold, 2005^80^ | Overall: 48 | Physician assistants, nurse practitioners, osteopathic physicians | NR | NR | NR | NR | NR | NR | NR | Not linked to a physical setting | NR
Levinson, 1993^138^ | Overall: (100) | NR | M overall: 44 | NR | Family medicine, internal medicine | Learners' graduation from medical school, overall: 15 (3–47) | NR | NR | Reduced malpractice premium | NR | Miles Program for Physician-Patient Communication, professional society, insurance industry/ health plan
| | | F overall: 9
Lewis, 1993^70^ | Overall: 253 (100) | None | F overall: (37.1) | Study group range: 37–47 | Family medicine, internal medicine, obstetrics and gynecology | NR | Large differences | Health plan | HMO mandate | NR | NR
Lin, 1997^73^ | NR | NR | NR | NR | Family medicine, internal medicine | NR | NR | Health plan | NR | Some activities clearly took place in the clinic, but others were not specified | Government
Lin, 2001^133^ | Overall: 109 (100) | None | M study group range: 40–44 (75.5–78.6) | NR | Primary care physician (NOS) | NR | Minor differences | Health plan | NR | Practice setting | Pharmaceutical industry
| | | F study group range: 12–13 (21.4–24.5)
Lindsay-McIntyre, 1987^115^ | Overall: 82 (100) | None | NR | NR | Family medicine | Learners' graduation from medical school, overall: (15–20) | NR | Private practice | NR | NR | NR
Lockyer, 2002^64^ | Overall: 637 (100) | None | NR | NR | Family medicine | NR | NR | Private practice | NR | NR | NR
Maclure, 1998^96^ | Overall: (100) | NR | M overall: (76) | NR | General practice (NOS) | NR | NR | NR | NR | NR | Government
| | | F overall: (24)
Macrae, 2004^85^ | Overall: 86 (100) | No | NR | NR | Surgery | Learners' graduation from medical school overall: 23 | Equivalent | University/ medical school faculty, private practice, hospital staff | NR | Not linked to a physical setting | Medical device industry
Maiman, 1988^47^ | Overall: 83 (100) | None | M overall: (80) | Overall: 46 | Pediatrics | Learners' completion of residency, overall: 14 years | NR | Private practice | NR | NR | NR
| | | F overall: (20)
Mann, 1997^52^ | Overall: 59 (100) | None | M overall: 49 | Study group range: 42.4–45 | Family medicine | NR | Minor differences | NR | NR | NR | NR
| | | F overall: 10
Margolis, 2004^118^ | The mean (range) number of clinicians in the 22 intervention practices was 5.6 (1–12) and in the 22 control practices 4.4 (1–12) | Nurses, clerical | NR | NR | Family medicine, pediatrics | NR | Minor differences | Private practice, hospital staff | NR | Practice setting | Government
Maxwell, 1984^57^ | NR | NR | NR | NR | NR | NR | NR | Hospital staff | NR | Practice setting | NR
Mazmanian, 1998^24^ | Overall: (100) | NR | NR | NR | Primary care | NR | NR | NR | NR | School/ institution, community hospital | Pharmaceutical industry, professional society, government
Mazmanian, 2001^161^ | Overall: 88 (100) | None | M overall: 76 (100) | Overall: 42 | NR | NR | NR | NR | Personal improvement | School/ institution | NR
| | | F overall: 16 (100)
McBride, 2000^144^ | Overall: 160 (100) | Physician assistants, nurse practitioners, nurses, pharmacists, medical technicians, nursing assistants | M study group range: (81) | NR | Family medicine, general practice (NOS), internal medicine, geriatrician | Years in practice, study group range: 12–14 | Equivalent | Private practice, health plan | NR | Practice setting | Government
| | | F study group range: (19)
McClellan, 2003^119^ | Overall: 477 (100) | None | NR | NR | Family medicine, general practice (NOS), internal medicine, obstetrics and gynecology, endocrinology | NR | NR | NR | NR | Practice setting, mailings | Government
McMahon, 1988^155^ | Overall: 34 (100) | None | NR | NR | Internal medicine | NR | NR | University/ medical school faculty, private practice | Hospital credentialing | Recreational/ resort, school/ institution | NR
Mehler, 2005^99^ | NR | NR | NR | NR | Family medicine, internal medicine, academic | NR | NR | Hospital staff | Quality improvement | Practice setting, electronic detailing | Grant making Foundation, insurance industry/ health plan
Meredith, 2000^51^ | Overall: (86.2) study group range: (81.0–93.9) | Physician assistants, nurse practitioners | F overall: (35.6) | Overall: 43.7 study group range: 43.1–44.0 | Family medicine, general practice (NOS), internal medicine | Mean years from training, overall: 11.7 study group range: 11.1–12.0 | Equivalent | Health plan | NR | Practice setting | NR
| | | F study group range: (30.6–41.4)
Messina, 2002^156^ | Overall: (100) | None | NR | NR | Primary care physician (NOS) | NR | NR | NR | NR | Practice setting | NCI
Moran, 1996^121^ | Overall: 15 (100) study group range: 5–10 (100) | None | M study group range: 5–6 (60–100) | NR | Family medicine, general practice (NOS), the specialty of the experimental group was not specified although none were residency trained suggesting that they were GPs | Learners' graduation from medical school, all five of the experimental groups graduated between 1950-1960. Six of the ten control physicians graduated in the 1980s | Large differences | Private practice | Participation was voluntary, but intervention physicians were invited because they were identified as having serious deficiencies in their practices | NR | Professional society
| | | F study group range: 0–4 (0–40)
Mukohara, 2005^13^ | Overall: 107 | None | F study group range: (38.9–47.2) | Study group range: 40.8–41.7 | General practice (NOS), internal medicine | NR | Equivalent | University/ medical school faculty | NR | School/ institution practice setting | NR
Myers, 2004^148^ | Overall: 838 | NR | NR | NR | Primary care physician (NOS) | NR | Not applicable | Private practice | NR | Practice setting | Insurance industry/ health plan
Norris, 2000^81^ | Overall: 32 (100) | None | NR | NR | Primary care physician (NOS) | NR | Equivalent | Health plan | NR | Practice setting | Government
Ockene, 1996^124^ | Overall: 45 (100) | None | M overall: 30 (66.7) | Overall: 38.1 study group range: 36.8–39.3 | Internal medicine | Learners' graduation from medical school, overall: 11.1 study group range: 9.9–12.9 | Minor differences | Health plan | NR | Practice setting, unclear where group sessions took place | Government
| | | M study group range: 9–11 (59–79)
| | | F overall: 15 (33.3)
| | | F study group range: 3–7 (21–41)
Ozer, 2005^104^ | Overall: 86 | Nurse practitioners | F study group range: (62.2–64.1) | Study group range: 41.4–44.1 | Pediatrics | Learners' graduation from medical school, study group range: 14–15 | Minor differences | Hospital staff, health plan | NR | NR | NR
Pazirandeh, 2002^128^ | Overall: 134 (100) | None | NR | NR | Family medicine, internal medicine, obstetrics and gynecology | NR | NR | NR | NR | NR | Pharmaceutical industry
Pereles, 1996^163^ | NR | None | NR | NR | NR | NR | NR | NR | NR | School/ institution | NR
Perera, 1983^107^ | Overall: 26 (100) | None | NR | Overall: (37.2–40.5) | Primary care physician (NOS) | NR | Minor differences | Health plan | NR | NR | NR
Pimlott, 2003^143^ | Overall: 274 (100) | None | M study group range: 145–170 (82.5–86.3) | Study group range: 50.6–50.7 (32–81) | Primary care physician (NOS) | Learners' graduation from medical school, study group range: 24.5 | Minor differences | NR | NR | Not linked to a physical setting | NR
| | | F study group range: 23–36 (13.7–17.5)
Pinto, 1998^74^ | Overall: (100) | None | M overall: 26 | Overall: 44.1 | Family medicine, general practice (NOS), internal medicine | Learners' completion of residency, overall: 9.2 | Equivalent | Private practice | Monetary/ financial gain | Practice setting | Government
| | | F overall: 13 | study group range: 43.7–44.6
Premi J, 1993^38^ | Overall: 40 (100) | None | NR | NR | Military physicians (specialty not reported) | Years in clinical practice, overall: 4.8 | NR | Military/ government | NR | Not linked to a physical setting | Government
Premi, 1994^41^ | Overall: 152 (100) | None | NR | NR | Family medicine, general practice (NOS) | NR | NR | NR | NR | Local communities | Professional society
Rabin, 1998^97^ | NR | NR | NR | NR | General practice (NOS), internal medicine, obstetrics and gynecology, primary care physician (NOS) | NR | NR | NR | NR | Practice setting | Government
Rahme, 2005^100^ | Study group range: 29–84 | None | NR | NR | General practice (NOS) | NR | NR | Health plan | Educational credit | Practice setting | Pharmaceutical industry
Ray, 1985^20^ | Overall: 372 (100) | None | NR | NR | NR | NR | NR | Private practice | Tennessee Medicaid program prescription behavior | Practice setting | Professional society
Ray, 2001^109^ | Overall: 209 (100) | None | NR | NR | Primary care physician (NOS) | NR | Equivalent | NR | NR | Practice setting | NR
Rodney, 1986^77^ | Overall: 196 (100) | None | NR | NR | Family medicine, internal medicine, other sigmoidoscopists | NR | NR | Private practice | NR | Recreational/ resort, practice setting, state/ medical meeting | NR
Rosenthal, 2005^59^ | Study group range: 1–12 | Nurses, clerical | NR | NR | Family medicine, pediatrics | NR | Minor differences | Private practice, hospital staff | CME credit | Practice setting | Professional society, government
Rost, 2001^22^ | Overall: (66.6) | Nurses | NR | NR | Primary care physician (NOS) | NR | Equivalent | Private practice | NR | Practice setting, via telephone | NR
Roter, 1995^84^ | Overall: 63 | Physicians-in-training (residents or fellows) | M overall: 63 | Overall: 40.3 (27–67) study group range: 38.5–42.7 | Family medicine, internal medicine | Years in practice, overall: 10.8 (1–39 years) study group range: 9.3 – 12.5 | Equivalent | Private practice, hospital staff, health plan | NR | NR | NR
| | | M study group range: 18–23 (82–96)
| | | F overall: 6
| | | F study group range: 1–4 (4–18)
Schectman, 1991^139^ | NR | Physician assistants, nurse practitioners | NR | NR | Internal medicine | Experience, study group range: (7 –13) | NR | Health plan | HMO mandate | Not linked to a physical setting | NR
Schectman, 1995^130^ | NR | NR | NR | NR | Family medicine, internal medicine | NR | Equivalent | University/ medical school faculty, private practice, HMO practitioners | NR | NR | NR
Schectman, 1996^16^ | Study group range: 13–190 | Physician assistants, nurse practitioners | NR | NR | Family medicine, internal medicine | Learners' completion of residency, study group range: (7 –10 years) | Large differences | Health plan | Quality improvement | Practice setting | NR
Schectman, 2003^108^ | Overall: 120 | Physician assistants, nurse practitioners | M study group range: 7–14 (36–58) | NR | Family medicine, internal medicine | Years of practice, study group range: 8.7– 11.0 | Minor differences | Health plan, group practices affiliated with not-for-profit group model HMOs | NR | NR | Government
| | | F study group range: 9–13 (42–64)
Schroy, 1999^82^ | NR | Physician assistants, nurse practitioners | M study group range: 48 | Study group range: 36 – 38 | Primary care physician (NOS) | NR | Equivalent | Primary care physicians at neighborhood health centers | NR | NR | NR
| | | F study group range: 52
Schwartzberg, 1997^98^ | NR | NR | M overall: (78) | NR | Family medicine, internal medicine, geriatrics | NR | NR | NR | NR | Medical specialty annual meetings | Professional society
| | | F overall: (22)
Sharif, 2002^94^ | Study group range: 6–9 (100) | None | NR | NR | Pediatrics | NR | NR | University/ medical school faculty | NR | NR | Professional society
Short, 2006^50^ | Study group range: 23–29 | None | M study group range: (52–56) | Overall: 47 | Family medicine, internal medicine, obstetrics and gynecology, pediatrics, psychiatry | Learners' completion of residency, overall: 17 years | Equivalent | Private practice | CME credit, monetary/ financial gain | Not linked to a physical setting | Government
Sibley, 1982^136^ | Overall: 16 (100) | None | NR | NR | Family medicine | NR | Equivalent | NR | NR | Not linked to a physical setting | Government
Slotnick, 1993^17^ | Overall: 33 (100) | None | M study group range: (66–100) | Study group range: 43–47 | Family medicine, general practice (NOS), internal medicine | NR | NR | NR | NR | NR | Pharmaceutical industry
| | | F study group range: (0–34)
Socolar, 1998^134^ | NR | None | M study group range: (64–67) | Overall: (<35: 12%, 35–50: 57%, >50: 31%) | Family medicine, pediatrics, 5% specialty not specified | NR | Equivalent | NR | NR | Home/ personal, practice setting | Government
| | | F study group range: (33–36)
Solomon, 2004^127^ | Overall: 32 (100) | None | F study group range: (30–45) | NR | Rheumatology | Learners' completion of fellowship, overall: 13 | Minor differences | Private practice | NR | NR | Pharmaceutical industry
Soumerai, 1987^105^ | Overall: 435 (100) | None | NR | Overall: 51 | Family medicine, general practice (NOS), internal medicine, 18% not specified | NR | Equivalent | NR | External audits | Practice setting | NR
Stein, 2001^95^ | Overall: 63 | Nurses, nursing home staff | NR | NR | Primary care physician (NOS) | NR | NR | NR | Quality improvement | Practice setting, by phone | NR
Stewart, 2005^43^ | Overall: 58 | None | M study group range: (63–71) | NR | Family medicine | Learners' graduation from medical school, study group range: 17.9–18.6 | Minor differences | Private practice military/ government | NR | Not linked to a physical setting | Government
Stross, 1985^116^ | Overall: (100) | None | NR | NR | Primary care physician (NOS) | NR | NR | Private practice, hospital staff | NR | NR | Government
Terry, 1981^49^ | Overall: 44 (100) | None | NR | NR | Family medicine, general practice (NOS), internal medicine | NR | NR | Rural western Pennsylvania | NR | Home/ personal, group meeting location not described | Government, insurance industry/ health plan
Thom, 2000^129^ | Overall: (100) | | F study group range: 1–2 (10–20) | Overall: 47 | Family medicine | Years in practice, overall: (15–17) | Equivalent | NR | NR | NR | Picker/ Common-wealth Fund and Bayer Institute for Health Care Communication
Tziraki, 2000^141^ | Overall: 616 (100) | None | M overall: 510 (83) | NR | Family medicine, general practice, (NOS), internal medicine | NR | Minor differences | Private practice | NR | NR | Government
| | | F overall: 106 (17)
Wells, 2000^151^ | Overall: 114 (87) | Nurse practitioners | NR | NR | Family medicine, internal medicine | NR | NR | Private practice, health plan, public health clinics | NR | Practice setting | Government
White, 1985^48^ | Overall: 103 (100) study group range: 40–63 (100) | None | NR | NR | Family medicine, internal medicine | NR | NR | Hospital staff | NR | NR | NR
White, 2004^63^ | Overall: 52 | NR | NR | NR | Family medicine | NR | NR | Private practice, hospital staff, health plan, military/ government | NR | Practice setting | NR
Wilson, 1988^154^ | Overall: 83 | None | M overall: 74 | Study group range: 40.5–41.77 | Family medicine | % Graduated from medical school in past 15 years: 45–83 | Minor differences | Private practice | NR | NR | NR
| | | M study group range: (81.5–93.1)
| | | F overall: 9
Winickoff, 1984^23^ | Overall: 16 (100) | None | NR | NR | Internal medicine | NR | NR | Health plan | Quality improvement | Practice setting | Insurance industry/ health plan
Worrall, 1999^152^ | Overall: 42 | None | NR | NR | Family medicine | NR | NR | Fee-for-service physicians | NR | NR | Pharmaceutical industry, government
Zuckerman, 2004^18^ | Overall: (100) | None | NR | NR | Family medicine, general practice (NOS), internal medicine, primary care physician (NOS) | NR | NR | NR | NR | Not linked to a physical setting | Professional society, government

CME = continuing medical education; GP = general practitioner; HMO = health maintenance organization; NCI = National Cancer Institute; NHLBI = National Heart, Lung, and Blood Institute; NOS = not otherwise specified; NR = not reported; PBSG = practice-based small-group; RWJ = Robert Wood Johnson Foundation

Table 3 Evidence Table. Description of CME activity

Author, year | Group | Group description, N | Media used | Educational methods | Intervention design | Hours in CME activity (T), days/week exposed (W), intervention duration (D) | Amount of exposure | Evaluation duration | Accredited | Part of QI or PI project | Educational goals
Adams, 1998^125^ | Intervention | Received formal intensive training sessions on counseling techniques and the approach to alcohol counseling as well as practice supports to promote screening and counseling, | Live | Lecture, mentor/ preceptor, office cuing system | Individuals | T: 2.5 | Multiple time or repetitive | 32 months | NR | No | Will primary care providers who have received training in a brief alcohol counseling intervention of 5 to 10 minutes use these skills with high-risk drinkers in a clinical setting that provides a facilitative office support system?
| | n assigned: 17 | | | | W: NR
| | | | | | D: NR
| Concurrent control | Received usual alcohol counseling intervention with weekly conferences at which alcohol counseling was encouraged in one session over two years, | Live | Lecture | Individuals | T: NR | NR | 32 months | NR | No
| | n assigned: 12 | | | | W: Once only
| | | | | | D: NR
Allison, 2005^147^ | Intervention | Intervention group that received multicomponent Internet CME modules, | Computer-based off-line | Feedback, (chlamydia screening rates for the physician's entire office), readings | Practice settings/ teams | T: 0.2 per module | Multiple time or repetitive | NR | NR | Yes | The overall goal of the educational intervention was to increase chlamydia screening for at-risk women in the managed care setting.
| | n assigned: NR | | | | W: NR
| | | | | | D: 1 year
| Concurrent control | Comparison group that received flat-text, Internet-based CME modules on women's health, | Computer-based off-line | Readings | Practice setting/ teams | T: NR | Multiple time or repetitive | NR | NR | Yes
| | n assigned: NR | | | | W: NR
| | | | | | D: 1 year
Andersen, 1990^36^ | Concurrent control | Primary care physicians receiving no training on affective and anxiety disorders in primary care, | NA | NA | NA | T: NA | NA | NA | NR | No | To improve primary care physicians' diagnosis, treatment, and referral of selected DSM-III / DSM-IIIR affective and anxiety disorders in primary care.
| | n assigned: NR | | | | W: NA
| | | | | | D: NA
| Intervention | Primary care physicians receiving 3.5 hour seminar on diagnosis, treatment, and referral of affective and anxiety disorders in primary care, | Live, video | Case-based learning, lecture | Individuals | T: 3.5 | One time | 1–8 weeks | Yes | No
| | n assigned: NR | | | | W: Once only
| | | | | | D: 3.5 hours
Anderson, 1996^103^ | Concurrent control | Control, | NA | NA | NA | T: NA | NA | NA | NA | No | This study was intended to measure and compare the effects of group education and feedback concerning prescribing patterns on physicians' prescribing of drugs to treat chronic pain. To modify the prescribing patterns of physicians who prescribe excessive amounts of drugs covered by the Triplicate Prescription Program.
| | n assigned: 18, | | | | W: NA
| | n analysis: 15 | | | | D: NA
| Intervention | Education and notification, | Live, video | Case-based learning, discussion group, lecture | Individuals | T: NR | One time | 6 months | NR | Yes
| | n assigned: 18, | | | | W: Once only
| | n analysis: 17 | | | | D: 1 day
| Concurrent control | Notification only, | NA | NA | NA | T: NA | NA | NA | NA | Yes
| | n assigned: 18, | | | | W: NA
| | n analysis: 17 | | | | D: NA
Beaulieu, 2002^140^ | Intervention | ”Exposed” physicians attended workshop incorporating features of effective educational interventions, | Live | Case-based learning, problem-based learning or team-based learning, readings, role play | Individuals, practice setting/ teams | T: 1.5 | One time | 4–6 months | Yes | No | Increase compliance with the recommendations of the Canadian Task Force on Preventive Health Care and decrease the ordering of tests not the subject of specific recommendations.
| | n assigned: 59, | | | | W: Once only
| | n analysis: 31 | | | | D: NR
| Concurrent control | ”Unexposed” physicians attended no such workshops until after the SP visit, | NA | NA | NA | T: NA | NA | 4–6 months | NA | No
| | n assigned: 49 | | | | W: NA
| | n analysis: 56 | | | | D: NA
Beaulieu, 2004^44^ | Intervention | Workshop only, | Live | Case-based learning, discussion group, problem-based learning or team-based learning, readings | Individuals, practice settings/ teams | T: NR | One time | 6 months | Yes | Yes | ”The primary objectives of the CURATA program were to (1) improve the GP's ability to identify OA patients through appropriate questioning and musculoskeletal examination and (2) to enhance the GP's ability to select appropriate pharmacologic and nonpharmacologic therapy according to a defined decision tree.”
| | n assigned: NR | | | | W: Once only
| | | | | | D: NR
| Concurrent control | Control group, | NA | NA | NA | W: NA | NA | 6 months | NA | NA
| | n assigned: NR | | | | D: NA
| Intervention | Workshop and a decision tree, | Live, print | Case-based learning, discussion group, problem-based learning or team-based learning, programmed learning, readings | Individuals, practice setting/ teams | T: NR | One time | 6 months | Yes | Yes
| | n assigned: NR | | | | W: Once only
| | | | | | D: NR
| Intervention | Decision tree only, | Print | Discussion group, programmed learning, readings | Individuals | T: NR | One time | 6 months | Yes | Yes
| | n assigned: NR | | | | W: Once only
| | | | | | D: NR
Bjornson, 1990^14^ | Intervention | Received information packet including letter, copy of study, and questionnaire, | Print | Readings | Individuals | T: NR | One time | 4 months | NR | No | 1 To investigate the impact of the Minnesota Department of Human Services drug-use review program which seeks to promote rational drug therapy among Medicaid users.; 2 To assess physician awareness and acceptance of the clinical trial results and to identify underlying factors associated with the intent to adopt a change in drug therapy.
| | n assigned: 288, | | | | W: NA
| | n analysis: 141 | | | | D: NA
| Concurrent control | Control, | NA | NA | NA | T: NA | NA | 4 months | NR | No
| | n assigned: 288, | | | | W: NA
| | n analysis: 288 | | | | D: NA
Block, 1988^37^ | Concurrent control | Control hospital in comparison city (no provider or public education), | NA | NA | NA | T: NA | NA | NA | NA | NA | To test whether a public health approach to CHD risk factors can be effective in reducing both risk and disease events in a demonstration population. “To improve cholesterol awareness and diet change in the general population” and “to lower thresholds at which physicians recommend dietary and drug therapy to better approximate the guidelines established by the consensus conference.”
| | n assigned: 38, | | | | W: NA
| | n analysis: 23 | | | | D: NA
| Intervention | Demonstration hospital (targeted with provider and public education), | Live, print | Lecture, point of care | Individuals | T: NR | Multiple time or repetitive | NR | NR | Yes
| | n assigned: 50, | | | | W: NR
| | n analysis: 41 | | | | D: NR
Bloomfield, 2005^68^ | Intervention | Multicomponent intervention plus patient letters, | Live, print, patient letter prompting patient to discuss with provider about letter contents (treatment) | Discussion group, lecture, patient informs provider | Individuals, practice setting/ teams | T: 1 | One time | NR | Yes | Yes | Our primary objective was to evaluate the effectiveness of this multicomponent intervention for improving evidence based lipid management for IHD patients with low high density lipoprotein cholesterol. A second objective was to evaluate the relative effectiveness of the three different prompts on provider prescribing behavior.
| | n assigned: NR | | | | W: Once only
| | | | | | D: 1 year
| Concurrent control | Control, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: NR | | | | W: NA
| Intervention | Multicomponent intervention plus progress notes, | Live, print, progress notes reminding PCP about appropriate approach | Discussion group, lecture, point of care | Individuals, practice settings/ teams | T: 1 | One time | NR | Yes | Yes
| | n assigned: NR | | | | W: Once only
| | | | | | D: 1 year
| Intervention | Multicomponent intervention plus computer chart reminders, | Live, print, chart reminders appearing on cover page of patient's computerized medical record | Discussion group, lecture, point of care | Individuals, practice settings/ teams | T: 1 | One time | NR | Yes | Yes
| | n assigned: NR | | | | W: Once only
| | | | | | D: 1 year
Brown, 1999^72^ | Intervention | Clinicians who attended training program in communication skills immediately, | Live | Clinical experiences, discussion group, lecture, role play, clinicians audio taped interaction with patients and listened between workshops | Individuals | T: 4 | Multiple time or repetitive | >=6 months | NR | No | The overall goal of the intervention was to achieve higher quality of care and higher levels of patient satisfaction by improving clinicians' communication skills.
| | n assigned: 37, | | | | W: NR
| | n analysis: 30 | | | | D: 10 hours
| Concurrent control | Clinicians who would receive training program on communication skills at a later time, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 32, | | | | W: NA
| | n analysis: 29 | | | | D: NA
Brown, 2004^135^ | Concurrent control | Control, | NA | NA | Individuals | T: NA | NA | 22 months | NA | NA | ”The interactive seminar was based on the theory of the self-regulation of guiding physicians to enhance their therapeutic skills in treating childhood asthma, and to develop their ability to educate and counsel families about asthma self-management.”
| | n analysis: 11 | | | | W: 1 day/week
| | | | | | D: NA
| Intervention | Interactive seminar, | Live, video, print | Case-based learning, demonstration, lecture, problem-based learning or team-based learning, readings | Individuals | T: 4–6 | Multiple time or repetitive | 22 months | NR | Unclear
| | n analysis: 12 | | | | W: 1 day/week
| | | | | | D: 2–3 weeks
Browner, 1994^122^ | Intervention | Physician practices randomized to receive a standard 3 hour CME seminar and syllabus on cholesterol management, | Live, print | Lecture, readings | Individuals | T: 3 hours | One time | 18 months | Yes | No | Compliance with the recommendations of the NCEP on high serum cholesterol levels in adults.
| | n assigned: 55, | | | | W: Once only
| | n analysis: 45 | | | | D: NR
| Intervention | Physician practices randomized to receive intensive CME on cholesterol management, | Live, print | Academic detailing, case-based learning, lecture, point of care, readings | Individuals, practice settings/ teams | T: NR | Multiple time or repetitive | 18 months | Yes | No
| | n assigned: 57, | | | | W: NR
| | n analysis: 47 | | | | D: 3 months
| Concurrent control | Physician practices who received no CME, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 62, | | | | W: NA
| | n analysis: 48 | | | | D: NA
Bunting, 2004^123^ | Concurrent control | Control group, | NA | NA | Individuals | T: NA | NA | 2 years | No | Unclear | To reduce test-ordering behaviors of physicians in the community setting
| | n assigned: 100, | | | | W: NA
| | n analysis: 98 | | | | D: 2 years
| Intervention | Multifaceted education group (meeting + feedback), | Live, print | Feedback, readings | Individuals | T: NR | Multiple time or repetitive | 2 years | No | Unclear
| | n assigned: 100, | | | | W: NA
| | n analysis: 95 | | | | D: 2 years
Carney, 1995^88^ | Concurrent control | Did not receive training, | NA | NA | Individuals | T: NA | NA | NA | NA | Unclear | To assess the effects of CME on cancer prevention practices on new patients requesting a PHE
| | n assigned: 32, | | | | W: NA
| | n analysis: 32 | | | | D: NA
| Intervention | Received CME on cancer detection, | Live, video | Demonstration, discussion group, feedback, lecture, programmed learning, role play | Individuals | T: 8 | One time | 1 year | NR | Unclear
| | n assigned: 25, | | | | W: Once only
| | n analysis: 25 | | | | D: NR
Casebeer, 1999^131^ | Concurrent control | No training on hypercholesterolemic management, | NA | NA | NA | T: NA | NA | | NA | NA | Improving physicians' performances in helping their hypercholesterolemic patients adhere to therapeutic regimens and in improving the health of those patients
| | n assigned: 14, | | | | W: NA
| | n analysis: 12 | | | | D: NA
| Intervention | Three interactive audio conferences plus chart reminders on managing hypercholesterolemic patients, | Audio, telephone conferences | Case-based learning, discussion group, point of care | Individuals | T: NR | Multiple time or repetitive | 9 month | NR | No
| | n assigned: 14, | | | | W: NR
| | n analysis: 14 | | | | D: NR
Chan, 1999^21^ | Concurrent control | No small group learning, but was provided with similar resources, | NA | NA | NA | T: NA | NA | NA | NA | NA | Present the patient problem, elaborate the patient problem (laboratory results and past medical history, etc) and redirect the group. Using the Internet to recreate successful PBL CME learning for rural physicians.
| | n assigned: 12, | | | | W: NA
| | n analysis: 11 | | | | D: NA
| Intervention | Internet based problem-based small group learning, | Internet, not real time | Problem-based learning or team-based learning | Individuals | T: NR | Multiple time or repetitive | 2 months | NR | No
| | n assigned: 11, | | | | W: NR
| | n analysis: 8 | | | | D: 2 months
Chassin, 1986^106^ | Intervention | Educational interventions to reduce pelvimetry rates, | Live, print | Feedback, lecture, 16 of 64 hospitals received only print mailings to physicians with privileges, without lecture | Practice setting/ teams | T: NR | One time | 10 months | Yes | Yes | To reduce the inappropriate use of x-ray pelvimetry
| | n assigned: 64 hospitals, | | | | W: NR
| | n analysis: 64 hospitals
| Concurrent control | No interventions regarding pelvimetry rates, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 56 hospitals, | | | | W: NA
| | n analysis: 56 hospitals
Cherkin, 1991^83^ | Intervention | University physicians: received 2 lectures and 1 video, | Live, video | Demonstration, discussion group, lecture | Individuals | T: NR | Multiple time or repetitive | 4 months | Yes | Unclear | Primary goal was to increase physician comfort and confidence in the management of back pain and to provide patients with additional information and assurance. A secondary goal was to reduce unnecessary spine radiography and lengthy bed rest prescriptions.
| | n assigned: 23, | | | | W: NR
| | n analysis: 15 | | | | D: NR
| Intervention | Community physicians—received 1 workshop, | Live, video | Demonstration, discussion group, lecture | Individuals | T: 1.5 | One time | 1–2 months | Yes | Unclear
| | n assigned: 17, | | | | W: Once only
| | n analysis: 14 | | | | D: NR
Chodosh, 2006^62^ | Intervention | Primary care providers at clinics randomized to a comprehensive management program for patients with dementia (ACCESS) and a provider education program, | Live, internet, not real time, print | Discussion group, lecture | Practice setting/ teams | T: NR | Multiple time or repetitive | 9 months | No | Yes | To improve the quality of care for dementia patients by educating providers about dementia management program, role of care managers and care protocols, recognition and treatment of dementia and depression, and assessment of capacity for medical decision-making
| | n analysis: 96 | | | | W: NR
| | | | | | D: NR
| Concurrent control | Primary care providers at clinics randomized to no management program or educational program, | NA | NA | Individuals, NA | T: NA | NA | NA | NA | NA
| | n analysis: 70 | | | | W: NA
| | | | | | D: NA
Chung, 2004^54^ | Intervention | Web intervention group, | Live, internet, not real time | Case-based learning, lecture, readings | Individuals | T: 1 lecture + website access | Multiple time or repetitive | 6 months | No | No | ”...determine if a web-based educational intervention improved physician knowledge about the recognition and medical management of diseases caused by biological agents. ...evaluate physicians' general knowledge of bioterrorism, identify their sources of information, and self-assess comfort level with the diagnosis of specific biological agents.”
| | n analysis: 31 | | | | W: NA
| | | | | | D: 1 month
| Concurrent control | Control group, | Live | Lecture | Individuals | T: 1 | One time | 6 months | NA | No
| | n analysis: 32 | | | | W: Once only
| | | | | | D: 1 month
Clark, 1998^120^ | Concurrent control | No educational intervention provided, | NA | NA | Individuals | T: NA | NA | 22 months | NA | No | To determine if an educational intervention targeting both physician knowledge and practice behaviors would have an impact on physician management of asthma, parents self-reported decision-making ability regarding managing asthma, as well as patient outcomes
| | n assigned: NR | | | | W: NA
| | | | | | D: NA
| Intervention | Attended seminars on asthma management, | Live, video | Case-based learning, clinical experiences, lecture | Individuals | T: 5 | Multiple time or repetitive | 22 months | NR | No
| | n assigned: NR | | | | W: NR
| | | | | | D: 2–3 weeks
Clark, 2000^78^ | Concurrent control | Pediatricians NOT receiving CME intervention, | NA | NA | Individuals | T: NA | NA | 2 years | NR | No | To evaluate the long-term impact of an interactive seminar for physicians based on principles of self-regulation on clinician behavior, children's use of health services for asthma, and parents' views of physician performance.
| | n assigned: 36, | | | | W: NA
| | n analysis: 33 | | | | D: NA
| Intervention | Pediatricians receiving CME intervention, | Live, video | Case-based learning, demonstration, lecture | Individuals | T: 5 | Multiple time or repetitive | 2 years | NR | No
| | n assigned: 38, | | | | W: NR
| | n analysis: 34 | | | | D: 2–3 weeks
Cohn, 2002^19^ | Intervention | Single intervention community, | Live, print | Academic detailing | Individuals | T: NR | Multiple time or repetitive | 3–6 months | NR | No | Increase health care providers' awareness of preventive care for women exposed to DES before birth
| | n assigned: 30, | | | | W: NA
| | n analysis: 13 | | | | D: NR
| Intervention | Double intervention community, | Live, print | Academic detailing | Individuals | T: NR | Multiple time or repetitive | 3–6 months | NR | No
| | n assigned: 29, | | | | W: NA
| | n analysis: 21 | | | | D: NR
| Concurrent control | Control community, | NA | NA | NA | T: NA | NA | 3–6 months | NR | No
| | n assigned: 24, | | | | W: NA
| | n analysis: 22 | | | | D: NR
Costanza, 1992^35^ | Concurrent control | Comparison, no intervention done, | NA | NA | NA | T: NA | NA | NA | NA | NA | To improve compliance with the National Cancer Institute's breast cancer screening guidelines.
| | n assigned: 64, | | | | W: NA
| | n analysis: 64 (pre) and 55 (post) | | | | D: NA
| Intervention | Intervention: received CME on breast cancer screening via both direct lectures, CBE practice sessions, and office reminder systems, | Live, print | Discussion group, lecture, point of care, simulation (other than standardized patient or role-play) | Individuals | T: NR | Multiple time or repetitive | NR | Yes | No
| | n assigned: 52, | | | | W: NR
| | n analysis: 52 (pre) and 45 (post) | | | | D: NR
Cummings, 1989^112^ | Intervention | Physicians participating in a 3-part seminar, | Live, video, print | Demonstration, discussion group, lecture, role play | Individuals | T: | Multiple time or repetitive | 1 year | Yes | No | To test the hypothesis that physicians in private practice who receive a continuing education program about how to counsel smokers to quit would counsel smokers more effectively and have higher rates of long-term smoking cessation among their patients.
| | n assigned: 31, | | | | W: NR
| | n analysis: 24 | | | | D: 5–14 weeks
| Concurrent control | Did not participate in seminar—control group, | NA | NA | Individuals, NA | T: NA | NA | 1 year | Yes | No
| | n assigned: 28, | | | | W: NR
| | n analysis: 20 | | | | D: NA
Cummings, 1989^113^ | Concurrent control | Control group did not participate in the seminar, | NA | NA | Individuals, NA | T: NA | NA | 1 year | Yes | Unclear | To test whether physicians who receive a continuing education program about how to counsel smokers to quit would counsel smokers more effectively and have higher rates of long-term smoking cessation among their patients who smoke.
| | n assigned: 41, | | | | W: NR
| | n analysis: 41 | | | | D: NA
| Intervention | Intervention group participated in a 3-part seminar, | Live, video, print | Case-based learning, demonstration, discussion group, lecture, role play | Individuals | T: 3 | Multiple time or repetitive | 1 Year | Yes | Unclear
| | n assigned: 40, | | | | W: NR
| | n analysis: 40 | | | | D: 5–14 weeks
Cummings, 1989^117^ | Intervention | Physicians participating in seminars about smoking cessation counseling, | Live, video, patient education materials | Case-based learning, demonstration, role play, self-reflection | Individuals | T: 3 | Multiple time or repetitive | 1 year | NR | No | To teach physicians to use a systematic approach to counseling smokers in cessation
| | n assigned: 31, | | | | W: 1 day/week
| | n analysis: 24 | | | | D: 5–14 weeks
| Concurrent control | Physicians receiving no training, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 28, | | | | W: NA
| | n analysis: 20 | | | | D: NA
Curran, 2000^34^ | Concurrent control | No CME instruction/course, | NA | NA | NA | T: NA | NA | NA | NA | NA | This evaluation study assessed the instructional effectiveness of a hybrid computer-mediated courseware delivery system on dermatologic office procedures.
| | n assigned: 22 | | | | W: NA
| | | | | | D: NA
| Intervention | Computer and web-based instructional course on dermatological office practices, | Computer-based off-line, Internet, not real time | Case-based learning, programmed learning, computer-based courseware | Individuals | T: NR | Multiple time or repetitive | NR | Yes | Unclear
| | n assigned: 16 | | | | W: NR
| | | | | | D: NR
| Intervention | Computer and web-based instructional course on dermatological office practices, | Computer-based off-line, internet, not real time | Case-based learning, programmed learning, computer-based courseware | Individuals | T: NR | One time | NR | Yes | Unclear
| | n assigned: 14 | | | | W: NR
| | | | | | D: NR
Davis, 2004^101^ | Intervention | Primary care physicians who were part of the Dean Health System (Madison, WI), | Live, video, audio, audio teleconferencing | Case-based learning, discussion group, problem-based learning or team-based learning | Individuals | T: 2.25–3.00 | Multiple time or repetitive | 6 months | Yes | Unclear | ”A group of pediatricians was recruited to participate in several PBL teleconferences in an effort to evaluate whether this mode of CME could improve their compliance with updated asthma guidelines, particularly with respect to controller use.
| | n assigned: 30, | | | | W: 1 day/week
| | n analysis: 20 | | | | D: 3 weeks
| Concurrent control | Those primary care physicians who chose not to participate in the study- from the same clinics (Dean Health System) as the intervention group, | NA | NA | NA | T: NA | NA | 6 months | | Unclear
| | n assigned: 34 | | | | W: NA
| | | | | | D: NA
Derebery, 2002^153^ | Concurrent control | Physicians who did not participate in educational workshop and were given a copy of the low back pain manual with no specific instructions, | Print | Readings | Individuals | T: NA | NA | 1 year | No | No | ”The purpose of this study then is to evaluate whether the educational strategy was effective in changing physicians' management behaviors of lower back pain.”
| | n analysis: 151 | | | | W: NA
| | | | | | D: NR
| Intervention | Physicians who participated in education intervention during CMC Professional Development Conference, | Live, print | Demonstration, discussion group, lecture, problem-based learning or team-based learning, readings, simulation (other than standardized patient or role-play) | Individuals | T: 10 (2 workshop+8 reading) | In addition to workshop, physicians received updated low back pain manual to read on their own within 2–3 months for additional CME credit | 1 year | No | No
| | n analysis: 107 | | | | W: NA
| | | | | | D:
Des Marchais, 1990^61^ | Intervention | Practical training in assessing interpersonal skills of their learners, followed by theory-based training, | Live, video | Case-based learning, demonstration, discussion group, reflection about personal experiences | Individuals | T: NR | NR | NR | NR | No | To train faculty in the appropriate and reliable assessment of interpersonal skills in their learners
| | n assigned: 12 | | | | W: NR
| | | | | | D: NR
| Intervention | Theory-based training in assessing interpersonal skills, followed by practical training, | Live, video | Case-based learning, demonstration, discussion group, reflection about personal experiences | Individuals | T: NR | NR | NR | NR | Unclear
| | n assigned: 13 | | | | W: NR
| | | | | | D: NR
Dietrich, 2000^110^ | Concurrent control | Completed statewide survey about sun protection counseling and did not practice in intervention communities, | NA | NA | NA | T: NA | NA | NA | NA | NA | To enhance sun protection advocacy/ counseling by primary care clinicians for children in New Hampshire communities
| | n analysis: 12 | | | | W: NA
| | | | | | D: NA
| Intervention | Community-based and practice-based interventions to increase sun protection counseling, | Live, print, telephone call | Academic detailing, lecture, problem-based learning or team-based learning, readings | Practice setting/ teams | T: 30–45 minutes for first office meeting, otherwise NR | Multiple time or repetitive | about 1 year | NR | Yes
| | n analysis: 29 | | | | W: NR
| | | | | | D: NR
Dormuth, 2004^15^ | Concurrent control | Control group that received intervention 3–8 months later after the intervention group, | Print | Readings | Individuals, practice settings/ teams | T: NR | Multiple time or repetitive | NR | NR | Yes | The overall goal of the intervention is to increase the probability of prescribing a drug recommended in the Therapeutic Letter rather than other drugs in the same class.
| | n assigned: 241 | | | | W: NR
| | | | | | D: NR
| Intervention | Intervention group that received evidence-based drug therapy letters, | Print | Readings | Individuals, practice setting/ teams | T: NR | Multiple time or repetitive | NR | NR | Yes
| | n assigned: 258 | | | | W: NR
| | | | | | D: 3.17 years
Doucet, 1998^40^ | Concurrent control | Lecture group, | Live | Discussion group, lecture | Individuals | T: 2 | One time | 3 months | Yes | Unclear | 1 Educate primary care physicians about headache, especially migraine, CDH and MIH.; 2 Increase awareness of how attitudes toward headache affect the diagnosis and ongoing management of patients.; 3 Understand the importance of the doctor-patient relationship in the therapeutic intervention and management of these headache types.; 4 Educate primary care physicians in the comprehensive management of migraine, CDH and MIH.
| | n assigned: 49, | | | | W: Once only
| | n analysis: 29 for the pre- and post-tests; 26 for the KFP assessments; and 26 for the CME evaluation | | | | D: NA
| Intervention | PBL group, | Live | Problem-based learning or team-based learning | Individuals | T: 6 | Multiple time or repetitive | 3 months | Yes | Unclear
| | n assigned: 38, | | | | W: 1 day/week
| | n analysis: 34 for the pre and post-tests; 21 for the KFP test; and 29 for the CME evaluation | | | | D: 3 weeks
Elliott, 1997^55^ | Intervention | Extensive intervention including training opinion leaders on cancer pain management and then dissemination of information to their communities, | Live, print | Case-based learning, clinical experiences, discussion group, lecture, readings | Practice settings/ teams | T: NR | Multiple time or repetitive | 15 months | NR | No | To improve the knowledge, attitudes, and clinical behaviors of physicians and nurses, improve the knowledge and attitudes about CPM of cancer patients and their families members, and to reduce cancer related pain experienced in cancer patients
| | n assigned: 3 communities | | | | W: NR
| | | | | | D: 1 year
| Concurrent control | No intervention, | NA | NA | NA | T: NA | NA | NA | NA | No
| | n assigned: 3 communities | | | | W: NA
| | | | | | D: NA
Evans CE, 1986^56^ | Concurrent control | No education or office materials about hypertension, | NA | NA | NA | T: NA | NA | 21 months | NA | NA | To improve physician's management of patients with hypertension and to lower patients' blood pressures
| | n assigned: 35 physicians (29 practices) | | | | W: NA
| | | | | | D: NA
| Intervention | 14 weekly information packets about hypertension diagnosis and management, as well as office materials, | Print | Readings, chart cue materials offered, but not necessarily implemented | Individuals, practice setting/ teams | T: NR | Multiple time or repetitive | 21 months | NR | Unclear
| | n assigned: 41 physicians (33 practices) | | | | W: 1 day/week
| | | | | | D: NR
Fordis, 2005^42^ | Intervention | Online CME about cholesterol management; 20 randomly selected for chart review in phase II, | Internet, real time (e.g. streaming) internet, not real time, print, risk calculator | Case-based learning, lecture, programmed learning, readings | Individuals | T: 3.8 | Multiple time or repetitive | 5 months | Yes | Yes | The overall goal of the educational intervention was to improve knowledge in cholesterol management guidelines and improve appropriate treatment for cholesterol.
| | n assigned: 52, | | | | W: NR
| | n analysis: 44 test (17 chart review) | | | | D: 2 weeks
| Intervention | Live CME about cholesterol management (exists in phase I and phase II); 20 randomly selected for chart review in phase II, | Live, print, risk calculator | Case-based learning, lecture, programmed learning, readings | Individuals | T: 1.75 | One time | 5 months | Yes | Yes
| | n assigned: 51, | | | | W: Once only
| | n analysis: 49 test (19 chart review) | | | | D: 10 days
| Concurrent control | No training on cholesterol management, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 20, | | | | W: NA
| | n analysis: 18 chart review | | | | D: NA
Frush, 2006^87^ | Intervention | Web-based education program, | Internet, not real time, video | Lecture, simulated scenario | Individuals | T: NR | education was available for 3 months | NR | No | Yes | The goal was to improve the proper use of the Broselow Pediatric Resuscitation Tape to reduce dosing errors and time to determine dose.
| | n analysis: 43 | | | | W: NR
| | | | | | D: NR
| Concurrent control | Control, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n analysis: 44 | | | | W: NA
| | | | | | D: NA
Gerbert, 2002^86^ | Concurrent control | Control group, | NA | NA | Individuals | T: NA | NA | 8 weeks | No | No | To improve physician skin cancer diagnosis and evaluation planning test performance
| | n analysis: 32 | | | | W: NA
| | | | | | D: NA
| Intervention | Intervention group, | Internet, not real time | Case-based learning, feedback, programmed learning, readings | Individuals | T: NR | Multiple time or repetitive | 8 weeks | No | No
| | n analysis: 39 | | | | W: NA
| | | | | | D: NR
Gerrity, 1999^32^ | Intervention | Depression Education Program, two 4-hour sessions about recognition and management of depression and syllabus, | Live, video, audio, print | Clinical experiences, discussion group, feedback, lecture, readings, role play | Individuals | T: 8 | Multiple time or repetitive | 2–6 weeks | NR | No | To improve primary care physicians' knowledge of depression (diagnosis and treatment) and the communication skills they use with patients with the disease
| | n assigned: 27, | | | | W: 1 day/week
| | n analysis: 23 | | | | D: 2 weeks
| Concurrent control | No training on depression recognition and management, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 29, | | | | W: NA
| | n analysis: 26 | | | | D: NA
Gerstein, 1999^53^ | Intervention | Workshop on diabetes-specific clinical practice guidelines, | Live | Case-based learning, discussion group | Individuals | T: 7 | One time | 24 months | NR | No | The overall goal of the intervention is to improve participants' attitude, knowledge, and practice behavior regarding diabetes.
| | n assigned: 1807, | | | | W: Once only
| | n analysis: 177 | | | | D: 1 day
| Concurrent control | Control group that did not attend workshop, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n analysis: 113 | | | | W: NA
| | | | | | D: NA
Gifford, 1996^46^ | Intervention | Neurologists subscribing to AAN CME course, who received movement disorders module, | Video, print | Programmed learning, readings | Individuals | T: 6.0 hours median | Multiple time or repetitive | 4–5 months | Yes | No | To improve neurologists' adherence to practice recommendations on disease detection, diagnostic test use, and treatments for movement disorders.
| | n assigned: 248, | | | | W: NR
| | n analysis: 176 | | | | D: NR
| Concurrent control | Neurologists subscribing to AAN CME course, who did not receive the movement disorders module, | NA | NA | NA | T: NA | NA | 4–5 months | NA | No
| | n assigned: 244, | | | | W: NA
| | n analysis: 183 | | | | D: NA
Gifford, 1999^142^ | Intervention | Neurologists who received mailed CONTINUUM Dementia Care Course, resource manual, seminar, and mailings: post-intervention evaluation, | Live, print | Case-based learning, discussion group, lecture, readings, mailings | Individuals, practice settings/ teams | T: 3 for seminar, otherwise NR | One time | 6 months | NR | No | The overall goal of the intervention is to improve adherence to guideline recommendations for the care of patients with dementia endorsed by the American Academy of Neurology and local opinion leaders.
| | n assigned: 139, | | | | W: Once only
| | n analysis: 95 | | | | D: 4 months
| Historical control | Baseline neurologists who do not receive teaching about dementia care: pre-intervention evaluation, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 139, | | | | W: NA
| | n analysis: 108 | | | | D: NA
| Concurrent control | Control neurologists who received no training about dementia care: post-intervention evaluation, | NA | NA | NA | T: NA | NA | | NA | NA
| | n assigned: 139, | | | | W: NA
| | n analysis: 102 | | | | D: NA
Goldberg, 2001^93^ | Intervention | 5 communities in W. Washington State with higher than average annual number of spine surgeries performed, | Live, video, print | Academic detailing, discussion group, lecture | Practice setting/ teams | T: NR | Multiple time or repetitive | NA | NR | Yes | ”To implement the conservative, evidence-based approach to low-back pain recommended in national guidelines, with the anticipated effect of reducing population-based rates of surgery.”
| | n assigned: 5 | | | | W: NR
| | | | | | D: 30 months
| Concurrent control | 5 communities in W. Washington State with higher than average annual number of spine surgeries performed, | NA | NA | NA | T: NA | NA | NA | NR | NA
| | n assigned: 5 | | | | W: NA
| | | | | | D: 30 months
Goldstein, 2005^146^ | Intervention | Individualized-intervention group, | Live, print | Discussion group, readings, packet which had patient-specific information form and advisory about guideline concordance of patient's antihypertensive drug regimen | Individuals | T: NR | Received multiple items for | NR | NR | Yes | The overall goal of the educational intervention would increase clinician adherence to drug-therapy guidelines in primary care clinics of a large healthcare system.
| | n analysis: 20 | | | | W: NA
| | | | | | D: NR
| Intervention | General-intervention group, | Live, print | Discussion group, readings, packet which had patient-specific information form | Individuals | T: NR | Received multiple items for | NR | NR | Yes
| | n analysis: 16 | | | | W: NA
| | | | | | D: NR
Goldwater, 2001^157^ | Intervention | Standard educational tools, | Print | Academic detailing, point of care, readings | Practice settings/ teams | T: NA | Multiple time or repetitive | NR | No | No | To achieve health care cost reductions without compromising the quality of patient care
| | n assigned: NR | | | | W: NR
| | | | | | D: 14 months
| Intervention | Therapeutic interchange, | Print | Academic detailing, point of care | Practice setting/ teams | T: NA | Multiple time or repetitive | NR | No | No
| | n assigned: NR | | | | W: NR
| | | | | | D: 14 months
Gonzales, 1999^111^ | Intervention | Limited intervention, received household and office-based materials only, | Print | Academic detailing, point of care | Individuals, practice settings/ teams | T: NA | NA | 1 year | NR | Unclear | To decrease total antibiotic use for uncomplicated acute bronchitis
| | n assigned: 31 | | | | W: Once only
| | | | | | D: NR
| Intervention | Full intervention, received household and office-based materials and an educational intervention, | Live, print | Academic detailing, demonstration, lecture, point of care | Individuals, Practice setting/ teams | T: 0.5 | One time | 1 year | NR | Unclear
| | n assigned: 28 | | | | W: Once only
| | | | | | D: 30 minutes
| Concurrent control | Control, | NA | NA | Individuals, practice settings/ teams | T: NA | NA | NA | NR | Unclear
| | n assigned: 34 | | | | W: NA
| | | | | | D: NA
Grady, 1997^79^ | Intervention | Cue enhancement, education, and peer comparison feedback and rewards (money), | Live, print | Feedback, lecture, point of care, readings, financial reward for compliance | Individuals, practice settings/ teams | T: NR | Multiple time or repetitive | NR | NR | No | To determine if cuing will result in significantly more referrals, completions, and compliance than physician education alone; that peer performance feedback and reward will result in more referrals.
| | n analysis: 20 | | | | W: NR
| | | | | | D: 1 year
| Concurrent control | Education only, | Live, print | Lecture, readings | Individuals, practice setting teams | T: NR | One time | NR | NR | No
| | n analysis: 23 | | | | W: Once only
| | | | | | D: NR
| Intervention | Cue enhancement (posters, chart stickers) plus education, | Live, print | Lecture, point of care, readings | Individuals, practice settings/ teams | T: NR | Multiple time or repetitive | NR | NR | No
| | n analysis: 18 | | | | W: NR
| | | | | | D: 1 year
Greenberg, 1985^25^ | Intervention | Lecture-based education on headaches or behavior problems, | Live | Lecture | Individuals | T: 1 | One time | 6–9 months | NR | No | To improve physician knowledge, skills, and behavior regarding common pediatric medical problems and to investigate differences in lecture or case-based learning
| | n assigned: 26 | | | | W: Once only
| | | | | | D: 1 hour
| Intervention | Case-based presentations on enuresis or sleep disorders, | Live | Case-based learning | Individuals | T: 1 | One time | 6–9 months | NR | No
| | n assigned: 22 | | | | W: Once only
| | | | | | D: 1 hour
Gullion, 1988^132^ | Concurrent control | No education about hypertension management, | NA | NA | NA | T: NA | NA | NA | NA | NA | ”The intervention attempted to improve physicians' management of hypertension through both medication and behavioral approaches.”
| | n assigned: 27, | | | | W: NA
| | n analysis: 26 | | | | D: NA
| Intervention | Education about behavioral management for hypertension, | Print, telephone conference | Discussion group, feedback, readings | Individuals | T: 1 hour call + reading time | Multiple time or repetitive | 11 months | NR | No
| | n assigned: 28, | | | | W: NR
| | n analysis: 27 | | | | D: NR
| Intervention | Education about medication and behavioral management for hypertension, | Print, telephone conference | Discussion group, feedback, readings | Individuals | T: 2 hours on call + reading time | Multiple time or repetitive | 11 months | NR | No
| | n assigned: 30, | | | | W: NR
| | n analysis: 29 | | | | D: NR
| Intervention | Education about medication management for hypertension, | Print, telephone conference | Discussion group, feedback, readings | Individuals | T: 1 hour call + reading time | Multiple time or repetitive | 11 months | NR | No
| | n assigned: 27, | | | | W: NR
| | n analysis: 25 | | | | D: NR
Hagen, 2005^126^ | Intervention | Education for physicians, nursing staff, pharmacists, and family members, | Live, print, laminated copies to be posted at stations and in charts | Lecture, readings | Practice setting/ teams | T: 1.75 | Multiple time or repetitive | 6 months | NR | Yes | The overall goal of the educational intervention is to decrease the use of psychotropics and dosage of psychotropics.
| | n assigned: NR | | | | W: NR
| | | | | | D: NR
| Concurrent control | No education, | NA | NA | NA | T: NA | NA | NA | NR | NA
| | n assigned: NR | | | | W: NA
| | | | | | D: NA
Harris, 2002^39^ | Intervention | Intervention group participating in the online domestic violence education program, | Internet, not real time | Case-based learning, feedback, readings | Individuals | T: NR | Multiple time or repetitive | 3 weeks | Yes | No | ”Improve the confidence of practicing physicians managing domestic violence patients.”
| | n assigned: 50, | | | | W: NR
| | n analysis: 28 | | | | D: 2 weeks
| Concurrent control | Control group not receiving education intervention about domestic violence. | NA | NA | NA | T: NA | NA | 3 weeks | NA | NA
| | n assigned: 49, | | | | W: NA
| | n analysis: 37 | | | | D: NA
Harris, 2005^75^ | Intervention | Intervention group that received TED (teleconferenced education detailing), | Live, audio, print, teleconference | Case-based learning, lecture, readings | Individuals, practice setting/ teams | T: 8 | Multiple time or repetitive | 12 months | Yes | Yes | The overall goal of the educational intervention was to evaluate if methods improved regarding diabetes treatment.
| | n assigned: 43, | | | | W: NR
| | n analysis: 32 | | | | D: 8, one hour sessions
| Concurrent control | Control group, | NA | NA | Individuals, practice settings/ teams | T: NA | NA | NA | NA | NA
| | n assigned: 47, | | | | W: NA
| | n analysis: 29 | | | | D: NA
Heale, 1988^66^ | Intervention | Small group, problem based sessions for a one day CME, | Live | Problem-based learning or team-based learning | Individuals | T: NR | One time | 7 months | NR | No | To test the effectiveness of different learning formats. Six topic areas were selected: transient ischemic attack, hypertension, premenstrual syndrome, chlamydial infections, dementia, common prescribing mistakes. Several specific learning objectives were carefully identified in each of these areas.
| | n analysis: 22 | | | | W: Once only
| | | | | | D: 1 day
| Intervention | Large group, case problem discussion educational method for one day CME, | Live | Case-based learning, discussion group | Individuals | T: NR | One time | 7 months | NR | No
| | n analysis: 12 | | | | W: Once only
| | | | | | D: 1 day
| Intervention | Traditional lecture educational method for 1 day CME, | Live | Lecture | Individuals | T: NR | One time | 7 months | NR | No
| | n analysis: 27 | | | | W: Once only
| | | | | | D: 1 day
Herbert, 2004^102^ | Concurrent control | Control module and no portrait, | Live | NA | Individuals | T: <2 | One time | 6 months | NA | NA | This intervention was designed to affect prescribing for hypertension.
| | n assigned: 56 | | | | W: Once only
| | | | | | D: NR
| Intervention | Control module and portrait, | Live | Clinical experiences, feedback, readings | Individuals | T: <2 | One time | 6 months | NR | Unclear
| | n assigned: 48 | | | | W: Once only
| | | | | | D: NR
| Intervention | Experimental module and portrait, | Live | Case-based learning, clinical experiences, demonstration, discussion group, problem- or team-based learning, readings | Individuals | T: <2 | One time | 6 months | NR | Unclear
| | n assigned: 49 | | | | W: Once only
| | | | | | D: NR
| Intervention | Experimental module and no portrait, | Live | Case-based learning, clinical experiences, demonstration, discussion group, problem- or team-based learning | Individuals | T: <2 | One time | 6 months | NR | Unclear
| | n assigned: 47 | | | | W: Once only
| | | | | | D: NR
Hergenroeder, 2002^60^ | Intervention | Video + skills instruction intervention group, | Live, video, print | Demonstration, feedback, simulation (other than standardized patient or role-play) | Individuals | T: NR | One time | NR | No | No | Teach physical examination of the ankle and knee to improve the knowledge and skills of pediatricians.
| | n assigned: 52, | | | | W: Once only
| | n analysis: 42 | | | | D: NR
| Intervention | Video only intervention group, | Video, Print | Demonstration | Individuals | T: NR | One time | NR | No | No
| | n assigned: 49, | | | | W: Once only
| | n analysis: 33 | | | | D: NR
Howe, 1997^145^ | Intervention | Patients diagnosed at 5 rural hospitals with intensive intervention: visits by urban oncologists, audit with feedback, physician reminder systems, | NR | Feedback, lecture, point of care, readings (the major difference between the groups was the intensity of the intervention) | NR | T: NR | Multiple time or repetitive | 2 years | NR | No | To determine if a more intensive outreach educational program had a greater impact on breast cancer management than audit and feedback program alone in eliminating the urban-rural difference in breast cancer management
| | n assigned: 201 patients (pre and post combined)/5 facilities | | | | W: NR
| | | | | | D: 2 years
| Intervention | Urban patients, received less intensive interventions, | NR | Feedback, point of care, readings | NR | T: NR | NR | 2 years | NR | No
| | n assigned: 947 patients/4 facilities | | | | W: NR
| | | | | | D: 2 years
| Intervention | Patients from rural areas but received care at urban centers which received only audit and feedback (less intensive) intervention, | NR | Feedback, point of care, readings | NR | T: NR | NR | 2 years | NR | No
| | n assigned: 265 patients/4 facilities | | | | W: NR
| | | | | | D: 2 years
| Intervention | Patients diagnosed and treated in hospitals receiving only audit and feedback (less intensive) intervention, | NR | Feedback, point of care, readings | NR | T: NR | Multiple time or repetitive | 2 years | NR | No
| | n assigned: 114 patients/4 facilities | | | | W: NR
| | | | | | D: 2 years
Jennett, 1988^76^ | Intervention | Cancer medicine CME, | Live, print, teleconference | Discussion group, feedback, mentor/ preceptor, readings | Individuals | T: 6.8 | Multiple time or repetitive | 12 months | NR | Unclear | To change doctor office behavior in the fields of cancer and cardiovascular medicine. Critical learning objectives listed in Table 3.
| | n assigned: 9, | | | | W: NR
| | n analysis: 9 | | | | D: 6–8 weeks
| Concurrent control | No CME, | NA | NA | NA | T: NA | NA | 12 months | NA | NA
| | n assigned: 11, | | | | W: NA
| | n analysis: 11 | | | | D: NA
| Intervention | Cardiovascular CME, | Live, print, teleconference | Discussion group, feedback, mentor/ preceptor, readings | Individuals | T: 7.7 hours | Multiple time or repetitive | 12 months | NR | Unclear
| | n assigned: 11, | | | | W: NR
| | n analysis: 10 | | | | D: 6–8 weeks
Juzych, 2005^92^ | Concurrent control | Control group, | NA | NA | NA | T: NA | NA | NA | NA | NA | The overall goal of the educational intervention was to reduce the amount of unnecessary antibiotic treatment for respiratory infections.
| | n assigned: 9, | | | | W: NA
| | n analysis: 9 | | | | D: NA
| Intervention | Educational intervention group, | Live, print | Case-based learning, lecture, readings | Individuals, practice setting/ teams | T: NR | Not perfectly clear, but seems to be a single half day session | NR | NR | Yes
| | n assigned: 21, | | | | W: NR
| | n analysis: 14 | | | | D: NR
Kemper, 2006^58^ | Intervention | Pull + drip, | Internet, not real time | Discussion group, problem-based learning or team-based learning | Individuals | T: NR | Online discussions; case-based, self-instructional modules | NR | Yes | Unclear | The goal of the educational intervention is to provide training on complementary or alternative medicine. The goal of the study was to examine the difference between “drip” (small amounts of information over a period of time) versus “bolus” methods (large amounts of information over a short period of time) and the difference between “push” and “pull” methods of delivery (email delivery or availability on a web site).
| | n assigned: 318, | | | | W: NR
| | n analysis: 202 | | | | D: NR
| Intervention | Push + drip, | Internet, not real time | Discussion group, problem-based learning or team-based learning | Individuals | T: NR | Online discussions; case-based, self-instructional modules | NR | Yes | Unclear
| | n assigned: 318, | | | | W: NR
| | n analysis: 206 | | | | D: NR
| Intervention | Pull + bolus, | Internet, not real time | Discussion group, problem-based learning or team-based learning | Individuals | T: NR | Online discussions; case-based, self-instructional modules | NR | Yes | Unclear
| | n assigned: 313, | | | | W: NR
| | n analysis: 177 | | | | D: NR
| Intervention | Push + bolus, | Internet, not real time | Discussion group, problem-based learning or team-based learning | Individuals | T: NR | Online discussions; case-based, self-instructional modules | NR | Yes | Unclear
| | n assigned: 318, | | | | W: NR
| | n analysis: 195 | | | | D: NR
Kiang, 2005^33^ | Concurrent control | Minnesota group, 2002, | NA | NA | NA | T: NA | not clear | NA | NA | NA | The overall goal of the educational intervention was to see if the WARN campaign would improve the “desired” responses of the primary care physicians regarding knowledge, beliefs, and decision-making of appropriate antimicrobial drug use for upper respiratory infections.
| | n assigned: 400 | | | | W: NA
| | | | | | D: NA
| Concurrent control | Minnesota group, 1999, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 400 | | | | W: NA
| | | | | | D: NA
| Intervention | Wisconsin group, 1999, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 400 | | | | W: NA
| | | | | | D: NA
| Intervention | Wisconsin group, 2002, | Many things were made available but it is not reported as to which groups used what methods. Options included live, regional meetings, CD-ROMs, mailings, grand rounds | Not clear | NR | T: NR | not clear | NR | NR | Yes
| | n assigned: 600 | | | | W: NR
| | | | | | D: NR
Kim, 1999^137^ | Concurrent control | Educational materials about preventative care practices only, | Print | Readings | NA | T: NA | Multiple time or repetitive | 2–2.5 years | NR | NA | To improve the quality of care, as measured by the provision of preventative care services recommended by U.S. Preventative Services Task Force, as well as lead to better patient satisfaction
| | n assigned: 24 MDs, 905 patients, | | | | W: NR
| | n analysis: 20 MDs | | | | D: 1 year
| Intervention | Educational materials about preventative care practices, peer-comparison feedback, and academic detailing from a pharmacist three times over a year, | Live, print | Academic detailing feedback, readings | Individuals | T: NR | Multiple time or repetitive | 2–2.5 years | NR | No
| | n assigned: 24 MDs, 905 patients, | | | | W: NR
| | n analysis: 21 MDs | | | | D: 1 year
Kottke, 1989^114^ | Intervention | Only educational materials for patient distribution, | Print | Readings | Individuals | T: NA | NR | 1 year | NR | Unclear | To develop a program to help physicians incorporate smoking cessation into their practice routine.
| | n assigned: 22 | | | | W: NA
| | | | | | D: NA
| Intervention | Workshop training and educational materials for patient distribution, | Live, print | Demonstration, discussion group, lecture, readings | Individuals | T: 6 | One time | 1 year | NR | Unclear
| | n assigned: 27 | | | | W: Once only
| | | | | | D: 6 hours
| Concurrent control | Control, | NA | NA | NA | T: NA | NA | 1 year | NR | Unclear
| | n assigned: 17 | | | | W: NA
| | | | | | D: NA
Kronick, 2003^71^ | Concurrent control | Control physicians receiving no training, | NA | NA | NA | T: NA | NA | 3 months | NA | NA | “...assess changes in the frequency and methods with which a group of rural physicians consulted on-line medical resources before and after the educational intervention. The intervention taught them how to search for and retrieve reliable, peer-reviewed, evidence-based information from bibliographic databases, such as PubMed and the Cochrane Library, and how to find additional resources in the University of Western Ontario (UWO) libraries' online collections.”
| | n assigned: 40, | | | | W: NA
| | n analysis: 40 | | | | D: NR
| Intervention | Individualized training sessions on evidence-based information retrieval by trained hospital librarians, | Live | Case-based learning, demonstration | Individuals | T: 3 | One time | 3 months | NA | No
| | n assigned: 41, | | | | W: Once only
| | n analysis: 30 | | | | D: NR
Kutcher, 2002^65^ | Intervention | General educational intervention program (small group info format), | Live, print | Discussion group, lecture, readings | Individuals | T: 1 | One time | 6 months | No | No | ”...the aim of this study was to evaluate the impact of a low-cost and brief educational program on family physicians' diagnosis and treatment of depression.”
| | n analysis: 30 | | | | W: Once only
| | | | | | D: NR
| Intervention | Enhanced educational intervention program (small group info format), | Live, print | Academic detailing, discussion group, lecture, readings | Individuals | T: 1.25 | One time | 6 months | No | No
| | n analysis: 35 | | | | W: Once only
| | | | | | D: NR
Labelle, 2004^67^ | Intervention | GPs attending first OSCE and workshop and participating in OSCE 12 months later, | Live, print | Case-based learning, demonstration, discussion group, lecture, problem-based learning or team-based learning, role play, standardized patient | Individuals, practice setting/ teams | T: NR | Multiple time or repetitive | 12 months | NR | No | ”Improve the ability of participants to do the following: distinguish between asthma and chronic obstructive pulmonary disease, determine the severity of the asthma, list the different asthma control criteria, interpret respiratory function test results (spirometry), establish a treatment plan, prescribe a WAP for the patient; identify criteria for referral to a specialist.”
| | n assigned: 24, | | | | W: Once only
| | n analysis: 12 | | | | D: 12 months
| Intervention | GPs attending a 6 and 12 month OSCE, | Live | Case-based learning, role play, standardized patient | Individuals | T: NR | Multiple time or repetitive | 12 months | NR | No
| | n assigned: 16, | | | | W: Once only
| | n analysis: 13 | | | | D: 12 months
Lane, 1991^69^ | Intervention | Multiple CME interventions and low-cost mammography, | Live, print | ARS, clinical experiences, demonstration, discussion group, feedback, lecture, mentor/ preceptor, readings | NR | T: NR | Multiple time or repetitive | NR | Yes | No | To determine if a community-wide multi-method approach to CME can increase physicians' compliance with national guidelines for breast cancer screening.
| | n analysis: NR | | | | W: NR
| | | | | | D: NR
| Concurrent control | No CME intervention and no mammography cost intervention, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n analysis: NR | | | | W: NA
| | | | | | D: NA
| Intervention | Multiple CME interventions AND no cost intervention with mammography, | Live, print | ARS, clinical experiences, demonstration, discussion group, feedback, lecture, mentor/ preceptor, readings | NR | T: NR | Multiple time or repetitive | NR | Yes | No
| | n analysis: NR | | | | W: NR
| | | | | | D: NR
| Intervention | No CME intervention but free mammography, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n analysis: NR | | | | W: NA
| | | | | | D: NA
Lane, 2001^45^ | Intervention | High-need physicians, as judged by their responses to a questionnaire on the need for breast cancer screening, received either an in-office or a self-learning intervention, | Live | Lecture, standardized patient | Individuals | T: 1–3 | One time | 6 months | Yes | Yes | Broad educational goals were to improve physicians' knowledge of the necessity of regular breast exams and mammograms (breast cancer screening practices) for women over age 50.
| | n assigned: 201, | | | | W: Once only
| | n analysis: 128 | | | | D: 1 day
| Concurrent control | Control physicians were also designated as high-need and low-need, but neither group received any CME intervention materials, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 223, | | | | W: NA
| | n analysis: 154 | | | | D: NA
Leopold, 2005^80^ | Intervention | CD-ROM video demonstrating technique, | Computer-based off-line | Demonstration, readings | Individuals | T: NR | NA | NR | NR | Unclear | The overall goal of the educational intervention is to see if the CME could change the relationship between an individual's confidence and competence in his or her ability to perform a task.
| | n assigned: NR | | | | W: NA
| | | | | | D: NR
| Intervention | Hands-on instruction by a trained tutor, | Live | Demonstration, feedback, mentor/ preceptor, simulation (other than SP or role-play) | Individuals | T: 0.08–0.17 | One time | NR | NR | Unclear
| | n assigned: NR | | | | W: Once only
| | | | | | D: NR
| Intervention | Printed guide, | Print | Readings | Individuals | T: NR | NA | NR | NR | Unclear
| | n assigned: NR | | | | W: NA
| | | | | | D: NR
Levinson, 1993^138^ | Concurrent control | Control physicians not receiving CME, | NA | NA | NA | T: NA | NA | 1 month | NA | No | To improve physician patient communication skills, including; 1) more open-ended questions,; 2) more psychosocial discussion,; 3) more information-giving, and; 4) less talking and more listening.
| | n assigned: 15, | | | | W: NA
| | n analysis: 15 | | | | D: NA
| Intervention | Physicians attending a one time short CME program on communication skills, | Live | Case-based learning, lecture | Individuals | T: 4.5 hours | One time | 1 month | Yes | No
| | n assigned: 16, | | | | W: Once only
| | n analysis: 15 | | | | D: NR
Lewis, 1993^70^ | Intervention | Comparison, received only written information, | Print | Readings | NR | T: NR | One time | 3 months | NR | No | Improve physician comfort with treating AIDS patients and with obtaining sexual histories. Improve knowledge about nosocomial HIV transmission.
| | n assigned: 106 | | | | W: NR
| | | | | | D: NR
| Concurrent control | Control, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 93 | | | | W: NA
| | | | | | D: NA
| Intervention | Experimental, received live CME program on HIV and taking a sexual history, | Live, video | Discussion group, lecture | NR | T: NR | One time | 3 months | NR | No
| | n assigned: 54 | | | | W: Once only
| | | | | | D: 1 day
Lin, 1997^73^ | Intervention | Multifaceted educational intervention and collaborative treatment model, | Live, video, print | Academic detailing, feedback, lecture, readings, role play | Practice settings/ teams | T: NR | Multiple time or repetitive | 6 months | NR | Unclear | To determine if an extensive physician educational intervention that improved the primary care treatment of patients with major depression would have an enduring effect after its discontinuation.
| | n assigned: 134 pre-intervention/109 post-intervention, | | | | W: NR
| | n analysis: 83 pre-intervention/65 post-intervention | | | | D: 1 year
| Concurrent control | Control practices (usual care), | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: NR, | | | | W: NA
| | n analysis: NR | | | | D: NA
Lin, 2001^133^ | Intervention | Intervention group, | Live | Academic detailing, case-based learning, demonstration, discussion group, role play | Individuals, practice setting/ teams | T: NR | Multiple time or repetitive | 1 year | NR | Unclear | To assess the effect of physician training on management of depression. Use education on optimal management of depression to improve PCP diagnosis and pharmacotherapy practices of depression.
| | n analysis: 56 | | | | W: NR
| | | | | | D: 3 months
| Concurrent control | Usual care group, | Live, NA | NA | NA | T: NR | Multiple time or repetitive | 1 year | NR | Unclear
| | n analysis: 53 | | | | W: NA
| | | | | | D: NR
Lindsay-McIntyre, 1987^115^ | Concurrent control | Family physicians providing usual care, | NA | NA | NA | T: NA | NA | NA | NA | No | Motivating physicians; a) to understand their role in assisting with the cessation process and; b) to provide this service on a regular basis,; c) providing the knowledge and skills needed to increase physicians' effectiveness in helping patients stop smoking
| | n assigned: NR | | | | W: NA
| | | | | | D: NA
| Intervention | Family physicians with counseling training, nicotine gum, chart cue, intervention flowsheet, and patient self-help materials, | Live, video, print | Demonstration, lecture, point of care, standardized patient | Individuals | T: 3–4 hour training session | Training 1 time, cueing with each patient | 1 year | NR | No
| | n assigned: NR | | | | W: NR
| | | | | | D: 2 months
| Intervention | Family physicians with nicotine gum and chart cue, | Print | Point of care | Individuals | T: NR | Multiple time or repetitive | 1 year | NR | No
| | n assigned: NR | | | | W: NR
| | | | | | D: 2 months
Lockyer, 2002^64^ | Intervention | Introductory course (track 1) on Alzheimer's disease, | Live | Case-based learning, discussion group, lecture, role play | Individuals | T: 6.5 | One time | 3 months | Yes | No | To improve physicians' diagnosis and management of Alzheimer's disease and other dementias.
| | n analysis: NR | | | | W: Once only
| | | | | | D: 1 day
| Intervention | Advanced course (track 2) on Alzheimer's disease, | Live | Case-based learning, discussion group, lecture | Individuals | T: 6.5 | One time | 3 months | Yes | No
| | n analysis: NR | | | | W: Once only
| | | | | | D: 1 day
Maclure, 1998^96^ | Intervention | 1 hour teleconference participants, | Live, video | Lecture, teleconference | Individuals | T: NR | One time | 3 months | NR | No | To determine if a variety of educational interventions have an impact on prescribing patterns of calcium channel blockers and ACE inhibitor as first line antihypertensive therapy.
| | n assigned: 94 | | | | W: NR
| | | | | | D: NR
| Concurrent control | Matched control for the teleconference group, | NA | NA | NA | T: NA | NA | 3 months | NA | No
| | n assigned: 188 | | | | W: NA
| | | | | | D: NA
| Intervention | Small group workshops, | Live | Discussion group, lecture | Individuals | T: NR | NR | 3 months | NR | No
| | n assigned: 70 | | | | W: NR
| | | | | | D: NR
| Concurrent control | Matched control for the small group workshop group, | NA | NA | NA | T: NA | NA | 3 months | NA | No
| | n assigned: 140 | | | | W: NA
| | | | | | D: NA
| Intervention | Physicians receiving 2 newsletters, | Print | Readings | Individuals | T: NR | Multiple time or repetitive | 3 months | NR | No
| | n assigned: 258 | | | | W: NR
| | | | | | D: NR
| Concurrent control | Control group for newsletter, | NA | NA | NA | T: NA | NA | 3 months | NA | No
| | n assigned: 241 | | | | W: NA
| | | | | | D: NA
Macrae, 2004^85^ | Intervention | Intervention group participating in electronic “journal club” & receiving 8 packages, each consisting of 1 clinical and 1 methodological article along with questions designed to guide critical appraisal, | Print | Readings, listserv discussion group with moderator | Individuals | T: NR | Multiple time or repetitive | 6 weeks | Yes | No | ”The objective of this randomized controlled trial was to assess the effectiveness of an Internet-based journal club, which is based on adult learning theory and findings from the continuing education literature, in developing critical appraisal skills of surgeons in practice.”
| | n assigned: 44, | | | | W: NR
| | n analysis: 26 | | | | D: 8 months
| Concurrent control | Control group received only the 8 clinical articles, | Print | Readings | Individuals | T: NR | Multiple time or repetitive | 6 weeks | NR | No
| | n assigned: 37, | | | | W: NR
| | n analysis: 29 | | | | D: 8 months
Maiman, 1988^47^ | Intervention | 2 session didactics and printed materials, | Live, print | Discussion group, lecture, readings | Individuals | T: 5 hours | Multiple time or repetitive | 6 months | NR | No | Teaching pediatricians compliance-enhancing strategies.
| | n assigned: 33, | | | | W: NR
| | n analysis: 32 | | | | D: NR
| Concurrent control | No additional education, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 27, | | | | W: NA
| | n analysis: 24 | | | | D: NA
| Intervention | Mailed printed materials, | Print | Readings | Individuals | T: NR | One time | 6 months | NR | No
| | n assigned: 30, | | | | W: NR
| | n analysis: 27 | | | | D: NR
Mann, 1997^52^ | Intervention | Training workshop on cholesterol-lowering practices with FP, dietician, educational specialist, and internist, | Live, video, print | Case-based learning, demonstration, discussion group, readings, simulation (other than standardized patient or role-play) | Individuals | T: NR | Multiple time or repetitive | 15 months | NR | No | ”The primary care physician will demonstrate skill in the detection, management (including counseling and educational activities), referral and follow-up of his/her patients who are at increased risk of cardiovascular disease due to their level of serum cholesterol.”
| | n analysis: 17 | | | | W: NR
| | | | | | D: NR
| Concurrent control | No workshop or chart cues, | NA | NA | NA | T: NA | NR | 15 months | NR | NA
| | n analysis: 15 | | | | W: NA
| | | | | | D: NA
| Intervention | Training workshop plus chart cues cholesterol-lowering interventions for patients in their clinical practice, | Live, video, print, cue stickers on medical chart | Case-based learning, demonstration, discussion group, point of care, readings, simulation (other than standardized patient or role-play) | Individuals | T: NR | Multiple time or repetitive | 15 months | NR | No
| | n analysis: 19 | | | | W: NR
| | | | | | D: NR
Margolis, 2004^118^ | Concurrent control | Control, | NA | NA | NA | T: NA | NA | NA | No | NA | To improve the delivery of preventive care to children.
| | n analysis: 22 | | | | W: NA
| | | | | | D: NA
| Intervention | Plan-do-study-act process improvement, | Live, organized set of tools otherwise unspecified | Academic detailing, feedback, lecture, unspecified organized set of tools | Practice setting/ teams | T: NR | Multiple time or repetitive | 18 months | Yes | Yes
| | n analysis: 22 | | | | W: NR
| | | | | | D: 12 months
Maxwell, 1984^57^ | Concurrent control | Physicians matched by department chairman to be similar in type and length of practice to committee members, | NA | NA | NA | T: NA | NA | NR | NA | NA | To improve the knowledge and clinical performance of physicians in medical care evaluation committees
| | n assigned: NR | | | | W: NR
| | | | | | D: NA
| Intervention | Physician members of three evaluation committees at a hospital, | Live | Case-based learning, discussion group | Practice setting/ teams | T: NR | Multiple time or repetitive | NR | NR | Yes
| | n assigned: NR | | | | W: NR
| | | | | | D: 1 year
Mazmanian, 1998^24^ | Concurrent control | Received lecture only, | Live | Lecture | Individuals | T: 1 | One time | 45 days | NR | No | To see if receiving information about barriers to clinical change during CME activities results in a higher rate of actual change
| | n assigned: 13 medical schools (340 physicians), | | | | W: Once only
| | n analysis: 13 schools (153 physicians) | | | | D: 1 hour
| Intervention | Received lecture as well as information regarding barriers to changing practice, | Live | Lecture | Individuals | T: 1 | One time | 45 days | NR | No
| | n assigned: 12 medical schools (398 physicians), | | | | W: Once only
| | n analysis: 12 schools (146 physicians) | | | | D: 1 hour
Mazmanian, 2001^161^ | Concurrent control | This group's questionnaires included a line on which they could sign indicating their commitment to change practice behaviors, | Live | Discussion group, lecture | Individuals | T: NR | One time | 3 months | Yes | No | To determine the effect of signing a commitment to change practice form on actual practice change
| | n assigned: 55, | | | | W: Once only
| | n analysis: 43 | | | | D: 1 day
| Intervention | This group's questionnaires did not include a signature line, | Live | Discussion group, lecture | Individuals | T: NR | One time | 3 months | Yes | No
| | n assigned: 55, | | | | W: Once only
| | n analysis: 45 | | | | D: 1 day
McBride, 2000^144^ | Intervention | Consultation group: primary care practices receiving 1-day conference and HEART Kits to improve prevention care systems PLUS 3 consultation meetings and 2 reinforcement visits during 1 year, | Live, print | Academic detailing, discussion group, feedback, lecture, point of care, problem-based learning or team-based learning | Practice setting/ teams | T: NR | Multiple time or repetitive | 6 months | NR | Yes | To improve primary care practice systems for heart disease prevention services
| | n assigned: 11 practices | | | | W: NR
| | | | | | D: 1 year
| Intervention | Prevention coordinator group: primary care practices receiving 1-day conference and HEART Kits PLUS prevention coordinator working 4.5 hours per week to promote practice systems improvements for prevention care, | Live, print | Lecture, point of care, problem-based learning or team-based learning, patient education | Practice settings/ teams | T: NR | Multiple time or repetitive | 6 months | NR | Yes
| | n assigned: 11 practices | | | | W: NR
| | | | | | D: 1 year
| Concurrent control | Conference-only group: primary care practices receiving 1-day conference and HEART Kits to improve prevention care systems, | Live, print | Lecture, point of care | Practice settings/ teams | T: NR | One time | 18 months | NR | Yes
| | n assigned: 12 practices | | | | W: NR
| | | | | | D: 1 day
| Intervention | Combined intervention: primary care practices receiving 1-day conference, HEART Kits, 3 consultation meetings, 2 reinforcement visits, and a prevention coordinator, | Live, print | Academic detailing, discussion group, feedback, lecture, problem-based learning or team-based learning, patient education | Practice settings/ teams | T: NR | Multiple time or repetitive | 6 months | NR | Yes
| | n assigned: 11 practices | | | | W: NR
| | | | | | D: 1 year
McClellan, 2003^119^ | Intervention | Intervention physicians received material at baseline, 2, 4 and 6 months, | Video, print | Feedback, readings | Individuals | T: NR | Multiple time or repetitive | 1.5–2 years | NR | Yes | Determine if an intervention that includes claims-based feedback about patterns of HbA1c measurement results in more frequent monitoring of HbA1c in diabetic Medicare beneficiaries improve healthcare of Medicare beneficiaries regarding management and monitoring of diabetes mellitus
| | n assigned: 247, | | | | W: NR
| | n analysis: 236 | | | | D: 6 months
| Concurrent control | Comparison physicians received no materials. | NA | NA | Individuals | T: NA | NA | 1.5–2yrs | NR | Yes
| | n assigned: 230, | | | | W: NA
| | n analysis: 223 | | | | D: NA
McMahon, 1988^155^ | Concurrent control | Internists on another IM service in the hospital with a high LOS, | Live | Discussion group, lecture | Individuals | T: NR | One time | 16 months | NR | Yes | To reduce length of stay on services identified with high length of stay in one hospital. Educate admitting physicians about LOS performance; educate physicians about prison follow-up care and continuity of care.
| | n assigned: NR | | | | W: Once only
| | | | | | D: NR
| Intervention | Internists admitting to 3 hospital services with high LOS, | Live | Discussion group, feedback, lecture | Individuals | T: 1 hour | Multiple time or repetitive | 16 months | NA | Yes
| | n assigned: NR | | | | W: Once only
| | | | | | D: NA
| Concurrent control | Physicians on other units; received no intervention, | NA | NA | NA | T: NA | NA | 16 months | NA | NA
| | n assigned: NR | | | | W: NA
| | | | | | D: NA
| Intervention | Internists admitting to 4 services with high LOS, | Live | Discussion group, lecture | Individuals | T: NR | One time | 16 months | NR | Yes
| | n assigned: NR | | | | W: Once only
| | | | | | D: NR
Mehler, 2005^99^ | Intervention | Electronic detailing intervention (using facsimiles and emails), | Internet, not real time, print | Academic detailing, readings | Practice setting/ teams | T: NR | Multiple time or repetitive | 3 months | NR | Yes | The goal of the educational interventions was to better facilitate the integration of, and adherence to, diabetic lipid-lowering guidelines in clinical practice.
| | n assigned: 415, | | | | W: NR
| | n analysis: 415 | | | | D: NR
| Intervention | Direct detailing intervention (using face-to-face education sessions), | Live, print | Academic detailing, lecture | Practice settings/ teams | T: NR | Multiple time or repetitive | 3 months | NR | Yes
| | n assigned: 146 | | | | W: NR
| | | | | | D: NR
| Concurrent control | Control, | NA | NA | NA | T: NA | NA | 3 months | NA | NA
| | n assigned: 323 | | | | W: NA
| | | | | | D: NA
Meredith, 2000^51^ | Intervention | Physician education & QI therapy intervention (reduced copayments for use of practice psychotherapists), | Live, print | Lecture, readings | Practice settings/ teams | T: NR | NA | 12 months (18 months after implementation) | NR | Yes | To improve long-term clinician knowledge of depression treatment.
| | n assigned: 58 | | | | W: NA
| | | | | | D: 6 months
| Intervention | Physician education & QI meds intervention (improved resources for antidepressant medication management), | Live, print | Lecture, readings | Practice setting/ teams | T: NR | Multiple time or repetitive | 12 months (18 months after implementation) | NR | Yes
| | n assigned: 49 | | | | W: NA
| | | | | | D: 6 months
| Concurrent control | Usual care, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 53 | | | | W: NA
| | | | | | D: NA
Messina, 2002^156^ | Intervention | Physician CME & no patient training, | Live, print | Demonstration, readings, standardized patient | Individuals | T: NR | Multiple time or repetitive | 3 years | NR | Unclear | Evaluate an intervention including both patients and physicians in attempts to increase the use of mammography.
| | n assigned: 342, | | | | W: NA
| | n analysis: 154 | | | | D: NR
| Concurrent control | No training: control physicians, control patients, | NA | NA | NA | T: NA | NA | 3 years | NR | Unclear
| | n assigned: 489, | | | | W: NA
| | n analysis: 115 | | | | D: NA
| Intervention | Physician CME (nurse educator training + SP visit) & patients with BSTC, | Live, audio, print | Demonstration, readings, standardized patient, telephone counseling | Individuals | T: NR | Multiple time or repetitive | 3 years | NR | Unclear
| | n assigned: 335, | | | | W: NA
| | n analysis: 149 | | | | D: NR
| Concurrent control | No physician CME, & patient BSTC only, | Live, audio | Readings, telephone counseling | Individuals | T: NR | Multiple time or repetitive | 3 years | NR | Unclear
| | n assigned: 435, | | | | W: NA
| | n analysis: 92 | | | | D: NR
Moran, 1996^121^ | Intervention | Cases - in need of remedial CME as identified by the Manitoba College of Physicians, | Live | Case-based learning, discussion group | Individuals | T: 30 | Multiple time or repetitive | 18 months | NR | No | To determine if problem-based, remedial, supportive CME program can cause sustained improvement in practice habits
| | n assigned: 5 | | | | W: NR
| | | | | | D: 10 days
| Concurrent control | Controls, | Live | Case-based learning, discussion group | Individuals | T: 30 | Multiple time or repetitive | NR | NR | No
| | n assigned: 10 | | | | W: NR
| | | | | | D: 10 days
Mukohara, 2005^13^ | Concurrent control | Received health-related news from email from Yahoo! Health, | Computer-based off-line | Readings | Individuals | T: NR | Multiple time or repetitive | NR | NR | No | The overall goal of the educational intervention was to see if delivery services such as the WBJC could influence doctors' use of evidence in practice.
| | n assigned: 53, | | | | W: Once only
| | n analysis: 45 | | | | D: NR
| Intervention | Received WBJC readings which had summaries of 1 or 2 articles from medical/health journals, | Computer-based off-line | Readings | Individuals | T: NR | Multiple time or repetitive | NR | NR | No
| | n assigned: 54, | | | | W: Once only
| | n analysis: 51 | | | | D: NR
Myers, 2004^148^ | Concurrent control | Control group, | NA | Readings | Individuals | T: NR | NA | 6 years | NR | Yes | ”The CDE Study, was designed to evaluate the impact of a physician intervention (i.e., CDE reminder-feedback and educational outreach) on CDE recommendation and performance rates in primary care practices.
| | n analysis: 198 practices | | | | W: NA
| | | | | | D: NA
| Intervention | Physician-oriented reminder-feedback and educational outreach intervention, | Live, audio, print | Academic detailing, feedback, lecture, readings | Individuals | T: NR | Multiple time or repetitive | 6 years | NR | Yes
| | n analysis: 120 practices | | | | W: NA
| | | | | | D: 5 years
Norris, 2000^81^ | Concurrent control | No training on physical activity counseling, | NA | NA | NA | T: NA | NA | NA | NA | NA | To increase the physical activity levels of patients in a health maintenance organization by teaching a counseling program to their primary care providers
| | n assigned: 17 MDs, 463 patients, | | | | W: NA
| | n analysis: 460 patients | | | | D: NA
| Intervention | 1-hour workshop on Physician-Based Assessment and Counseling for Exercise, a behavior-based tool for PCPs counseling healthy adults, | Live, print, follow-up phone calls about protocol | Lecture, point of care, opinion-leader from clinic teaching | Practice setting/ teams | T: 1 | Multiple time or repetitive | 6 months | NR | No
| | n assigned: 15 MDs, 384 patients, | | | | W: NR
| | n analysis: 362 patients | | | | D: NR
Ockene, 1996^124^ | Intervention | Lipid intervention physician training, | Live, video | Feedback, lecture, role play, standardized patient | Individuals | T: 3 | 2 types of training sessions, each provided once | Evaluation was conducted over a 2 year time span | NR | No | To help physicians develop nutrition counseling skills.
| | n assigned: 17, | | | | W: 1 day/week
| | n analysis: 115 | | | | D: 2 weeks
| Concurrent control | Usual care, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 14, | | | | W: NA
| | n analysis: 92 | | | | D: NA
| Intervention | Lipid intervention physician training plus practice management, | Live, video | Feedback, lecture, role play, standardized patient | Individuals, practice settings/ teams | T: 3 | 2 types of training sessions, each provided once | Evaluation was conducted over a 2 year time span | NR | Yes
| | n assigned: 14, | | | | W: 1 day/week
| | n analysis: 118 | | | | D: 2 weeks
Ozer, 2005^104^ | Concurrent control | Comparison group, | NA | NA | NA | T: NA | NA | NA | NA | NA | The goal of this intervention was to increase clinicians' screening and brief counseling of adolescents in the targeted health risk areas of tobacco, alcohol and drug use, sexual behavior, seatbelt use, and helmet use.
| | n assigned: 44, | | | | W: NA
| | n analysis: 37 | | | | D: NA
| Intervention | Intervention group, | Live, print | Discussion group, lecture, role play, screening and charting tools | Practice setting/ teams | T: 8 | One time | 8 months | NR | Yes
| | n assigned: 42, | | | | W: Once only
| | n analysis: 39 | | | | D: NR
Pazirandeh, 2002^128^ | Intervention | Intervention group receiving didactic lectures on the results of screening and the effect of prudent management on osteoporosis outcome, | Live, print | Lecture, readings, Q & A period | Individuals | T: NR | One time | 6 months | No | Unclear | ”To test the impact of focused patient education as well as didactic lecture on physician behavior and patient care outcome, we used focused patient education as a tool to elicit change in physician behavior as it relates to the management of osteoporosis.”
| | n analysis: 53 | | | | W: Once only
| | | | | | D: NR
| Concurrent control | Control group receiving no intervention, | NA | NA | Individuals | T: NA | NA | 6 months | No | Unclear
| | n analysis: 81 | | | | W: NA
| | | | | | D: NR
Pereles, 1996^163^ | Intervention | Wrote commitment to change after CME course, | Live | NR | Individuals | T: NR | NR | 3 months | NR | Unclear | Goals of the educational intervention not stated but the study is not evaluating the course but the impact of “written commitment to change” after the course on behavior
| | n assigned: 7 | | | | W: NR
| | | | | | D: NR
| Concurrent control | CME course only, | Live | NR | Individuals | T: NR | NR | 3 months | NR | Unclear
| | n assigned: 9 | | | | W: NR
| | | | | | D: NR
Perera, 19836^107^ | Intervention | Primary care physicians enrolled in a preceptorship for sigmoidoscopy training, 2nd training, | Live | Clinical experiences, demonstration | Individuals | T: 8 | One time | 3 months | Yes | No | ”To increase the rate of sigmoidoscopy by physicians in a health maintenance organization”
| | n assigned: 13 | | | | W: 2 days/week
| | | | | | D: 2 days
| Concurrent control | Primary care physicians who did not sign up for sigmoidoscopy training, | NA | NA | NA | W: NA | NA | NA | NA | NA
| | n assigned: 74
| Intervention | Primary care physicians enrolled in a preceptorship for sigmoidoscopy training, 1st training, | Live | Clinical experiences, demonstration | Individuals | T: 8 | One time | 7–10 months | Yes | No
| | n assigned: 13 | | | | W: 2 days/week
| | | | | | D: 2 days
Pimlott, 2003^143^ | Concurrent control | Control group receiving mailed packages of feedback education materials on antihypertensives, | Print | Feedback, readings | Individuals | T: NR | Multiple time or repetitive | 6 months | NR | Unclear | To improve prescribing of benzodiazepine hypnotic sedatives to the elderly
| | n analysis: 206 | | | | W: NA
| | | | | | D: 6 months
| Intervention | Intervention group receiving mailed packages of feedback about participants' prescribing (of benzodiazepines) and evidence-based education materials, | Print | Feedback, readings | Individuals | T: NR | Multiple time or repetitive | 6 months | NR | Unclear
| | n analysis: 168 | | | | W: NA
| | | | | | D: 6 months
Pinto, 1998^74^ | Concurrent control | Physicians and patients were given a manual about exercise counseling but no formal training or instruction, | Print | Readings | Individuals | T: NR | Given materials to read-exposure up to the physicians | 8 months | NR | No | Assist physicians to address barriers to activity counseling: lack of counseling skills and lack of time. To determine if an educational intervention can have an impact on physician counseling on exercise
| | n assigned: 17, | | | | W: NR
| | n analysis: 15 | | | | D: NR
| Intervention | Physicians were given the manual as well as an hour training session and follow-up reminders. Patients were also given reminders about exercise, | Live, print | Discussion group, readings, role play | Individuals | T: 1 | One time | 8 months | NR | No
| | n assigned: 17, | | | | W: Once only
| | n analysis: 12 | | | | D: 1 hour
Premi J, 1993^38^ | Concurrent control | Review articles only on the management of chest pain, | Print | Readings | Individuals | T: NR | NR | NR | NR | No | To improve physicians' knowledge about the diagnosis and management of chest pain from different etiologies using a video-workbook educational program.
| | n assigned: 10, | | | | W: NR
| | n analysis: 10 | | | | D: NR
| Concurrent control | No education on the management of chest pain, | NA | NA | NA | T: NA | NA | NA | NR | NA
| | n assigned: 10, | | | | W: NA
| | n analysis: 7 | | | | D: NA
| Intervention | educational workbook (video + questions/ answers) and review articles on the management of chest pain, | Video, print | Case-based learning, readings | Individuals | T: NR | NR | NR | NR | No
| | n assigned: 10, | | | | W: NR
| | n analysis: 4 | | | | D: NR
| Intervention | Educational workbook (video + questions/ answers) on the management of chest pain, | Video, print | Case-based learning, readings | Individuals | T: NR | NR | NR | NR | No
| | n assigned: 10, | | | | W: NR
| | n analysis: 9 | | | | D: NR
Premi, 1994^41^ | Concurrent control | Family and general practice MDs waitlisted for CME and receiving no training, | NA | NA | NA | T: NA | NA | NA | NA | NA | To effectively disseminate new information while simultaneously providing more opportunities for individual learning
| | n assigned: 52, | | | | W: NA
| | n analysis: 46 | | | | D: NA
| Intervention | Family and general practice MDs who participated in twice monthly small group community CME about hormone replacement, asthma, congestive heart failure, otitis media, and other topics, | Live, print | Case-based learning, discussion group, problem-based learning or team-based learning, readings | Individuals | T: 24 | Multiple time or repetitive | 3 months | Yes | No
| | n assigned: 100, | | | | D: 1 year (for this evaluation)
| | n analysis: 76
Rabin, 1998^97^ | Intervention | Educational materials alone, | Print | Readings | Individuals | T: NR | NR | 3 months | NR | No | To determine if educational materials alone or educational material plus simulated patient instructors were more effective than no intervention at changing physicians practice concerning history-taking and counseling related to sexual behaviors and sexually transmitted disease
| | n assigned: NR | | | | W: NR
| | | | | | D: NR
| Concurrent control | No intervention, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: NR | | | | W: NA
| | | | | | D: NA
| Intervention | Educational materials and simulated patient instructor, | Live, print | Readings, standardized patient | Individuals | T: NR | Multiple time or repetitive | 3 months | NR | No
| | n assigned: NR | | | | W: NR
| | | | | | D: NR
Rahme, 2005^100^ | Intervention | Workshop and decision tree group, | Live, print | Discussion group, lecture, readings | Individuals | T: 1.5 | One time | 5 months | Yes | Yes | The overall goal of the educational intervention was to increase general practitioners' ability to select the proper pharmacological treatment for patients with osteoarthritis.
| | n analysis: 84 | | | | W: Once only
| | | | | | D: NA
| Concurrent control | Control group, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n analysis: 82 | | | | W: NA
| | | | | | D: NA
| Intervention | Decision tree group only, | Print | Readings | Individuals | T: NA | NA | 5 months | Yes | Yes
| | n analysis: 54 | | | | W: NA
| | | | | | D: NA
| Intervention | Workshop group only, | Live | Discussion group, lecture | Individuals | T: 1.5 | One time | 5 months | Yes | Yes
| | n analysis: 29 | | | | W: Once only
| | | | | | D: NA
Ray, 1985^20^ | Concurrent control | No intervention about prescribing behavior, | NA | NA | NA | T: NA | NA | NA | NA | NA | To generate sustained improvement in appropriate and cost-effective antibiotic prescribing behaviors
| | n assigned: 98+150, | | | | W: NA
| | n analysis: 248 | | | | D: NA
| Intervention | Drug-educator visit about contraindicated antibiotics or oral cephalosporins, | Live | Academic detailing | Individuals | T: NR | One time | 2 years | NR | No
| | n assigned: 71+76, | | | | W: Once only
| | n analysis: 147 | | | | D: 1 visit
| Intervention | Physicians receiving a physician-counselor visit about contraindicated antibiotics or oral cephalosporins, | Live | Academic detailing | Individuals | T: 0.25 | One time | 2 years | NR | No
| | n assigned: 44+45, | | | | W: Once only
| | n analysis: 89 | | | | D: 1 visit
Ray, 2001^109^ | Intervention | visit by a physician-educator on the reasons to switch to drugs other than NSAIDS, as well as chart reminder stickers, | Live, print | Academic detailing, readings, chart reminders | Individuals | T: NR | Multiple time or repetitive | 1 year | NR | Yes | Evaluate a physician education program that communicated guidelines for management of osteoarthitis in elderly patients that emphasized avoidance of NSAIDs when possible.
| | n assigned: 110, | | | | W: NR
| | n analysis: 103 | | | | D: NR
| Concurrent control | No educational intervention on slowing NSAID prescribing, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 110, | | | | W: NA
| | n analysis: 106 | | | | D: NA
Rodney, 1986^77^ | Intervention | One of 3 small-group courses (12–45 per group), | Live, video | Demonstration, lecture, simulation (other than standardized patient or role-play) | Individuals | T: 4 | One time | 12–18 months | Yes | No | 1) improved physician compliance with American Cancer Society colorectal cancer screening recommendations;; 2) demonstration of safety and efficacy of the flexible sigmoidoscope in the hands of the office-based generalist;; 3) promotion of learning through well supervised workshops in sigmoidoscopic techniques
| | n assigned: 82, | | | | W: Once only
| | n analysis: 61 | | | | D: 1 day
| Intervention | Large group course, | Live, video | Demonstration, lecture, simulation (other than standardized patient or role-play) | Individuals | T: 15 | One time | 12–18 months | Yes | No
| | n assigned: 114, | | | | W: 4 days/week
| | n analysis: 94 | | | | D: 4 days
| Concurrent control | Randomly contacted physicians, of whom 22% had received other CME on flexible sigmoidoscopy, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 97, | | | | W: NA
| | n analysis: 97 | | | | D: NA
Rosenthal, 2005^59^ | Concurrent control | Practices that receive only 1 of the 4-step intervention, | Review of data | Review of practice's data | Practice settings/ teams | T: NR | One time | NR | NR | Yes | The overall goal of the intervention was to improve performance of the practice settings so as to improve parents' reports of physicians' actions and parents' knowledge and behavior.
| | n analysis: 22 | | | | W: NR
| | | | | | D: NR
| Intervention | Practices that receive the full 4-step intervention, | Live, handheld, review of data | Lecture, readings, review of practice's data | Practice setting/ teams | T: NR | Multiple time or repetitive | NR | NR | Yes
| | n analysis: 22 | | | | W: NR
| | | | | | D: NR
Rost, 2001^22^ | Concurrent control | Primary care practices without a mental health professional on faculty, | NA | NA | NA | T: NA | NA | NA | NA | NA | To determine whether redefining primary care team roles would improve outcomes for patients beginning a new treatment episode for major depression.
| | n assigned: 6 practices (12 doctors), | | | | W: NA
| | n analysis: 6 practices (12 doctors) | | | | D: NA
| Intervention | Primary care practices without a mental health professional on faculty, | By phone | Conference calls | Practice setting/ teams | T: 6 | Multiple time or repetitive | 6 months | NR | Yes
| | n assigned: 6 practices (12 doctors), | | | | W: NR
| | n analysis: 6 practices (12 doctors) | | | | D: 2 months
Roter, 1995^84^ | Intervention | Emotion-handling skills education, | Live | Discussion group, lecture, role play, standardized patient | Individuals | T: 8 | Multiple time or repetitive | Immediate - 6 months | NR | No | To teach physicians communication skills so they will be more successful in distinguishing distressed from non-distressed patients, will be more likely to identify psychological problems of these patients, and will more often manage psychosocial problems.
| | n assigned: 22 | | | | W: 1 day/week
| | | | | | D: 2 weeks
| Concurrent control | No education control, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 24 | | | | W: NA
| | | | | | D: NA
| Intervention | Problem defining skills education, | Live | Discussion group, lecture, role play, standardized patient | Individuals | T: 8 | Multiple time or repetitive | Immediate - 6 months | NR | No
| | n assigned: 23 | | | | W: 1 day/week
| | | | | | D: 2 weeks
Schectman, 1991^139^ | Intervention | Received memo on the use of allergy trial packs, | Print | Readings, directed physicians to use allergy trial packs | Practice setting/ teams | T: NR | NR | NR | NR | Yes | To reduce antihistamine prescribing costs in an HMO
| | n assigned: 20 | | | | W: NR
| | | | | | D: NR
| Concurrent control | Did not receive memo, | NA | NA | Practice settings/ teams | T: NA | NA | NA | NA | NA
| | n assigned: 190 | | | | W: NA
| | | | | | D: NA
| Concurrent control | Did not receive memo, | NA | NA | Practice settings/ teams | T: NA | NA | NA | NA | NA
| | n assigned: 13 | | | | W: NA
| | | | | | D: NA
Schectman, 1995^130^ | Concurrent control | Private FFS, received only memo, | Print | Readings | NR | T: NR | Multiple time or repetitive | 6 months | NR | Yes | To study the effect of a simple intervention using feedback on prescribing habits on network and group model HMO physician prescribing practices (H2 inhibitors).
| | n assigned: 33 (the study only provides the total in the private practice group) | | | | W: NR
| | | | | | D: several weeks
| Intervention | Private FFS, received memo and feedback on H2 blocker use, | Print | Feedback, readings | NR | T: NR | Multiple time or repetitive | 6 months | NR | Yes
| | n assigned: 33 (the study only provides the total in the private practice group) | | | | W: NR
| | | | | | D: several weeks
| Concurrent control | Group model-academic, received only memo, | Print | Readings | NR | T: NR | Multiple time or repetitive | 6 months | NR | Yes
| | n assigned: 21 (the study only provides the total in academic group) | | | | W: NR
| | | | | | D: several weeks
| Intervention | Group model-academic, received memo and feedback on H2 blocker use, | Print | Feedback, readings | NR | T: NR | Multiple time or repetitive | 6 months | NR | Yes
| | n assigned: 21 (the study only provides the total in the academic group) | | | | W: NR
| | | | | | D: several weeks
| Intervention | Group model-nonacademic, received memo and feedback on H2 blocker use, | Print | Feedback, readings | NR | T: NR | Multiple time or repetitive | 6 months | NR | Yes
| | n assigned: 9 (the study only provides the total in the nonacademic group) | | | | W: NR
| | | | | | D: several weeks
| Concurrent control | Group model, nonacademic and received only memo, | Print | Readings | NR | T: NR | Multiple time or repetitive | 6 months | NR | Yes
| | n assigned: 9 (the study only provides the total in the nonacademic group) | | | | W: NR
| | | | | | D: several weeks
Schectman, 1996^16^ | Intervention | All providers at the largest HMO site receiving memo about anti-histamine use, | Print, samples of first generation anithistamines to use with patients | Readings | Practice setting/ teams | T: NR | One time | 6 months | No | Yes | To reduce antihistamine prescribing costs in an HMO.
| | n assigned: 27 | | | | W: NR
| | | | | | D: 1 month
| Concurrent control | Providers in 4 control HMO sites, | NA | NA | NA | T: NA | NA | 6 months | NA | NA
| | n assigned: 14 | | | | W: NA
| | | | | | D: NA
Schectman, 2003^108^ | Concurrent control | No clinician intervention, | Video, print | NA | Individuals, practice settings/ teams | T: NR | NA | 1 year | NR | Unclear | ”to investigate the effect of physician education and individual performance feedback with or without patient educational materials on adherence to a clinical practice guideline for the care of acute low back pain.”
| | n analysis: 56 | | | | W: NA
| | | | | | D: 1 year
| Intervention | Clinical practice guideline, | Live, video, print | Lecture, readings | Individuals, practice setting/ teams | T: NR | Multiple time or repetitive | 1 year | NR | Unclear
| | n analysis: 50 | | | | W: NA
| | | | | | D: 1 year
Schroy, 1999^82^ | Concurrent control | Comparison sites, | NA | NA | NA | T: 1 | NA | 1 year | NR | Yes | To assess the impact of “academic detailing” in the form of an outreach educational seminar combined with implementation of on-site gastroenterologists on provider compliance.
| | n assigned: 5 comparison sites | | | | W: NA
| | | | | | D: NA
| Intervention | Academic detailing intervention sites, | Live | Academic detailing, discussion group, lecture | Individuals, practice setting/ teams | T: 1 | One time | 1 year | NR | Yes
| | n assigned: 4 intervention sites | | | | W: Once only
| | | | | | D: NR
Schwartzberg, 1997^98^ | Intervention | Attended seminar on homecare and given written materials on the topic, | Live, print | Case-based learning, lecture, readings | Individuals | T: NR | One time | 3 months | NR | No | To determine if a seminar on home care of geriatric patients had an impact on the behaviors and attitudes of physicians attending the session
| | n assigned: 355, | | | | D: half day
| | n analysis: 131
| Concurrent control | No seminar attended, | NA | NA | NA | T: NA | NA | NA | NA | No
| | n assigned: 249, | | | | W: NA
| | n analysis: 204 | | | | D: NA
Sharif, 2002^94^ | Concurrent control | Pediatricians from 2 inner-city pediatric clinics in the same academic medical center who did not attend workshop, | NA | NA | NA | T: NA | NA | NA | NA | NA | To train pediatricians in smoking cessation counseling.
| | n assigned: 9 | | | | W: NA
| | | | | | D: NA
| Intervention | Pediatricians from 2 inner-city pediatric clinics in the same academic medical center who attended workshop, | Live | Lecture, role play | Individuals | T: NR | One time | 3 weeks | NR | No
| | n assigned: 6 | | | | W: Once only
| | | | | | D: 1 day
Short, 2006^50^ | Concurrent control | No CME, | NA | | NA | T: NA | NA | NA | NA | NA | The goal of the educational intervention was to improve the knowledge, attitudes, beliefs, and behavior scores in physicians so as to demonstrate improved dealings with issues regarding intimate partner violence.
| | n assigned: 37, | | | | W: NA
| | n analysis: 29 | | | | D: NA
| Intervention | Online CME program, | Internet, not real time | Lecture, problem-based learning or team-based learning, readings, multiple media, interactivity | Individuals | T: NR | Multiple time or repetitive | 12 months | Yes | Unclear
| | n assigned: 44, | | | | W: NR
| | n analysis: 23 | | | | D: 4 hours minimum and up to 16
Sibley, 1982^136^ | Concurrent control | No education, | NA | NA | NA | T: NA | NA | NA | NA | NA | To improve the quality of clinical care and to determine whether continuing medical education affects the quality of clinical care
| | n assigned: 8 | | | | W: NA
| | | | | | D: NA
| Intervention | 18 continuing-education packages, | Audio, print | Case-based learning, lecture, readings | Individuals | T: 3–4 (median) | Multiple time or repetitive | 18 months | NR | No
| | n assigned: 8 | | | | W: NR
| | | | | | D: not clear but seems to be available for an 18 month window
Slotnick, 1993^17^ | Intervention | Education about a newer drug (Mazicon) through enhanced advertising with a “clinical challenge” scenario, | Print | Readings | Individuals | T: NR | One time | Immediate | NR | No | To see if important ideas in prescribing information could be made more accessible to doctors, using an educational approach based on adult learning theory
| | n assigned: 10 | | | | W: Once only
| | | | | | D: 1 session
| Intervention | Education about a newer drug (Mazicon) through enhanced advertising with a “clinical challenge” scenario and an introduction on how to use the “clinical challenge”, | Print | Readings | Individuals | T: NR | One time | Immediate | NR | No
| | n assigned: 11 | | | | W: Once only
| | | | | | D: 1 session
| Intervention | Education about an older drug (Bumex) through enhanced advertising with a “clinical challenge” scenario and an introduction on how to use the “clinical challenge”, | Print | Readings | Individuals | W: Once only | One time | Immediate | NR | No
| | n assigned: 9 | | | | D: 1 session
| Intervention | Education about a newer drug (Mazicon) through conventional advertising, | Print | Readings | Individuals | T: NR | One time | Immediate | NR | No
| | n assigned: 11 | | | | W: Once only
| | | | | | D: 1 session
| Intervention | Education about an older drug (Bumex) through enhanced advertising with a “clinical challenge” scenario, | Print | Readings | Individuals | T: NR | One time | Immediate | NR | No
| | n assigned: 8 | | | | W: Once only
| | | | | | D: 1 session
| Intervention | Education about an older drug (Bumex) through conventional advertising, | Print | Readings | Individuals | T: NR | One time | Immediate | NR | No
| | n assigned: 12 | | | | W: Once only
| | | | | | D: 1 session
Socolar, 1998^134^ | Concurrent control | No formal feedback on charting, | NA | NA | Individuals | T: NA | NA | 1 year | NR | No | The goal of the current study was to determine whether chart audit with written feedback improves the chart documentation and knowledge of physicians doing evaluations for child sexual abuse and to learn what other factors are associated with better physician chart documentation and knowledge.
| | n assigned: 75, | | | | W: NA
| | n analysis: 45 | | | | D: NA
| | Received feedback on documentation of child abuse cases, | Print | Feedback, readings | Individuals | T: NR | Multiple time or repetitive | 1 year | NR | No
| | n assigned: 72, | | | | W: NR
| | n analysis: 42 | | | | D: 1 year
Solomon, 2004^127^ | Intervention | Intervention group: 3 part intervention for GIOP, | Live, print | Discussion group, lecture, readings | Individuals | T: NR | Multiple time or repetitive | 6 months | NR | No | ”The long-range goal of our work is improving management of GIOP.”
| | n analysis: 10 | | | | W: NR
| | | | | | D: 6 weeks
| Concurrent control | Control arm, | NA | NA | NA | T: NA | NA | 6 months | NA | No
| | n analysis: 11 | | | | W: NA
| | | | | | D: NA
Soumerai, 1987^105^ | Concurrent control | No intervention, | NA | NA | NA | T: NA | NA | 9 months | NA | Unclear | Reduce inappropriate prescribing of three target drugs by Medicaid physicians.
| | n assigned: 162, | | | | W: NA
| | n analysis: 54–70 | | | | D: NA
| Intervention | Academic detailing and printed materials, | Live, print | Academic detailing, readings, brochures | Individuals | T: 33 minutes | Multiple time or repetitive | 9 months | NR | Unclear
| | n assigned: 141, | | | | W: 1 day/week
| | n analysis: 69–75 | | | | D: 6 months
| Intervention | Print only educational intervention, | Print | Readings, brochures | Individuals | T: NR | Multiple time or repetitive | 9 months | NR | Unclear
| | n assigned: 132 | | | | W: NR
| | | | | | D: NR
Stein, 2001^95^ | Concurrent control | Not counseled to reduce NSAID use, | NA | NA | NA | T: NA | NA | NA | NA | NA | To determine the effects of an educational program on NSAID use and clinical outcomes in nursing homes.
| | n assigned: 10 homes (77 patients), | | | | W: NA
| | n analysis: 10 homes (71 patients) | | | | D: NA
| Intervention | Education and instructions on how to reduce the use of NSAIDS among residents over 65, | Live, handheld, by phone | Readings, study physician visit, algorithm | Practice setting/ teams | T: NR | Multiple time or repetitive | 3 months | NR | Yes
| | n assigned: 10 homes (81 patients), | | | | W: NR
| | n analysis: 10 homes (76 patients) | | | | D: NR
Stewart, 2005^43^ | Intervention | Intervention group receiving case-based on-line learning modules, | Internet, not real time | Case-based learning, discussion group, readings | Individuals | T: NR | Multiple time or repetitive | 6 months | NR | Yes | The overall goal of the intervention was to increase knowledge, quality of practice, and targeted behaviors compared to family physicians randomized to a wait-listed control group.
| | n assigned: 27 | | | | W: NA
| | | | | | D: 4 weeks
| Concurrent control | Control group, | NA | | NA | T: NA | NA | NA | NA | NA
| | n assigned: 31 | | | | W: NA
| | | | | | D: NA
Stross, 1985^116^ | Concurrent control | Received no intervention, | NA | NA | NA | T: NA | NA | NA | NA | NA | To improve the community hospital management of osteoarthritis through educationally influential physician peers.
| | n assigned: 3 communities (>15 primary care physicians each) | | | | W: NA
| | | | | | D: NA
| Intervention | Educationally influential physicians received training about osteoarthritis management, | Live, print, “audiovisual materials” | Feedback, readings, use of “educationally influential” physician | Practice setting/ teams | T: NR | Multiple time or repetitive | 1 year | NR | No
| | n assigned: 3 communities (>15 primary care physicians each) | | | | W: NR
| | | | | | D: NR
Terry, 1981^49^ | Concurrent control | Education on other pulmonary topics, | Audio, print | Case-based learning, lecture, readings | Individuals | T: 4 | Multiple time or repetitive | 6 months | Yes | No | To improve the care of patients with chronic bronchitis and emphysema
| | n assigned: 6 | | | | W: NR
| | | | | | D: 9 months
| Intervention | Group meetings about educational needs and 2 audiovisual programs about management and patient counseling, | Live, audio, print | Case-based learning, discussion group, lecture, readings | Individuals | T: NR | Multiple time or repetitive | 6 months | Yes | No
| | n assigned: 10 | | | | W: NR
| | | | | | D: 18 months
| Intervention | Group meetings about educational needs, 2 audiovisual programs about management and patient counseling and feedback on questionnaire performance, | Live, audio, print | Case-based learning, discussion group, feedback, lecture, readings | Individuals | T: NR | Multiple time or repetitive | 6 months | Yes | No
| | n assigned: 7 | | | | W: NR
| | | | | | D: 18 months
| Intervention | Two audiovisual programs about management and patient counseling, | Live, audio, print | Case-based learning, lecture, readings | Individuals | T: 4 | Multiple time or repetitive | 6 months | Yes | No
| | n assigned: 12 | | | | W: NR
| | | | | | D: 9 months
| Intervention | Two audiovisual programs about management and patient counseling and feedback on questionnaire performance, | Audio, print | Case-based learning, feedback, lecture, readings | Individuals | T: NR | Multiple time or repetitive | 6 months | Yes | No
| | n assigned: 9 | | | | W: NR
| | | | | | D: 9 months
Thom, 2000^129^ | Intervention | CME on patient trust, | Live, video | Demonstration, discussion group, lecture, role play | Individuals | T: 7 | One time | 6 months | NR | Unclear | To modify physician behaviors (as identified by patients in a previous study) important to establishing patient trust through a short training program to increase patient trust.
| | n assigned: 10 | | | | W: Once only
| | | | | | D: NR
| Concurrent control | No CME, | NA | NA | Individuals | T: NA | NA | 6 months | NR | Unclear
| | n assigned: 10 | | | | W: NA
| | | | | | D: NA
Tziraki, 2000^141^ | Intervention | Received the National Cancer Institute training manual on nutrition counseling and systems change, | Print | Readings | Practice settings/ teams | T: NR | One time | 4–6 months | NR | Yes | To assist primary care physicians in improving their practice behaviors related to nutrition and cancer prevention
| | n assigned: 256, | | | | W: NA
| | n analysis: 205 | | | | D: NA
| Concurrent control | Received no training on nutrition counseling and systems change, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 255, | | | | W: NA
| | n analysis: 222
| Intervention | Received a 3-hour training on nutrition counseling and systems change to support nutrition counseling, | Live, print | Discussion group, lecture, problem-based learning or team-based learning, role play | Practice setting/ teams | T: 3 | One time | 4–6 months | NR | Yes
| | n assigned: 244, | | | | W: Once only
| | n analysis: 191 | | | | D: NA
Wells, 2000^151^ | Concurrent control | Usual care, including AHRQ depression practice guidelines, | NA | NA | NA | T: NA | NA | NA | NA | NA | To improve quality of care, health outcomes, and employment in patients with depression managed in the primary care setting
| | n assigned: 16 clinics, 443 patients, | | | | W: NA
| | n analysis: 16 clinics, 374 patients | | | | D: NA
| Intervention | Quality improvement interventions with either medication adherence support or cognitive behavioral therapy; QI included institutional support, training of local leaders, 2-day MD workshop, manuals, monthly lectures, academic detailing, audit with feedback, 1-day staff workshop, and support materials, | Live, print | Academic detailing, discussion group, feedback, lecture, point of care, readings | Practice setting/ teams | T: NR | Multiple time or repetitive | NR | NR | Yes
| | n assigned: 30 clinics, 913 patients, | | | | W: NR
| | n analysis: 30 clinics, 752 patients | | | | D: NR
White, 1985^48^ | Intervention | Generalists receiving unitopic (cardiology) university-based CME program, | Live | NR | Individuals | T: NR | One time | 6 months | NR | No | To improve in hospital treatment of acute myocardial infarction by generalist physicians.
| | n analysis: 31 | | | | W: 4 days/week
| | | | | | D: 4 days
| Intervention | Generalists receiving a multitopic university-based CME, | Live | NR | Individuals | T: NR | One time | 6 months | NR | No
| | n analysis: 73 | | | | W: 4 days/week
| | | | | | D: 4 days
| Concurrent control | Generalists in communities receiving no training on myocardial infarction, | Live, NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 40 MDs (4 communities), | | | | W: NA
| | n analysis: 40 MDs (4 communities) | | | | D: NA
| Intervention | Generalists in communities receiving training on management of myocardial infarction, | Live | Case-based learning, discussion group, lecture | Individuals | T: 3.5 | One time | 6 months | | No
| | n assigned: 63 MDs (8 communities), | | | | W: Once only
| | n analysis: 63 MDs (8 communities) | | | | D: 3.5 hours
White, 2004^63^ | Intervention | Small-group problem-based learning (PBL) sessions, | Live | Case-based learning, discussion group | Individuals | T: 1 | One time | 3 months | NR | No | The major objective for both sessions was to provide an update for primary care physicians for the management of asthma in an ambulatory setting.
| | n assigned: 23, | | | | W: Once only
| | n analysis: 23 | | | | D: NA
| Concurrent control | Didactic lecture sessions, | Live | Case-based learning, discussion group, lecture | Individuals | T: 1 | One time | 3 months | NR | No
| | n assigned: 29, | | | | W: Once only
| | n analysis: 29 | | | | D: NA
Wilson, 1988^154^ | Concurrent control | Family physicians who received nicotine gum, but no training, | NR | NR | Individuals | T: NA | MDs were told to offer nicotine gum | NA | NA | NA | To teach physicians a smoking cessation counseling protocol involving “simple advice, setting a date for quitting, the offer of nicotine gum with instructions for proper use, a contract for quitting, and the offer of continuing support”
| | n assigned: 27, | | | | W: NA
| | n analysis: 27 | | | | D: NA
| Concurrent control | Family physicians who received usual care, | NA | NA | NA | T: NA | NA | NA | NA | NA
| | n assigned: 25 | | | | W: NA
| | | | | | D: NA
| Intervention | Family physicians who received nicotine gum plus training, | Live | NR | Individuals | T: 4 hours | One time | 1 YEAR | NR | Unclear
| | n assigned: 22 | | | | W: Once only
| | | | | | D: NA
Winickoff, 1984^23^ | Intervention | Internists in HMO who received 6 months of monthly feedback on colorectal cancer screening practices compared with colleagues, 1st group to receive intervention, | Print | Feedback | Practice setting/ teams | T: NR | Multiple time or repetitive | 12 months | NR | Yes | To improve physician performance in colorectal cancer screening
| | n assigned: 8 | | | | W: NR
| | | | | | D: 6 months
| Intervention | Internists in HMO who received 6 months of monthly feedback on colorectal cancer screening practices compared with colleagues, 2nd group to receive intervention, | Print | Feedback | Practice settings/ teams | T: NR | Multiple time or repetitive | 6 months | NR | Yes
| | n assigned: 8 | | | | W: NR
| | | | | | D: 6 months
Worrall, 1999^152^ | Concurrent control | Control participants received a copy of the clinical practice guideline in the mail, | Print | Readings | Individuals | T: NA | One time | 6 months | NR | Unclear | The objective of our study was to assess whether a workshop on clinical practice guidelines and the provision of follow-up consults with a psychiatrist improved the process of care and outcomes for patients with depression diagnosed by their family physician.
| | n assigned: 20 | | | | W: NA
| | | | | | D: NA
| Intervention | Participants who received 3 hour educational intervention and access to a psychiatrist, | Live | Case-based learning, discussion group, lecture | Individuals | T: 3 | One time | 6 months | NR | Unclear
| | n assigned: 22 | | | | W: Once only
| | | | | | D: 3 hours (it was a workshop)
Zuckerman, 2004^18^ | Concurrent control | Received only a newsletter, no educational materials, | NA | NA | NA | T: NA | NA | NA | NR | NA | ”The overall goal was to increase the prescribing of beta-blockers to fee-for-service Medicaid patients immediately after a hospitalization for AMI. A secondary project aim was to improve compliance among patients who were prescribed beta-blockers post-AMI, but who were refilling their prescriptions at intervals that suggested poor compliance. The third aim was to evaluate the economic implications of an increase in beta-blocker prescribing.”
| | n assigned: 10972 | | | | W: NA
| | | | | | D: NA
| Intervention | Received “underutilization packages” of educational materials (doctors whose post-AMI patients had not been prescribed a beta-blocker), | Print | Readings | Individuals | T: NR | One time | 30 days | NR | Unclear
| | n assigned: 328 | | | | W: NA
| | | | | | D: 2 weeks
| Intervention | Received “noncompliant packages” of educational materials (doctors whose post-AMI patients were noncompliant with beta-blocker therapy), | Print | Readings | Individuals | T: NR | One time | 30 days | NR | Unclear
| | n assigned: 157 | | | | W: NA
| | | | | | D: 2 weeks

AAN = American Academy of Neurology; ACCESS = Alzheimer's Disease Coordinated Care for San Diego Seniors; ACE = angiotensin-converting enzyme; AHRQ = Agency for Healthcare Research and Quality; AMI = acute myocardial infarction; ARS = audience response system; BSTC = barrier specific telephone counseling; CBE = clinical breast examination; CDE = complete diagnostic evaluation; CDH = chronic daily headache; CHD = coronary heart disease; CME = continuing medical education; DES = diethylstilbestrol; DSM = Diagnostic and Statistic Manual of Mental Disorders; FPs = family practitioner; GIOP = glucocorticoid-induced osteoporosis; GP = general practitioner; HMO = health maintenance organization; IHD = ischemic heart disease; IM = internal medicine; KFP = Key Features Program; LOS = length of stay; MD = medical doctor; MIH = medication induced headache; NA = not applicable; NCEP = National Cholesterol Education Program; NR = not reported; NSAID = non-steroidal anti-inflammatory drugs; OA = osteoarthritis; OSCE = objective structured clinical examination; PBL = problem-based learning; PCP = primary care provider; PHE = physical health examination; PI = practice improvement; QI = quality improvement; SP = standardized patient; TED = teleconferenced education detailing; WAP = written action plan; WBJC = Weekly Browsing Journal Club

Table 4 Evidence Table. Quality of studies assessing the effectiveness of continuing medical education

Author, year | Randomized | Randomization scheme described | Blinded evaluation | Blinding described | Withdrawals described | Power analysis described | Sufficient power to detect statistical significance | Total quality score*
Adams, 1998^125^ | Yes | No | No | NR | NR | No | No | 1
Allison, 2005^147^ | Yes | Yes | No | Not described | No | Yes | No | 2
Andersen, 1990^36^ | Yes | No | NR | NR | No | No | NR | 1
Anderson, 1996^103^ | Yes | No | NR | NR | Yes | No | NR | 2
Beaulieu, 2002^140^ | Yes | Inappropriate | Yes | Yes | Yes | Yes | No | 3
Beaulieu, 2004^44^ | No | NR | No | NR | No | No | NR | 0
Bjornson, 1990^14^ | Yes | No | NR | Not described | Yes | Yes | No | 2
Block, 1988^37^ | No | NR | NR | NR | No | No | NR | 0
Bloomfield, 2005^68^ | Yes | Yes | NR | Not described | Yes | Yes | Yes | 3
Brown, 1999^72^ | Yes | Inappropriate | NR | NR | NR | Yes | Yes | 0
Brown, 2004^135^ | Yes | Yes | No | NR | No | No | NR | 2
Browner, 1994^122^ | Yes | Yes | No | NR | No | Yes | Yes | 2
Bunting, 2004^123^ | No | NR | NR | NR | No | No | NR | 0
Carney, 1995^88^ | Yes | No | Yes | Yes | Yes | Yes | Yes | 4
Casebeer, 1999^131^ | Yes | No | NR | NR | No | No | | 1
Chan, 1999^21^ | Yes | No | NR | Not described | Yes | Yes | Yes | 2
Chassin, 1986^106^ | Yes | Inappropriate | NR | NR | No | No | NR | 0
Cherkin, 1991^83^ | No | NR | No | NR | No | No | NR | 0
Chodosh, 2006^62^ | Yes | No | No | NR | No | No | NR | 1
Chung, 2004^54^ | Yes | Yes | No | NR | No | Yes | No | 2
Clark, 1998^120^ | Yes | No | NR | NR | No | No | NR | 1
Clark, 2000^78^ | Yes | No | NR | NR | Yes | Yes | Yes | 2
Cohn, 2002^19^ | No | NR | NR | NR | No | No | No | 0
Costanza, 1992^35^ | No | NR | No | NR | No | Yes | Yes | 0
Cummings, 1989^112^ | Yes | Yes | Yes | Yes | Yes | No | NR | 5
Cummings, 1989^113^ | Yes | Yes | Yes | Yes | No | No | NR | 4
Cummings, 1989^117^ | Yes | Yes | Yes | Yes | No | No | No | 4
Curran, 2000^34^ | Yes | Yes | NR | NR | No | No | NR | 2
Davis, 2004^101^ | No | NR | No | NR | No | No | NR | 0
Derebery, 2002^153^ | No | NR | NR | NR | No | No | No | 0
Des Marchais, 1990^61^ | Yes | No | NR | NR | No | No | No | 1
Dietrich, 2000^110^ | Yes | Inappropriate | No | NR | No | No | NR | 0
Dormuth, 2004^15^ | Yes | Yes | Yes | Not described | No | No | NR | 3
Doucet, 1998^40^ | No | NR | NR | NR | No | No | NR | 0
Elliott, 1997^55^ | Yes | No | NR | NR | No | No | | 1
Evans CE, 1986^56^ | Yes | Yes | Yes | Inappropriate | Yes | Yes | Yes | 3
Fordis, 2005^42^ | Yes | Yes | NR | NR | Yes | Yes | Yes | 3
Frush, 2006^87^ | Yes | No | NR | NR | No | No | NR | 1
Gerbert, 2002^86^ | Yes | No | NR | NR | No | No | NR | 1
Gerrity, 1999^32^ | Yes | Yes | Yes | Yes | Yes | No | NR | 5
Gerstein, 1999^53^ | No | NR | NR | NR | No | Yes | No | 0
Gifford, 1996^46^ | Yes | Yes | NR | NR | Yes | Yes | Yes | 3
Gifford, 1999^142^ | Yes | Yes | Yes | Not described | Yes | Yes | Yes | 4
Goldberg, 2001^93^ | Yes | No | NR | NR | No | Yes | Yes | 1
Goldstein, 2005^146^ | Yes | Yes | NR | Not described | Yes | No | NR | 3
Goldwater, 2001^157^ | No | NR | NR | NR | No | No | NR | 0
Gonzales, 1999^111^ | No | No | NR | Not described | No | No | NR | 0
Grady, 1997^79^ | Yes | Yes | NR | NR | Yes | No | NR | 3
Greenberg, 1985^25^ | No | | Yes | Yes | No | No | NR | 2
Gullion, 1988^132^ | Yes | No | Yes | Not described | Yes | No | NR | 3
Hagen, 2005^126^ | NR | No | NR | Not described | No | No | NR | 0
Harris, 2002^39^ | Yes | No | NR | NR | No | No | NR | 1
Harris, 2005^75^ | Yes | Yes | NR | Not described | No | No | NR | 2
Heale, 1988^66^ | Yes | Yes | NR | NR | No | No | NR | 2
Herbert, 2004^102^ | Yes | Yes | Yes | Yes | Yes | No | NR | 5
Hergenroeder, 2002^60^ | Yes | Yes | Yes | Inappropriate | No | No | NR | 2
Howe, 1997^145^ | No | NR | NR | NR | No | No | NR | 0
Jennett, 1988^76^ | Yes | Yes | Yes | Yes | Yes | No | NR | 5
Juzych, 2005^92^ | No | No | No | Not described | No | No | NR | 0
Kemper, 2006^58^ | Yes | Yes | No | NR | No | No | NR | 2
Kiang, 2005^33^ | No | No | NR | Not described | No | Yes | Yes | 0
Kim, 1999^137^ | Yes | No | NR | NR | Yes | No | NR | 2
Kottke, 1989^114^ | Yes | Yes | NR | NR | No | Yes | No | 2
Kronick, 2003^71^ | Yes | No | NR | NR | No | Yes | Yes | 1
Kutcher, 2002^65^ | No | NR | NR | Not described | No | No | NR | 0
Labelle, 2004^67^ | No | NR | No | NR | No | No | NR | 0
Lane, 1991^69^ | No | NR | NR | NR | No | Yes | Yes | 0
Lane, 2001^45^ | No | NR | NR | NR | Yes | No | NR | 1
Leopold, 2005^80^ | Yes | No | No | Not described | No | No | NR | 1
Levinson, 1993^138^ | Yes | No | Yes | Yes | Yes | Yes | Yes | 4
Lewis, 1993^70^ | No | NR | No | NR | No | No | NR | 0
Lin, 1997^73^ | No | NR | No | NR | No | No | NR | 0
Lin, 2001^133^ | Yes | Yes | NR | NR | No | No | NR | 2
Lindsay-McIntyre, 1987^115^ | Yes | No | No | NR | Yes | No | NR | 2
Lockyer, 2002^64^ | No | NR | NR | NR | No | No | NR | 0
Maclure, 1998^96^ | Yes | Inappropriate | NR | NR | No | No | NR | 0
Macrae, 2004^85^ | Yes | No | Yes | Yes | Yes | Yes | Yes | 4
Maiman, 1988^47^ | Yes | Yes | Yes | Yes | Yes | No | NR | 5
Mann, 1997^52^ | Yes | No | NR | NR | No | No | NR | 1
Margolis, 2004^118^ | Yes | Yes | NR | Not described | No | Yes | Yes | 2
Maxwell, 1984^57^ | No | NR | Yes | Yes | No | No | NR | 2
Mazmanian, 1998^24^ | Yes | No | NR | NR | No | No | NR | 1
Mazmanian, 2001^161^ | Yes | Yes | Yes | Yes | No | No | NR | 4
McBride, 2000^144^ | Yes | No | No | NR | No | Yes | No | 1
McClellan, 2003^119^ | Yes | Yes | NR | NR | No | Yes | Yes | 2
McMahon, 1988^155^ | No | NR | NR | NR | No | No | NR | 0
Mehler, 2005^99^ | Yes | Yes | No | NR | No | No | NR | 2
Meredith, 2000^51^ | Yes | Yes | No | NR | No | No | NR | 2
Messina, 2002^156^ | No | NR | NR | NR | No | No | NR | 0
Moran, 1996^121^ | No | NR | No | NR | No | No | NR | 0
Mukohara, 2005^13^ | Yes | Yes | NR | Not described | No | Yes | Yes | 2
Myers, 2004^148^ | Yes | No | No | NR | No | Yes | No | 1
Norris, 2000^81^ | Yes | Yes | NR | NR | No | Yes | No | 2
Ockene, 1996^124^ | Yes | Inappropriate | NR | NR | No | No | NR | 0
Ozer, 2005^104^ | No | No | NR | Not described | Yes | No | NR | 1
Pazirandeh, 2002^128^ | No | NR | No | NR | No | No | NR | 0
Pereles, 1996^163^ | Yes | No | NR | NR | No | No | NR | 1
Perera, 1983^107^ | Yes | No | NR | NR | Yes | No | NR | 2
Pimlott, 2003^143^ | Yes | Yes | NR | NR | No | No | NR | 2
Pinto, 1998^74^ | Yes | Yes | No | NR | No | No | No | 2
Premi J, 1993^38^ | Yes | No | NR | NR | No | No | No | 1
Premi, 1994^41^ | No | NR | NR | NR | No | No | NR | 0
Rabin, 1998^97^ | Yes | No | Yes | Not described | No | No | NR | 2
Rahme, 2005^100^ | Yes | Yes | NR | NR | No | No | NR | 2
Ray, 1985^20^ | No | NR | NR | NR | No | No | NR | 0
Ray, 2001^109^ | Yes | Yes | NR | NR | Yes | No | NR | 3
Rodney, 1986^77^ | No | NR | No | NR | No | No | NR | 0
Rosenthal, 2005^59^ | Yes | Yes | No | Not described | No | Yes | Yes | 2
Rost, 2001^22^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | 5
Roter, 1995^84^ | Yes | No | NR | NR | Yes | Yes | Yes | 2
Schectman, 1991^139^ | No | NR | No | NR | No | No | NR | 0
Schectman, 1995^130^ | Yes | No | Yes | Yes | No | Yes | Yes | 3
Schectman, 1996^16^ | No | NR | No | NR | No | No | NR | 0
Schectman, 2003^108^ | Yes | Yes | NR | NR | No | Yes | Yes | 2
Schroy, 1999^82^ | No | NR | NR | NR | Yes | Yes | Yes | 1
Schwartzberg, 1997^98^ | No | NR | NR | NR | Yes | No | NR | 1
Sharif, 2002^94^ | No | NR | NR | NR | No | No | NR | 0
Short, 2006^50^ | Yes | Yes | No | NR | Yes | Yes | No | 3
Sibley, 1982^136^ | Yes | Yes | Yes | Yes | No | Yes | Yes | 4
Slotnick, 1993^17^ | No | NR | NR | NR | No | Yes | Yes | 0
Socolar, 1998^134^ | Yes | Inappropriate | NR | NR | Yes | Yes | Yes | 1
Solomon, 2004^127^ | Yes | No | NR | NR | No | Yes | No | 1
Soumerai, 1987^105^ | Yes | Yes | NR | Not described | No | No | NR | 2
Stein, 2001^95^ | Yes | Yes | Yes | Yes | No | No | NR | 4
Stewart, 2005^43^ | Yes | Yes | NR | NR | NR | Yes | Yes | 2
Stross, 1985^116^ | Yes | No | NR | Not described | No | No | NR | 1
Terry, 1981^49^ | Yes | Yes | Yes | Yes | No | No | NR | 4
Thom, 2000^129^ | No | NR | Yes | Not described | No | No | NR | 1
Tziraki, 2000^141^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | 5
Wells, 2000^151^ | Yes | Yes | NR | NR | Yes | Yes | Yes | 3
White, 1985^48^ | Yes | Yes | Yes | Yes | No | No | NR | 4
White, 2004^63^ | Yes | Yes | Yes | NR | No | No | NR | 3
Wilson, 1988^154^ | Yes | Yes | Yes | Yes | Yes | Yes | No | 5
Winickoff, 1984^23^ | Yes | No | NR | NR | NR | Yes | Yes | 1
Worrall, 1999^152^ | Yes | Yes | NR | Not described | No | Yes | Yes | 2
Zuckerman, 2004^18^ | No | NR | NR | Not described | No | No | NR | 0

* Total quality score was calculated using the Jadad^8^ criteria: 1) appropriateness of the randomization scheme, 2) appropriateness of the blinding, and 3) description of withdrawals and drop-outs.

NR = not reported

Table 5 Evidence Table. Quality of systematic reviews evaluating the effectiveness of simulation in medical education

Author, year | Question clearly stated | Search methods described/ comprehensive | Inclusion criteria reported/ appropriate | Study quality Assessed/ appropriate | Methodology reproducible | Discuss differences in study design or population | Results combined appropriately | Conclusions supported by data | Tests for publication bias
Psychomotor skills
Haque, 2006^26^ | Yes | Partially/yes | Yes/yes | No/can't tell | Can't tell | Yes | Yes | Yes | No
Aucar, 2005^29^ | Partially | Yes/partially | No/can't tell | No/can't tell | Can't tell | Partially | Can't tell | Yes | No
Gerson, 2004^30^ | Partially | Yes/partially | No/can't tell | Yes/yes | Can't tell | Yes | Can't tell | Yes | No
Sutherland, 2006^31^ | Yes | Yes/partially | Yes/yes | Yes/partially | Can't tell | Yes | Can't tell | Yes | No
Ravert, 2002^159^ | Yes | Partially/partially | Yes/yes | No/can't tell | Can't tell | No | Can't tell | Yes | No
Gaffan, 2006^158^ | Partially | Yes/partially | Yes/yes | No/can't tell | Can't tell | No | Can't tell | Yes | No
Communication skills
Gaffan, 2006^158^ | Partially | Yes/partially | Yes/yes | No/can't tell | Can't tell | No | Can't tell | Yes | No
Spangler, 2002^160^ | Yes | Yes/partially | Yes/yes | No/can't tell | Can't tell | No | Can't tell | Yes | No
Cognitive skills
Hmelo, 1990^28^ | Partially | Yes/yes | Partially/partially | No/can't tell | Can't tell | No | Yes | Partially | No
Gaffan, 2006^158^ | Partially | Yes/partially | Yes/yes | No/can't tell | Can't tell | No | Can't tell | Yes | No
Other
Issenberg, 2005^27^ | Yes | Yes/yes | Yes/yes | Yes/yes | Yes | Yes | Yes | Yes | No

Table 6 Evidence Table. Reporting of adult learning principles in studies assessing the effectiveness of continuing medical education

Author, year | Enables learners to be active contributors to their learning* | Relate to learners' current work or life experience^†^ | Tailored to learners' current or past experiences^‡^ | Allow learners to identify their own learning goals and direct their education^§^ | Allow learners to practice what they learn‖ | Provide support to self-directed learners¶ | Receive feedback from teachers and/or peers during active learning^#^ | Allow learners to reflect on learning** | Learners observe the faculty role-model behaviors^††^
Adams, 1998^125^ | Poor | Good | Fair | Poor | Poor | Poor | Fair | Good | Poor
Allison, 2005^147^ | Fair | Good | Fair | Poor | Poor | Poor | Poor | Poor | Poor
Andersen, 1990^36^ | Poor | Good | Poor | Poor | Poor | Poor | Poor | Poor | Poor
Anderson, 1996^103^ | Fair | Good | Fair | Poor | Fair | Poor | Poor | Fair | Poor
Beaulieu, 2002^140^ | Fair | Good | Poor | Poor | Fair | Poor | Poor | Poor | Poor
Beaulieu, 2004^44^ | Fair | Good | Good | Poor | Poor | Fair | Fair | Poor | Poor
Bjornson, 1990^14^ | Poor | Good | Poor | Poor | Poor | Poor | Poor | Fair | Poor
Block, 1988^37^ | Poor | Good | Poor | Poor | | Poor | Poor | Poor | Poor
Bloomfield, 2005^68^ | Fair | Good | Fair | Poor | Poor | Fair | Poor | Poor | Poor
Brown, 1999^72^ | Fair | Good | Poor | Poor | Fair | Good | Poor | Good | Poor
Brown, 2004^135^ | Fair | Good | Fair | Fair | Poor | Fair | Fair | Poor | Poor
Browner, 1994^122^ | Poor | Fair | Poor | Poor | Poor | Poor | Poor | Poor | Poor
Bunting, 2004^123^ | Poor | Good | Poor | Poor | Good | Fair | Good | Poor | Poor
Carney, 1995^88^ | Fair | Fair | Poor | Poor | Fair | Poor | Poor | Poor | Poor
Casebeer, 1999^131^ | Good | Good | Good | Good | Good | Fair | Poor | Poor | Poor
Chan, 1999^21^ | Good | Good | Good | Good | Good | Good | Fair | Fair | Poor
Chassin, 1986^106^ | Poor | Good | Poor | Poor | Poor | Poor | Fair | Poor | Poor
Cherkin, 1991^83^ | Fair | Good | Fair | Poor | Poor | Poor | Poor | Fair | Fair
Chodosh, 2006^62^ | Poor | Good | Poor | Poor | Poor | Poor | Poor | Poor | Poor
Chung, 2004^54^ | Poor | Fair | Poor | Poor | Poor | Fair | Poor | Poor | Poor
Clark, 1998^120^ | Fair | Good | Fair | Poor | Poor | Poor | Poor | Fair | Fair
Clark, 2000^78^ | Good | Good | Fair | Fair | Fair | Fair | Fair | Poor | Poor
Cohn, 2002^19^ | Poor | Fair | Poor | Poor | Good | Fair | Poor | Poor | Poor
Costanza, 1992^35^ | Poor | Fair | Poor | Poor | Fair | Poor | Poor | Poor | Poor
Cummings, 1989^112^ | Fair | Good | Good | Fair | Good | Poor | Fair | Fair | Good
Cummings, 1989^113^ | Fair | Good | Fair | Fair | Good | Poor | Fair | Fair | Fair
Cummings, 1989^117^ | Fair | Good | Poor | Poor | Fair | Poor | Poor | Good | Fair
Curran, 2000^34^ | Good | Good | Good | Fair | Poor | Good | Good | Good | Poor
Davis, 2004^101^ | Fair | Good | Fair | Poor | Poor | Poor | Fair | Poor | Poor
Derebery, 2002^153^ | Good | Good | Fair | Poor | Fair | Poor | Fair | Fair | Fair
Des Marchais, 1990^61^ | Fair | Good | Poor | Poor | Fair | Poor | Fair | Good | Poor
Dietrich, 2000^110^ | Poor | Good | Poor | Poor | Fair | Fair | Poor | Poor | Poor
Dormuth, 2004^15^ | Poor | Good | Poor | Poor | Poor | Fair | Poor | Poor | Poor
Doucet, 1998^40^ | Fair | Good | Good | Poor | Fair | Poor | Poor | Fair | Poor
Elliott, 1997^55^ | Poor | Poor | Fair | Poor | Poor | Poor | Poor | Poor | Poor
Evans CE, 1986^56^ | Poor | Good | Poor | Poor | Poor | Fair | Poor | Poor | Poor
Fordis, 2005^42^ | Fair | Good | Poor | Poor | Poor | Fair | Fair | Poor | Poor
Frush, 2006^87^ | Poor | Good | Fair | Poor | Fair | Poor | Poor | Poor | Poor
Gerbert, 2002^86^ | Fair | Fair | Poor | Poor | Poor | Poor | Fair | Poor | Poor
Gerrity, 1999^32^ | Good | Good | Good | Good | Good | Good | Good | Good | Good
Gerstein, 1999^53^ | Poor | Good | Poor | Poor | Poor | Poor | Poor | Poor | Poor
Gifford, 1996^46^ | Poor | Good | Poor | Poor | Poor | Good | Poor | Poor | Poor
Gifford, 1999^142^ | Poor | Good | Poor | Poor | Poor | Poor | Poor | Poor | Poor
Goldberg, 2001^93^ | Good | Good | Poor | Fair | Fair | Fair | Poor | Good | Poor
Goldstein, 2005^146^ | Fair | Good | Good | Poor | Poor | Poor | Poor | Poor | Poor
Goldwater, 2001^157^ | Poor | Good | Poor | Poor | Good | Poor | Poor | Poor | Poor
Gonzales, 1999^111^ | Poor | Good | Fair | Poor | Poor | Poor | Poor | Poor | Poor
Grady, 1997^79^ | Poor | Fair | Fair | Poor | Poor | Poor | Good | Poor | Poor
Greenberg, 1985^25^ | Fair | Good | Fair | Poor | Poor | Poor | Poor | Poor | Poor
Gullion, 1988^132^ | Fair | Good | Good | Poor | Poor | Poor | Fair | Poor | Poor
Hagen, 2005^126^ | Poor | Good | Fair | Poor | Poor | Fair | Poor | Poor | Poor
Harris, 2002^39^ | Poor | Good | Poor | Poor | Poor | Fair | Poor | Poor | Poor
Harris, 2005^75^ | Fair | Good | Fair | | Poor | Fair | Poor | Poor | Poor
Heale, 1988^66^ | Good | Good | Fair | Poor | Poor | Poor | Poor | Poor | Poor
Herbert, 2004^102^ | Good | Good | Fair | Poor | Poor | Fair | Fair | Poor | Poor
Hergenroeder, 2002^60^ | Poor | Fair | Poor | Poor | Good | Good | Poor | Poor | Fair
Howe, 1997^145^ | Poor | Fair | Poor | Poor | Poor | Poor | Good | Poor | Poor
Jennett, 1988^76^ | Fair | Good | Good | Fair | Good | Poor | Good | Fair | Poor
Juzych, 2005^92^ | Poor | Good | Fair | Poor | Poor | Fair | Poor | Poor | Poor
Kemper, 2006^58^ | Fair | Fair | Fair | Poor | Poor | Fair | Poor | Poor | Poor
Kiang, 2005^33^ | Poor | Good | Fair | Poor | Poor | Poor | Poor | Poor | Poor
Kim, 1999^137^ | Poor | Good | Poor | Poor | Good | Poor | Good | Fair | Poor
Kottke, 1989^114^ | Fair | Good | Poor | Poor | Fair | Poor | Poor | Fair | Poor
Kronick, 2003^71^ | Good | Good | Fair | Good | Poor | Good | Poor | Poor | Poor
Kutcher, 2002^65^ | Fair | Good | Poor | Poor | Poor | Poor | Fair | Fair | Poor
Labelle, 2004^67^ | Fair | Good | Poor | Poor | Fair | Poor | Good | Poor | Poor
Lane, 1991^69^ | Fair | Fair | Poor | Poor | Fair | Poor | Poor | Poor | Poor
Lane, 2001^45^ | Poor | Good | Fair | Poor | Good | Good | Good | Good | Poor
Leopold, 2005^80^ | Fair | Good | Fair | Poor | Fair | Fair | Fair | Poor | Fair
Levinson, 1993^138^ | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor
Lewis, 1993^70^ | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor
Lin, 1997^73^ | Poor | Good | Fair | Poor | Fair | Poor | Good | Poor | Good
Lin, 2001^133^ | Good | Fair | Fair | Poor | Fair | Good | Fair | Fair | Fair
Lindsay-McIntyre, 1987^115^ | Poor | Good | Poor | Poor | Fair | Poor | Poor | Poor | Fair
Lockyer, 2002^64^ | Fair | Good | Fair | Poor | Fair | Poor | Poor | Poor | Poor
Maclure, 1998^96^ | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor
Macrae, 2004^85^ | Fair | Good | Poor | Poor | Poor | Poor | Poor | Poor | Poor
Maiman, 1988^47^ | Fair | Good | Poor | Poor | Poor | Poor | Poor | Poor | Poor
Mann, 1997^52^ | Fair | Good | Poor | Poor | Poor | Fair | Poor | Poor | Fair
Margolis, 2004^118^ | Fair | Good | Fair | Poor | Poor | Poor | Fair | Poor | Poor
Maxwell, 1984^57^ | Fair | Poor | Poor | Fair | Poor | Poor | Fair | Poor | Poor
Mazmanian, 1998^24^ | Poor | Poor | Good | Poor | Poor | Poor | Poor | Poor | Poor
Mazmanian, 2001^161^ | Fair | Poor | Fair | Poor | Poor | Poor | Fair | Poor | Poor
McBride, 2000^144^ | Good | Good | Poor | Good | Fair | Good | Poor | Poor | Poor
McClellan, 2003^119^ | Poor | Good | Fair | Poor | Poor | Poor | Fair | Poor | Poor
McMahon, 1988^155^ | Poor | Fair | Poor | Poor | Poor | Poor | Good | Fair | Poor
Mehler, 2005^99^ | Fair | Good | Fair | Poor | Poor | Poor | Poor | Poor | Poor
Meredith, 2000^51^ | Poor | Good | Poor | Fair | Poor | Poor | Poor | Poor | Poor
Messina, 2002^156^ | Fair | Good | Fair | Poor | Poor | Fair | Poor | Fair | Poor
Moran, 1996^121^ | Good | Good | Good | Good | Poor | Good | Fair | Good | Poor
Mukohara, 2005^13^ | Fair | Fair | Fair | Poor | Poor | Fair | Poor | Poor | Poor
Myers, 2004^148^ | Poor | Good | Fair | Poor | Poor | Good | Fair | Fair | Poor
Norris, 2000^81^ | Poor | Good | Poor | Poor | Poor | Fair | Poor | Poor | Poor
Ockene, 1996^124^ | Poor | Good | Fair | Poor | Fair | Poor | Fair | Poor | Poor
Ozer, 2005^104^ | Fair | Good | Fair | Poor | Poor | Poor | Poor | Poor | Poor
Pazirandeh, 2002^128^ | Poor | Good | Poor | Fair | Poor | Poor | Poor | Poor | Poor
Pereles, 1996^163^ | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor
Perera, 1983^107^ | Poor | Good | Good | Poor | Fair | Poor | Fair | Poor | Fair
Pimlott, 2003^143^ | Poor | Good | Fair | Poor | Poor | Poor | Good | Poor | Poor
Pinto, 1998^74^ | Good | Good | Poor | Poor | Fair | Fair | Fair | Poor | Poor
Premi J, 1993^38^ | Poor | Fair | Poor | Poor | Poor | Poor | Poor | Poor | Fair
Premi, 1994^41^ | Good | Good | Fair | Good | Fair | Good | Fair | Fair | Poor
Rabin, 1998^97^ | Poor | Good | Fair | Poor | Poor | Poor | Fair | Poor | Poor
Rahme, 2005^100^ | Fair | Good | Fair | Poor | Poor | Poor | Poor | Poor | Poor
Ray, 1985^20^ | Fair | Good | Good | Poor | Poor | Poor | Poor | Poor | Poor
Ray, 2001^109^ | Poor | Good | Fair | Poor | Good | Fair | Fair | Fair | Poor
Rodney, 1986^77^ | Poor | Good | Poor | Poor | Fair | Fair | Fair | Poor | Fair
Rosenthal, 2005^59^ | Poor | Good | Fair | Poor | Poor | Poor | Poor | Poor | Poor
Rost, 2001^22^ | Fair | Good | Poor | Poor | Poor | Poor | Fair | Poor | Poor
Roter, 1995^84^ | Poor | Fair | Poor | Poor | Good | Poor | Fair | Poor | Poor
Schectman, 1991^139^ | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor
Schectman, 1995^130^ | Poor | Poor | Poor | Poor | Poor | Poor | Fair | Poor | Poor
Schectman, 1996^16^ | Poor | Good | Poor | Poor | Poor | Poor | Poor | Poor | Poor
Schectman, 2003^108^ | Fair | Fair | Poor | Poor | Poor | Poor | Good | Poor | Poor
Schroy, 1999^82^ | Fair | Good | Fair | Poor | Fair | Poor | Poor | Fair | Poor
Schwartzberg, 1997^98^ | Poor | Fair | Fair | Poor | Poor | Fair | Poor | Poor | Poor
Sharif, 2002^94^ | Fair | Good | Poor | Poor | Fair | Poor | Poor | Poor | Poor
Short, 2006^50^ | Good | Good | Fair | Fair | Poor | Fair | Poor | Poor | Poor
Sibley, 1982^136^ | Fair | Good | Fair | Fair | Poor | Fair | Fair | Poor | Poor
Slotnick, 1993^17^ | Poor | Fair | Fair | Poor | Poor | Poor | Poor | Poor | Poor
Socolar, 1998^134^ | Poor | Poor | Fair | Poor | Poor | Poor | Poor | Poor | Poor
Solomon, 2004^127^ | Fair | Good | Fair | Poor | Good | Fair | Poor | Fair | Poor
Soumerai, 1987^105^ | Fair | Good | Fair | Poor | Poor | Poor | Poor | Fair | Poor
Stein, 2001^95^ | Poor | Good | Poor | Poor | Poor | Fair | Poor | Poor | Poor
Stewart, 2005^43^ | Fair | Good | Fair | Poor | Poor | Poor | Poor | Poor | Poor
Stross, 1985^116^ | Fair | Good | Good | Poor | Poor | Good | Good | Fair | Poor
Terry, 1981^49^ | Good | Good | Fair | Poor | Poor | Fair | Fair | Poor | Poor
Thom, 2000^129^ | Poor | Fair | Poor | Poor | Poor | Poor | Poor | Poor | Poor
Tziraki, 2000^141^ | Good | Good | Good | Good | Fair | Fair | Poor | Poor | Fair
Wells, 2000^151^ | Poor | Fair | Poor | Poor | Poor | Poor | Poor | Poor | Poor
White, 1985^48^ | Fair | Good | Fair | Poor | Poor | Poor | Poor | Poor | Poor
White, 2004^63^ | Fair | Good | Fair | Poor | Poor | Poor | Poor | Poor | Poor
Wilson, 1988^154^ | Poor | Good | Poor | Poor | Poor | Poor | Poor | Poor | Poor
Winickoff, 1984^23^ | Poor | Good | Fair | Poor | Poor | Poor | Fair | Poor | Poor
Worrall, 1999^152^ | Fair | Good | Fair | Fair | Fair | Good | Poor | Poor | Poor
Zuckerman, 2004^18^ | Poor | Good | Fair | Poor | Poor | Poor | Poor | Poor | Poor

* Ratings of “good” indicate that two or more of the following were reported: learners identify/choose a question OR actively contribute to finding the answer OR teach the results of their learning to others. Ratings of “fair” indicate that only one of the above were reported OR none of the above were reported but the curriculum employed partially active learning methods such a interactive lectures or group discussions. Ratings of “poor” indicate that none of the above are described.

† Ratings of “good” indicate that learners would recognize the curriculum as having practical or immediate value to their work or lives. Ratings of “fair” indicate that learners would recognize the curriculum as having theoretical or future value to their work or lives. Ratings of “poor” indicate that learning addresses an issue that the learners do not recognize as having value to their work or lives OR the curriculum's relevance to the learners is not clear.

‡ Ratings of “good” indicate that the authors describe a needs assessment AND describe how the curriculum is tailored towards the needs of the learners. Ratings of “fair” indicate that the authors describe only one of the above. Ratings of “poor ” indicate that the authors neither describe a needs assessment nor do they describe how the curriculum is tailored towards the needs of learners.

§ Ratings of “good” indicate that learners received complete freedom to pursue independent studies or projects during part or all of the curriculum. Ratings of “fair” indicate that learners may choose from a range of learning methods or projects, but the range is limited. Ratings of “poor” indicate that the learners are limited to a single curriculum plan or it is not described.

‖ Ratings of “good” indicate that the learners engage in applied or simulated activities during at least 50% of curriculum time. Ratings of “fair” indicate learners engage in applied or simulated activities <50% of curriculum time. Ratings of “poor” indicate that the curriculum does not provide opportunities for practicing knowledge or skills or it is not described.

¶ Ratings of “good” indicate that the curriculum specifically allots faculty time/resources for supporting learners during independent learning projects. Ratings of “fair” indicate that the curriculum provides only self-learning materials (e.g., online library or bulletin boards) or faculty are available for but not dedicated to supporting self-directed learning. Ratings of “poor” indicate that the curriculum provides none of the above or it is not described.

# Ratings of “good” indicate that the curriculum includes mechanisms for providing formative (feedback that is intended to help learners adjust their learning or activities prior to completion of the curriculum) AND summative (feedback intended to inform learners of their progress upon completion of the curriculum) feedback to learners. Ratings of “fair” indicate that the curriculum only includes mechanisms for providing one of the above. Ratings of “poor” indicate that feedback to learners is not provided or is not described.

** Ratings of “good” indicate that the curriculum describes mechanisms that are specifically intended to help learners reflect on their learning. These may include structured reflection time and debriefing meetings or presentations that are intended for self-reflection. Ratings of “fair” indicate that the curriculum describes learning sessions, such as debriefing meetings or summary presentations, which are not specifically intended for reflection on learning but are likely to involve some reflection by learners. Ratings of “poor” indicate opportunities for self-reflection are not included in the curriculum or are not described.

†† Ratings of “good” indicate that the learners observe role models actually practicing goal behavior in clinical settings. Ratings of “fair” indicate learners observe role models in simulated settings. Ratings of “poor” indicate role modeling is not used or is not described.

Table 7 Evidence Table. Effectiveness of continuing medical education on short-term and long-term knowledge outcomes

Author, year | Media used | Educational techniques | Amount of exposure | Main outcome measure | Type of objective | Objectives met | Summary of results | Overall conclusions | Evaluation duration
Knowledge Objectives Met, Evaluation Duration Not Reported
Kiang, 2005^33^ | Int: NA | Int: NA | Int: NA | Responses to questions about non-predictive clinical factors and social factors | Knowledge Cognitive skills | Yes | In Wisconsin, significant improvement occurred in the responses to the 2 questions about nonpredictive clinical factors and the social factor that may increase the likelihood of prescribing antimicrobial agents. | In conclusion, this study suggests that the WARN campaign had at least a modest positive effect on the knowledge and decision-making of primary care clinicians in Wisconsin. | Int: NA
| CC: NA | CC: NA | CC: NA | | | Yes | Overall, Wisconsin clinicians demonstrated significant improvement regarding the influence of purulent nasal discharge (p=0.044) and productive cough (p=0.010) after accounting for temporal changes in Minnesota. | | CC: NA
| Int: many things were made available but it is not reported as to which groups used what methods; options included live, regional meetings, CD-ROMs, mailings, grandrounds | Int: not clear | Int: not clear | | | | | | Int: NR
| CC: NA | CC: NA | CC: not clear | | | | | | CC: NA
Curran, 2000^34^ | Int: Computer-based off-line, Internet, not real time | Int: Case-based learning, Programmed learning, computer-based courseware | Int: Multiple time or repetitive | Physician learning achievement | Knowledge | Yes | These results indicate that those physicians who participated in a computer-mediated instructional courseware program performed significantly better on a cognitive test of dermatologic office procedures than physicians who received no CME. A significant difference was also found between the mean ranked scores of experimental study group I and the control group (p=.000). A Mann-Whitney test of the mean ranked scores of experimental study group II and the control group also revealed a significant difference (p=.000). | This evaluation revealed that a hybrid computer-mediated courseware system was an effective means for increasing knowledge and improving self-reported competency in dermatologic office procedures, and that participants were very satisfied with the self-paced instruction and use of asynchronous computer conferencing for collaborative information sharing among colleagues. | Int: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
| Int: Computer-based off-line, Internet, not real time | Int: Case-based learning, Programmed learning, computer-based courseware | Int: One time | | | | | | Int: NR
Costanza, 1992^35^ | Int: Live, Print | Int: Discussion group, Lecture, Point of care, Simulation (other than standardized patient or role-play) | Int: Multiple time or repetitive | Physician knowledge and attitudes toward breast cancer screening | Knowledge Attitudes | Yes | Two barriers to use of mammography, concern that mammography is not cost-effective and concern about interpreting ambiguous reports, affected physicians less in the intervention group than in the control. | This study demonstrates that primary care physicians will change their screening practice in response to interventions aimed at altering beliefs regarding mammography benefits or to barriers and their sense of consensus development. | Int: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Andersen, 1990^36^ | Int: Live, Video | Int: Case-based learning, Lecture | Int: One time | Physicians' diagnostic accuracy for psychiatric conditions, as measured by pre and post-tests incorporating multiple clinical vignettes | Knowledge Cognitive skills | Yes | Compared with control, intervention physicians had significantly better post-test composite scores for affective and anxiety disorders; differences significant in 2 of 4 affective disorders (major depression and dysthymic disorder but not depression with psychotic features or bipolar), no specific anxiety disorders (0 of 4), and no somatic disorders. Pre-test scores negatively correlated with improvement in accuracy (more improvement on incorrect pre-test cases). | A brief, single-session intervention can have an impact on physicians' psychiatric diagnostic abilities. Additionally, physicians' participation in the intervention was more likely to refer psychiatric patients. | Int: 1–8 weeks
| CC: NA | CC: NA | CC: NA | | | Yes | | | CC: NA
Block, 1988^37^ | Int: Live, Print | Int: Lecture, Point of care | Int: Multiple time or repetitive | Thresholds for treatment of cholesterol identified by physicians on test | Knowledge | Yes | Physicians in the demonstration project reported lower values for normal, for initiation of diet therapy and lipid lowering therapy (p<0.05). | Physicians in a community with both physician and public education reported changing their practice more significantly than physicians in a comparison community. | Int: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Premi J, 1993^38^ | Int: Video, Print | Int: Case-based learning, Readings | Int: NR | Knowledge of chest pain diagnosis and management, as measured by test | Knowledge | Yes | Using the test questions based on the workbook content, there was a significant increase in posttest scores of intervention (67–>83) vs. control group (stable at 70) (p=0.0001), with no significant effect of review articles. Using general question about chest pain (not covered in the workbook), there was no difference comparing posttest to pretest scores in the groups (control 63.1–>64.6%, intervention 59.9 – >61.6%). | “The program proved successful in improving the participating physicians' knowledge about the diagnosis and management of chest pain.” | Int: NR
| Int: Video, Print | Int: Case-based learning, Readings | Int: NR | | | | | | Int: NR
| CC: Print | CC: Readings | CC: NR | | | | | | CC: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Knowledge Objectives Met, Evaluation Duration Less Than or Equal to 30 Days
Harris, 2002^39^ | Int: Internet, not real time | Int: Case-based learning, Feedback, Readings | Int: Multiple time or repetitive | Physician knowledge, attitudes, and practice behaviors in managing domestic violence cases, as measured by survey | Knowledge Attitudes | Yes | Compared with control group, intervention group had a statistically significant better improvement in scores regarding provider fear of offending patients (p=0.008) and victim-blaming (p=0.022). Compared with control group, intervention group had greater improvements in knowledge scores (p<0.001), but no statistically significant improvements in perceived system support or perceived frequency of asking about domestic violence. | “An on-line DV education program can improve physician confidence (as measured by self efficacy), attitudes, and self-reported knowledge in managing DV patients.” | Int: 3 weeks
| CC: NA | CC: NA | CC: NA | | | Yes | | | CC: 3 weeks
Knowledge Objectives Met, Evaluation Duration Greater Than 30 Days
Doucet, 1998^40^ | Int: Live | Int: Problem-based or team-based learning | Int: Multiple time or repetitive | The Key Feature Problems examination (evaluation of clinical reasoning skills) | Knowledge Cognitive skills | Yes | Whereas those enrolled in the lecture group had a mean score of 28 (SD = 5.23), participants of the PBL group had a mean examination score of 34.76 (SD = 5.96). This represents a 25% difference, deemed educationally significant. The difference in scores between the intervention and control groups was highly statistically significant (p=0.001). | “Tests of knowledge acquisition and the KFP tests of clinical reasoning skills indicated that the PBL group benefited more than the lecture group. In addition, physicians participating in the PBL sessions enjoyed the interactive approach and rated the program more highly. Participants in the PBL group rated the program sessions more favorably than did their counterparts in the lecture group across seven of the nine program dimensions. However, physicians in the lecture group did report that the program held their interest, contributed to their knowledge and skills and provided content useful to their practice. Physicians in the lecture group also agreed that the facilitators presented the concepts effectively, but were less inclined to agree that the discussion component of the lecture enhanced their learning.” | Int: 3 months
| CC: Live | CC: Discussion group, Lecture | CC: One time | | | Yes | | | CC: 3 months
Doucet, 1998^40^ | Int: Live | Int: Problem-based or team-based learning | Int: Multiple time or repetitive | Pre-Post test assessing “knowledge acquisition in the area of headache diagnosis and management” (40 items, developed by a neurologist) | Knowledge | Yes | There was no statistically significant difference observed in knowledge regarding headache diagnosis and management between the intervention and control groups at baseline (p=0.69). On the post-test, the intervention group performed at a statistically significantly higher level than the control group (p=0.05). Mean score for PBL group=33.30 (with SD = 3.67). Mean score for lecture group=31.38 (SD = 4.42). The authors, however, note that the observed post-test difference, at 6%, was not educationally significant. | “Tests of knowledge acquisition and the KFP tests of clinical reasoning skills indicated that the PBL group benefited more than the lecture group. In addition, physicians participating in the PBL sessions enjoyed the interactive approach and rated the program more highly. Participants in the PBL group rated the program sessions more favorably than did their counterparts in the lecture group across seven of the nine program dimensions. However, physicians in the lecture group did report that the program held their interest, contributed to their knowledge and skills and provided content useful to their practice. Physicians in the lecture group also agreed that the facilitators presented the concepts effectively, but were less inclined to agree that the discussion component of the lecture enhanced their learning.” | Int: 3 months
| CC: Live | CC: Discussion group, Lecture | CC: One time | | | | | | CC: 3 months
Premi, 1994^41^ | Int: Live, Print | Int: Case-based learning, Discussion group, Problem-based or team-based learning, Readings | Int: Multiple time or repetitive | Knowledge about asthma, CHF, hormone replacement, and otitis media, as assessed on true-false test >3 months after topic discussed | Knowledge | Yes | Pretest scores were similar in intervention and control (64.7 vs. 64.4) but improved to 76.8 (SD 11.7) in intervention vs. 65.7 in control (12.0), for a gain of 12.1% in intervention (p=0.0001). | Small-group community CME may lead to knowledge gains in topics discussed; unclear about practice behavior without rigorous evaluation | Int: 3 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Fordis, 2005^42^ | Int: Live, Print, Risk calculator | Int: Case-based learning, Lecture, Programmed learning, Readings | Int: One time | Knowledge of cholesterol management, as measured by pretest to posttest 1 (immediate) and posttest 2 (12 week) scores | Knowledge | Yes | Regarding the group main effect, the online CME group scored slightly higher than the live CME group when averaged across all 3 testing occasions (4.8% additional items correct, 95% CI, 0.6%–9.0%; partial w2= 0.01; p=.03). | Appropriately designed, evidence-based online CME can produce objectively measured changes in behavior as well as sustained gains in knowledge that are comparable or superior to those realized from effective live activities. | Int: 5 months
| Int: Internet, real time (e.g., streaming), Internet, not real time, Print, Risk calculator | Int: Case-based learning, Lecture, Programmed learning, Readings | Int: Multiple time or repetitive | | | | For both groups combined, posttest 1 scores surpassed pretest levels, and posttest 2 scores surpassed both pretest and posttest 1 levels (p<.001). The sizes of the differences from pretest to posttest 1 and pretest to posttest 2 were large, representing increases in percentage of items correct of 31.0% (95% CI: 27.0%–35.0%) and 36.4% (95% CI: 32.2%–40.6%), respectively. Although the increase from posttest 1 to posttest 2 was statistically significant (p<.001), the percentage increase was only 5.4% (95% CI: 2.6%–8.2%). | | Int: 5 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Stewart, 2005^43^ | Int: Internet, not real time | Int: Case-based learning, Discussion group, Readings | Int: Multiple time or repetitive | Physician knowledge | Knowledge | Yes | The intervention was associated with increased knowledge. Knowledge scores among the intervention group family physicians were higher than among control group family physicians on the prevention topic, at both 2 months and 6 months. The difference for the diabetes topic was in the expected direction but was not significant. | The case-based on-line discussion demonstrated a mixed effect, with significant differences on only one of two cases and for only two of the three outcomes (family physicians' knowledge and quality of practice). | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | The study identified a promising continuing education format (case-based, on-line learning), as well as questions for future research regarding the content and order of cases presented in on-line education. | CC: NA
Beaulieu, 2004^44^ | Int: Live, Print | Int: Case-based learning, Discussion group, Problem-based or team-based learning, Programmed learning, Readings | Int: One time | | Knowledge | Yes | Median pre and posttest scores (evaluating knowledge retention) were compared, showing an improvement in score for both questions describing patients with (p<0.1), and patients without GI risk factors (p<0.0001). Improvement was also said to be sustained at the 6 month evaluation. | “The results of the initial evaluations have demonstrated that these evidence-based interventions were successful not only in improving physicians' knowledge regarding the diagnosis and management of OA, but also—more importantly—in changing their behavior to make more appropriate therapy choices for their patients. The observed modification of their prescription patterns reflects an improvement in their medical practice, which may lead to better patient outcomes and generate greater cost efficiencies for the health care system.” | Int: 6 months
| Int: Live | Int: Case-based learning, Discussion group, Problem-based or team-based learning, Readings | Int: One time | | | | | | Int: 6 months
| Int: Print | Int: Discussion group, Programmed learning, Readings | Int: One time | | | | | | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 6 months
Cohn, 2002^19^ | Int: Live, Print | Int: Academic detailing | Int: Multiple time or repetitive | Provider knowledge | Knowledge | Yes | Data strongly suggest that intervention increased DES knowledge (statistically significant among double, but not single intervention community). There were also significant increases in the proportion of healthcare providers in the intervention group who read national DES guidelines. | “Academic detailing can increase DES knowledge and history taking among primary care providers.” | Int: 3–6 months
| Int: Live, Print | Int: Academic detailing | Int: Multiple time or repetitive | | | | | | Int: 3–6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 3–6 months
Lane, 2001^45^ | Int: Live | Int: Lecture, Standardized patient | Int: One time | One main outcome measure was whether or not physicians referred 90–100% of women over age 50 to get a mammogram every 1–2 years. The other main outcome was a reduction in the score of needing the CME activity (improved knowledge and understanding) | Knowledge Practice behavior | Yes | There was improvement in the need for CME scores of more physicians in the intervention group than the control group. The intervention significantly improved knowledge and behaviors about breast cancer screening practices. | Participation in the CME activity improved physicians' awareness, knowledge, and behaviors regarding clinical breast exams and breast cancer screening practices, as compared to a control group. | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | Yes | | | CC: NA
Gifford, 1996^46^ | Int: Video, Print | Int: Programmed learning, Readings | Int: Multiple time or repetitive | Factual knowledge about movement disorders, as measured by test | Knowledge | Yes | For 6/7 factual knowledge questions, neurologists' knowledge about movement disorders was higher in the intervention group than in the control group (p<.01). Range for intervention was 44–86% correct and control 32–74% correct. | The educational course improved neurologists' reported decision-making. | Int: 4–5 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 4–5 months
Maiman, 1988^47^ | Int: Live, Print | Int: Discussion group, Lecture, Readings | Int: Multiple time or repetitive | Physician compliance knowledge | Knowledge | Yes | Tutorial and printed materials increased pediatricians' knowledge about adherence-enhancing techniques; tutorials more than printed materials alone. | CME increased physician knowledge and compliance-enhancing practices and resulted in improvement in mothers' adherence to therapy. | Int: 6 months
| Int: Print | Int: Readings | Int: One time | | | | | | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
White, 1985^48^ | Int: Live | Int: Case-based learning, Discussion group, Lecture | Int: One time | Knowledge gains on management of myocardial infarction after CME in multitopic, unitopic, or community CME, as measured by knowledge test pre-, post-, and 6 months post- | Knowledge | Yes | Generalizability study: Physicians in all groups had significant knowledge gains with retention at 6 months (baseline of 68.8–81.5% improving to 80.2–91.7% on post-test and 75.6–82.8% at six months post-test; p<0.01). | “A carefully conceived and executed traditional CME program can result not only in significant increases in physician's knowledge but also in related changes in their patient care practices” ... “both knowledge and behavioral change can persist for at least 6 months” | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
| Int: Live | Int: NR | Int: One time | | | | | | Int: 6 months
| Int: Live | Int: NR | Int: One time | | | | | | Int: 6 months
Terry, 1981^49^ | Int: Live, Audio, Print | Int: Case-based learning, Discussion group, Feedback, Lecture, Readings | Int: Multiple time or repetitive | Knowledge and judgment in COPD management, as measured by self-assessment questionnaires at baseline, 8 months, and 18 months | Knowledge Cognitive skills | Yes | Intervention groups showed a 23% significant increase in scores on posttest 1 to match those of pulmonologists, while there was no improvement for control groups (p>0.05 for group differences). Intervention groups receiving feedback had similar scores on posttest 2 to intervention groups not receiving feedback. Among intervention physicians who did not agree to participate in standardized patients, posttest scores dropped to baseline. | Physicians completing a home study AV program increased knowledge about diagnosis and treatment of COPD, but their behavior in simulated exercises was not different from controls. Experimental group physicians did use more patient-education and smoking cessation information during patient visits. Group meetings for needs assessment and feedback (given 2 weeks after tests) had no apparent effect beyond the audiovisual materials. | Int: 6 months
| Int: Live, Audio, Print | Int: Case-based learning, Discussion group, Lecture, Readings | Int: Multiple time or repetitive | | | Yes | | | Int: 6 months
| Int: Audio, Print | Int: Case-based learning, Feedback, Lecture, Readings | Int: Multiple time or repetitive | | | | | | Int: 6 months
| Int: Live, Audio, Print | Int: Case-based learning, Lecture, Readings | Int: Multiple time or repetitive | | | | | | Int: 6 months
| CC: Audio, Print | CC: Case-based learning, Lecture, Readings | CC: Multiple time or repetitive | | | | | | CC: 6 months
Short, 2006^50^ | Int: Internet, not real time | Int: Lecture, Problem-based or team-based learning, Readings, multiple media, interactivity | Int: Multiple time or repetitive | Educational outcome measure | Knowledge Attitudes | Yes | The MANOVA results showed a significant time by group interaction for the overall physician PREMIS scores (Wilks's lambda = 0.274, p=0.001), indicating a change over 12 months for the study group that was significantly greater than for the control group. There were significant positive changes for the two background PREMIS scales (perceived preparation, p=0.000, and perceived knowledge, p=0.000), five of the six opinion scales (preparation, p=0.000; legal requirements, p=0.011; workplace issues, p=0.002; self-efficacy, p=0.013; and victim understanding, p=0.044); and the practice issues scale (p=0.000). Actual knowledge also improved, but the change was only significant at p <= 0.10 (p=0.06). The only scale that clearly showed no improvement was the opinions scale related to alcohol/drugs and IPV (p=0.445). | This study shows that an asynchronous, interactive, online CME program developed by a cadre of national experts, in accordance with current online education best practices, can be successful in changing a number of physicians' IPV knowledge, attitudes, beliefs, and self-reported behaviors and practices, and that these changes can persist over >= 12 months. | Int: 12 months
| CC: NA | CC: NA | CC: NA | | | Yes | | | CC: NA
Meredith, 2000^51^ | Int: Live, Print | Int: Lecture, Readings | Int: Multiple time or repetitive | Clinician knowledge about depression treatment | Knowledge | Yes | Compared to physicians in usual care, physicians in both the intervention groups showed greater increases in overall depression knowledge (p=0.06). The change in overall depression knowledge scores was most pronounced for the QI therapy group (p=0.01 compared to usual care and p=0.09 compared to QI-meds). Knowledge scores did not change significantly for general treatment & antidepressant medication but there were significant increases in psychotherapy knowledge scores for the QI meds and QI therapy groups compared to usual care (p=0.04 & 0.04 respectively). | Clinicians exposed to multifaceted QI programs for depression in managed primary care practices gained knowledge about assessing and treating depression over 18 months following implementation. The main activity accompanying this gain in knowledge was direct participation in the specific types of formal and informal educational activities that were part of the study protocol. | Int: 12 months (18 months after implementation)
| Int: Live, Print | Int: Lecture, Readings | Int: NA | | | | | | Int: 12 months (18 months after implementation)
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Mann, 1997^52^ | Int: Live, Video, Print | Int: Case-based learning, Demonstration, Discussion group, Readings, Simulation (other than standardized patient or role-play) | Int: Multiple time or repetitive | Physician knowledge, as measured by posttests | Knowledge | Yes | Significant (p=0.002) group × time effect was seen in the overall knowledge score; statistically significantly higher scores were seen in the intervention group (compared to control, p=0.02) at posttest. Statistically significant increases in knowledge of screening, selecting and managing patients and on dietary modification principles, and a nonsignificant, but increasing trend (p=0.09) in dietary assessment techniques, was also seen when comparing the control group to both intervention groups. | Educational training workshops appear to be effective in changing physicians' behavior, and should thus, be continued along with additional research on the mechanisms of which behavior change occurs. | Int: 15 months
| Int: Live, Video, Print Other: cue stickers on medical chart | Int: Case-based learning, Demonstration, Discussion group, Point of care, Readings, Simulation (other than standardized patient or role-play) | Int: Multiple time or repetitive | | | | | | Int: 15 months
| CC: NA | CC: NA | CC: NR | | | | | | CC: 15 months
Gerstein, 1999^53^ | Int: Live | Int: Case-based learning, Discussion group | Int: One time | Knowledge, attitudes, and practice behavior regarding diabetes care, based on participant questionnaire | Knowledge Attitudes Practice behavior | Yes | After 40 days, participants' overall scores improved significantly while there was no change in the controls' scores (F =24.14; p<0.0001). Significant improvement was also noted in domains of attitude (F=31.75; p<0.0001), knowledge (F=4.23; P =0.041), and practice behavior (F=10.43; p=0.0014). | An interactive, small group, diabetes continuing education program effectively disseminates practice guidelines to family physicians. The impact of such a program declines after 1 year. | Int: 24 months
| CC: NA | CC: NA | CC: NA | | | Yes | However, improvement was not apparent after a year. Participants who completed 425-day assessment scored lower in attitude subscale compared to controls, despite having initially scored higher at the 40-day assessment. | | CC: NA
| | | | | | Yes
Knowledge Objectives Not Met, Evaluation Duration Not Reported
Gerrity, 1999^32^ | Int: Live, Video, Audio, Print | Int: Clinical experiences, Discussion group, Feedback, Lecture, Readings, Role play | Int: Multiple time or repetitive | Knowledge about depression diagnosis and management, as measured on a 54-item written test | Knowledge | No | Intervention and control group did not differ significantly in mean scores (41.5 vs. 39.3, p=0.136) or in their assessment of their knowledge in depression (64% vs. 44% rating selves as very knowledgeable about antidepressants, p=0.175). | The Depression Education Program changed physicians' behavior and may be an important component in the efforts to improve the care of depressed patients. | Int: 2–6 weeks
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Knowledge Objectives Not Met, Evaluation Duration Greater Than 30 Days
Chung, 2004^54^ | Int: Live, Internet, not real time | Int: Case-based learning, Lecture, Readings | Int: Multiple time or repetitive | Knowledge of diagnosis and management of victims of bioterrorism. | Knowledge | No | There was no significant change from baseline to 1 and 6 month follow-up for the intervention or control group. | “Even shortly after a bioterrorist attack, physicians were unable to demonstrate an increase in knowledge after voluntarily participating in a web-based educational intervention. ...passive learning through the creation of medical Web sites on the concepts of bioterrorism may not be the most effective method to educate clinicians and, thus, prepare for future attacks.” | Int: 6 months
| CC: Live | CC: Lecture | CC: One time | | | | | | CC: 6 months
Elliott, 1997^55^ | CC: NA | CC: NA | CC: NA | Physician and nurse knowledge of CPM | Knowledge | No | There was a trend toward improved knowledge in the intervention group, but it was not statistically significant. | With the exception of attitudes of patients and caregivers, there was a trend toward improvement in pain ratings as well as provider attitudes and knowledge but the effect was minor and the overall results were not overwhelmingly convincing | CC: NA
| Int: Live, Print | Int: Case-based learning, Clinical experiences, Discussion group, Lecture, Readings | Int: Multiple time or repetitive | | | | | | Int: 15 months
Evans CE, 1986^56^ | Int: Print | Int: Readings, Chart cue materials offered, but not necessarily implemented | Int: Multiple time or repetitive | Physician knowledge of hypertension, as measured by multiple-choice posttest | Knowledge | No | Mean knowledge scores did not differ between groups (50 and 52%, p>0.05). There were no significant correlations between scores and patients' blood pressures, but a weak correlation between scores and patient compliance (r=0.25, p<0.05). | "Our study demonstrates no influence of a mailed continuing medical education program on the practices of physicians or on the control of blood pressure of hypertensive patients referred from a community survey to these physicians after the program was begun. | Int: 21 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 21 months
Knowledge Objectives With Mixed Results, Evaluation Duration Not Reported
Maxwell, 1984^57^ | Int: Live | Int: Case-based learning, Discussion group | Int: Multiple time or repetitive | Knowledge gains on topics under discussion in medical care evaluation committees, as measured by 30-item multiple-choice tests | Knowledge | Mixed | Statistically significant improvement pre- to post- in only 1 of 3 departments. Scores improved in “successful committees” on specific topics compared with those of matched controls or their own scores on control topics (p<0.01). | Medical care evaluation meetings have educational value | Int: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NR
Kemper, 2006^58^ | Int: Internet, not real time | Int: Discussion group, Problem-based or team-based learning | Int: online discussions; case-based, self-instructional modules | Differences of the three types of scores between the four groups | Knowledge Attitudes | No control group | No significant difference in any of the three outcome scores by delivery strategy. | Results from this study have important implications for professional education & future research. Educators wishing to use the Internet can be confident that improvements are not heavily dependent on the curriculum delivery strategy. The delivery method that is easiest for instructors (boluspush), may present the fewest barriers for completion (such as full mailboxes & institutional firewalls), particularly for short, introductory courses. The delivery strategy that is easiest does not appear to result in substantially worse outcomes. Additional interventions are needed to improve clinicians' communication behavior. This study demonstrated that Internet education can substantially improve clinicians' knowledge & confidence regardless of the delivery strategy. | Int: NR
| Int: Internet, not real time | Int: Discussion group, Problem-based or team-based learning | Int: online discussions; case-based, self-instructional modules | | | | | | Int: NR
| Int: Internet, not real time | Int: Discussion group, Problem-based or team-based learning | Int: online discussions; case-based, self-instructional modules | | | | | | Int: NR
| Int: Internet, not real time | Int: Discussion group, Problem-based or team-based learning | Int: online discussions; case-based, self-instructional modules | | | | | | Int: NR
Kemper, 2006^58^ | Int: Internet, not real time | Int: Discussion group, Problem-based or team-based learning | Int: online discussions; case-based, self-instructional modules | Changes in knowledge, confidence and communication scores | Knowledge Attitudes | No control group | Statistically significant improvement in scores after they were taken. | Results from this study have important implications for professional education & future research. Educators wishing to use the Internet can be confident that improvements are not heavily dependent on the curriculum delivery strategy. The delivery method that is easiest for instructors (boluspush), may present the fewest barriers for completion (such as full mailboxes & institutional firewalls), particularly for short, introductory courses. The delivery strategy that is easiest does not appear to result in substantially worse outcomes. Additional interventions are needed to improve clinicians' communication behavior. This study demonstrated that Internet education can substantially improve clinicians' knowledge & confidence regardless of the delivery strategy. | Int: NR
| Int: Internet, not real time | Int: Discussion group, Problem-based or team-based learning | Int: online discussions; case-based, self-instructional modules | | | | | | Int: NR
| Int: Internet, not real time | Int: Discussion group, Problem-based or team-based learning | Int: online discussions; case-based, self-instructional modules | | | | | | Int: NR
| Int: Internet, not real time | Int: Discussion group, Problem-based or team-based learning | Int: online discussions; case-based, self-instructional modules | | | | | | Int: NR
Rosenthal, 2005^59^ | Int: Live, Handheld, Review of data | Int: Lecture, Readings, Review of practice data | Int: Multiple time or repetitive | Parent reports of knowledge | Knowledge | No control group | For parents of both 1-month-olds and 6-month-olds, the control and intervention parents did not differ in the adjusted change in the proportion of parents reporting parent knowledge in age-specific topics. | An office system intervention improved parent reports of quantity of anticipatory guidance but did not change parent knowledge or parent behavior. | Int: NR
| CC: Review of data | CC: Review of practice's data | CC: One time | | | | | | CC: NR
Hergenroeder, 2002^60^ | Int: Video, Print | Int: Demonstration | Int: One time | Physician knowledge of performing a physical exam | Knowledge | No control group | There was a statistically significant increase between baseline and followup in knowledge test scores for both intervention groups, and there was a significant difference between the groups at followup. | “This study demonstrated that improvements in physicians' knowledge and skills in performing ankle and knee physical examinations were associated with the physicians' participation in either intervention. The improvements in physicians' knowledge and skills in the ankle and knee examinations were greater in the videotape plus skills intervention group than in the videotape-alone group.” | Int: NR
| Int: Live, Video, Print | Int: Demonstration, Feedback, Simulation (other than standardized patient or role-play) | Int: One time | | | | | | Int: NR
Des Marchais, 1990^61^ | Int: Live, Video | Int: Case-based learning, Demonstration, Discussion group, Reflection about personal experiences | Int: NR | Appropriate assessment of interpersonal skills of videotaped physicians-in-training, as measured by participants' scoring of the video compared with median score in group | Knowledge | No control group | Both groups showed increased interrater agreement after the first portion of training, but no substantial or significant increase beyond that after the second portion of the training. Order of training (theoretical vs. practical first) had no significant effect. Psychiatrists had a higher reliability score before and after training compared with family physicians. | A short, specific training can increase interrater agreement in the assessment of the doctor-patient relationship. | Int: NR
| Int: Live, Video | Int: Case-based learning, Demonstration, Discussion group, Reflection about personal experiences | Int: NR | | | | | | Int: NR
Knowledge Objectives With No Control Group, Evaluation Duration Less Than or Equal to 30 Days
Slotnick, 1993^17^ | Int: Print | Int: Readings | Int: One time | Knowledge of prescribing information as applied to clinically-oriented test questions on a post-intervention test | Knowledge | No control group | Higher mean test scores were seen for clinical challenge readers vs. conventional ad readers, with a reported effect size of 0.45 SD. There was no difference with an introductory ad explaining the use of the clinical challenge. Knowledge scores were higher for older drug than newer drug. Compared with those reading conventional ads, physicians using enhanced ads had RR 1.48 (1.07–2.05) for correctly answering questions drawn from the clinical challenge scenario, vs. RR 1.12 (NS) for those not covered in the scenario. | Pharmaceutical ads with enhanced clinical challenges increase physician knowledge on testing, specifically for questions that were drawn from the clinical challenges themselves. | Int: immediate
| Int: Print | Int: Readings | Int: One time | | | | | | Int: immediate
| Int: Print | Int: Readings | Int: One time | | | | | | Int: immediate
| Int: Print | Int: Readings | Int: One time | | | | | | Int: immediate
| Int: Print | Int: Readings | Int: One time | | | | | | Int: immediate
| Int: Print | Int: Readings | Int: One time | | | | | | Int: immediate
Knowledge Objectives With Mixed Results, Evaluation Duration Greater Than 30 Days
Chodosh, 2006^62^ | Int: Live, Internet, not real time, Print | Int: Discussion group, Lecture | Int: Multiple time or repetitive | Providers' knowledge regarding dementia care, as measured by test | Knowledge | Mixed | Higher percentage of intervention than usual-care clinic providers answered both of knowledge-related questions on capacity determination correctly (adjusted OR 2.4, 95% CI: 1.2–4.8). No difference existed for questions on knowledge of areas of delirium evaluation, patient safety, and depression treatment. | Despite a successful intervention demonstrating significant improvements in quality of care for patients with dementia, providers' knowledge and attitudes were minimally affected. | Int: 9 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Knowledge Objectives With No Control Group, Evaluation Duration Greater Than 30 Days
White, 2004^63^ | Int: Live | Int: Case-based learning, Discussion group | Int: One time | Performance of questionnaire (knowledge) | Knowledge | No control group | Groups did not differ on their performance. Their performance, however, varied across time, as indicated by the significant main effect for time, F (2,33)=18.10, p<.01, which was consistent for both groups. | This study found no evidence that PBL is any better than more didactic learning sessions in facilitating knowledge gain, knowledge retention, or changes in attitude about asthma management. | Int: 3 months
| CC: Live | CC: Case-based learning, Discussion group, Lecture | CC: One time | | | | Both groups significantly improved their performance at the second administration and retained this level at the third, delayed testing. | However, this study, similar to other studies, suggests that there is weak evidence that physicians attribute additional value to the more interactive PBL approach to CME. | CC: 3 months
| | | | | | | For the knowledge measure, there was a significant drop in performance comparing the delayed test 3 months later to the immediate post-test, but it was still significantly better than performance on the pretest.
Lockyer, 2002^64^ | Int: Live | Int: Case-based learning, Discussion group, Lecture, Role play | Int: One time | Physician practice behaviors: knowledge scores | Knowledge | No control group | Both track 1 (introductory course) and track 2 (advanced course) participants improved statistically significantly between pre and posttest scores; track 1 had a moderate effect size difference (0.5), and track 2 a minimal effect size (0.2). Between tracks comparisons showed statistically significant differences between tracks for precourse assessment of knowledge but not for post-course assessment of knowledge. | Track 1 (introductory course) physicians improved moderately, while track 2 (advanced course) physicians showed a small or negligible change in knowledge, comfort, and involvement in patient care for dementia patients. Tracking in CME - assigning physicians to courses based on pre-course ability, interest, or skill - needs further study. | Int: 3 months
| Int: Live | Int: Case-based learning, Discussion group, Lecture | Int: One time | | | | | | Int: 3 months
Kutcher, 2002^65^ | Int: Live, Print | Int: Academic detailing, Discussion group, Lecture, Readings | Int: One time | Knowledge test | Knowledge | No control group | Both enhanced and general intervention groups improved from pre to post test (p<0.0001), but no comparison between groups was made. | “A well-designed, directional, brief, simple, and low-cost educational program can increase family physicians' knowledge of depression, improve their diagnostic skills, and optimize their treatment of depression.” | Int: 6 months
| Int: Live, Print | Int: Discussion group, Lecture, Readings | Int: One time | | | | | | Int: 6 months
Heale, 1988^66^ | Int: Live | Int: Lecture | Int: One time | Physician knowledge of six topic areas addressed by CME | Knowledge | No control group (No for technique) | Performance assessments on the knowledge MCQ were not provided. The only statement was that there was no difference in acquired or retained knowledge (7 months) among the three learning formats. | Within a one day CME course in family medicine, the learning format had no effect on acquired or retained knowledge or on physician performance in three patient problems. Physicians rated the small group problem based format higher. | Int: 7 months
| Int: Live | Int: Case-based learning, Discussion group | Int: One time | | | | | | Int: 7 months
| Int: Live | Int: Problem-based or team-based learning | Int: One time | | | | | | Int: 7 months
Greenberg, 1985^25^ | Int: Live | Int: Lecture | Int: One time | Knowledge regarding common pediatric problems, as assessed by a multiple-choice test on one of 4 topics | Knowledge | No control group (No for technique) | Case-based learners showed improvement on 64% of the post-tests vs. 29% of lecture-based learners, but this was not statistically significant. 6–9 months later, 55% of the lecture-based learners and 43% of the case-based learners showed a decline in test scores; no tests of significance were reported. | Case-based learning, compared with lecture-based learning, was associated with some significant advantages in teaching skills and behavior in management of common pediatrics problems. | Int: 6–9 months
| Int: Live | Int: Case-based learning | Int: One time | | | | | | Int: 6–9 months
Labelle, 2004^67^ | Int: Live, Print | Int: Case-based learning, Demonstration, Discussion group, Lecture, Problem-based or team-based learning, Role play, Standardized patient | Int: Multiple time or repetitive | Long-term knowledge of written action plans and related asthma management criteria, as assessed by OSCE | Knowledge | No control group | Written action plan (WAP) knowledge increased between baseline and 12 months for those GPs in the second group (participating in the OSCE (objective structured clinical examination) at 6 months) p=0.01. WAP knowledge did increase, but not to a statistically significant degree for those not participating in the OSCE at 6 months (group 1), p=0.28. | “This study demonstrated a positive impact of the combination of a case-based, interactive asthma workshop featuring a preformatted tool to aid in drafting of WAPs, with a reinforcing OSCE 6 months post-workshop, on GP knowledge and self-reported use of WAPs. These results support the conclusion of reviews of CME programs that interactive and sequential educational activities providing opportunities to practice appear promising in changing physician practice.” | Int: 12 months
| Int: Live | Int: Case-based learning, Role play, Standardized patient | Int: Multiple time or repetitive | | | | | | Int: 12 months

CC = concurrent control; CI = confidence interval; CME = continuing medical education; COPD = chronic obstructive pulmonary disease; DES = diethylstilbestrol; DV = domestic violence; GI = gastrointestinal; GP = general practitioner; Int = intervention group; KFP = Key Features Program; MANOVA = multiple analysis of variance; MCQ = multiple choice questionnaire; NA = not applicable; NR = not reported; NS = not significant; OR = odds ratio; OSCE = objective structured clinical examination; PBL = problem-basedlearning; PREMIS = Physician Readiness to Manage Intimate Partner Violence Survey; QI = quality improvement; SD = standard deviation

Table 8 Evidence Table. Grading of the body of evidence for the effectiveness of continuing medical education and the effectiveness of simulation in medical education

| Key Question 1/2 - Effectiveness of CME on Acquisition/Retention | | | | | Key Question3
| Knowledge | Attitudes | Skills | Practice Behaviors | Clinical Outcomes | Psychomotor Skills | Communication Skills | Cognitive Skills | Total
[underlined: Quantity of Evidence:] | 40 | 36 | 22 | 114 | 39 | 7 | 2 | 2 | 9
Number of studies | | | | | | 172 studies | 14 | 37 | 223
[underlined: Quality and Consistency of Evidence:] | High | High | High | High | High | Yes | No | No
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -1 | -1 | -2 | -1 | -1 | Only 1/6 had reproducible methodology | None had reproducible methods | Not reproducible | -2
| | | | | | Quality of studies assessed in only 3 | Only 1 of 3 assessed study quality | No assessment of study quality
Did the studies have important inconsistency? (-1) | -1 | -1 | -1 | -1 | -1 | Yes | No | Yes | -1
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest? | -1 | -1 | -1 | -1 | -1 | No | No | No | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1 | -1 | -1 | -1 | Sparse, only 2 had quantitative data | Sparse | Sparse | -1
Did the studies have high probability of reporting bias? (-1) | -1 | -1 | 0 | -1 | -1 | Yes | Yes | Yes | -1
Did the studies show strong evidence of association between intervention and recruitment outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders or some other measure that suggests a large difference between study groups (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity or some other measure that suggests a very large difference between study groups (+2))[underlined: - use your clinical judgment for absolute differences.] | 0 | 0 | +1 | 0 | 0 | Of the quantitative results, one showed strong associations between transference of skills to OR (task completion rate and error rate) | Not quantitated, but consistently better with role play and or simulated patients | Average effect size 0.63 across 33 studies that collected data in one review | +1
| | | | | | | | Effect sizes ranged -.04 for computer assisted trauma management teaching to 5.06 for anesthesia simulator
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | +1 | 0 | +1 | Yes, large differences in types of learners, skill taught, intensity and frequency of simulation method, and outcome measures. | Yes differences in learners, intensity and frequency, and measures | Yes, differences in learners, and content being taught | +1
Overall grade of evidence (high, moderate, low, very low) | Very low | Very low | Low | Very low | Low | Moderate | Low | Low | Low-Moderate

High = further research is very unlikely to change our confidence in the estimates; moderate = further research is likely to have an important impact on our confidence in the estimate of effect and [underlined: may] change the estimate; low = further research is likely to have an important impact on our confidence in the estimate of effect and [underlined: is likely] to change the estimate; very low = any estimate of effect is very uncertain.

Table 9 Evidence Table. Effectiveness of continuing medical education on short-term and long-term attitude outcomes

Author, year | Media used | Educational techniques | Amount of exposure | Main outcome measure | Type of objecttive | Objectives met | Summary of results | Overall conclusions | Evaluation duration
Attitudinal Objectives Met, Evaluation Duration Not Reported
Bloomfield, 2005^68^ | Int: Live, Print, Patient letter prompting patient to discuss with provider about treatment | Int: Discussion group, Lecture: Patient informs provider | Int: One time | Provider view of live education, opinion leader, and prompts | Attitudes | Yes | 99% of respondents agreed somewhat or completely that the workshop increased their knowledge and 86% stated that they were more likely to treat as a result of the workshop. 60% felt that the opinion leader had influenced their prescribing decisions and about 50% stated that they agreed or strongly agreed that the prompts positively influenced their prescribing, while 40% found the prompts annoying and 14% felt the prompts did more harm than good. | In conclusion, this study shows that a relatively simple intervention (an educational workshop, opinion leader influence and prompts) based on a theoretical model of provider behavior, which is designed to address empirically identified barriers, can result in substantial improvement in provider prescription behavior. | Int: NR
| Int: Live, Print, Chart reminders appearing on cover page of patient's medical record | Int: Discussion group, Lecture Point of care | Int: One time | | | | | | Int: NR
| Int: Live, Print, Progress notes reminding PCP about appropriate approach | Int: Discussion group, Lecture Point of care | Int: One time | | | | | | Int: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Mukohara, 2005^13^ | Int: Computer-based off-line | Int: Readings | Int: Multiple time or repetitive | Time spent reading | Attitudes | Yes | The control group reported a significant increase in the time they spent reading medical journals, amounting to 20% (26 minutes per week), while the WBJC group's reading time decreased by 7% (10 minutes per week). The difference in the change in reading time between the groups was 35.3 minutes (95% CI: 5.1, 65.6). | While doctors appreciated these summaries, which improved their reading efficiency, the intervention had little impact on their use of research evidence in practice. | Int: NR
| CC: Computer-based off-line | CC: Readings | CC: Multiple time or repetitive | | | | | | CC: NR
Curran, 2000^34^ | Int: Computer-based off-line, Internet, not real time | Int: Case-based learning, Programmed learning, computer-based courseware | Int: Multiple time or repetitive | Self-reported performance change | Attitudes | Yes | Wilcoxon tests of the retrospective responses to the performance statements revealed significant differences between self-reported pre- and post-learning performance at p<.05. This suggests that participants experienced improved competencies in all performance areas related to dermatologic office procedures as a result of participating in the computer-mediated instructional program. | This evaluation revealed that a hybrid computer-mediated courseware system was an effective means for increasing knowledge and improving self-reported competency in dermatologic office procedures, and that participants were very satisfied with the self-paced instruction and use of asynchronous computer conferencing for collaborative information sharing among colleagues. | Int: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
| Int: Computer-based off-line, Internet, not real time | Int: Case-based learning, Programmed learning, computer-based courseware | Int: One time | | | | | | Int: NR
Curran, 2000^34^ | Int: Computer-based off-line, Internet, not real time | Int: Case-based learning, Programmed learning, computer-based courseware | Int: Multiple time or repetitive | To determine participant (physician) reaction to the computer-based CME activity | Attitudes | Yes | Participants were very satisfied with the self-paced instruction and use of asynchronous computer conferencing for collaborative information sharing among colleagues. | This evaluation revealed that a hybrid computer-mediated courseware system was an effective means for increasing knowledge and improving self-reported competency in dermatologic office procedures, and that participants were very satisfied with the self-paced instruction and use of asynchronous computer conferencing for collaborative information sharing among colleagues. | Int: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
| Int: Computer-based off-line, Internet, not real time | Int: Case-based learning, Programmed learning, computer-based courseware | Int: One time | | | | | | Int: NR
Costanza, 1992^35^ | Int: Live Print | Int: Discussion group, Lecture, Point of care, Simulation (other than standardized patient or role-play) | Int: Multiple time or repetitive | Physician knowledge and attitudes toward breast cancer screening | Knowledge | Yes | Two barriers to use of mammography, concern that mammography is not cost-effective and concern about interpreting ambiguous reports, affected physicians less in the intervention group than in the control. | This study demonstrates that primary care physicians will change their screening practice in response to interventions aimed at altering beliefs regarding mammography benefits or to barriers and their sense of consensus development. | Int: NR
| CC: NA | CC: NA | CC: NA | | Attitudes | | | | CC: NA
Lane, 1991^69^ | Int: Live Print | Int: ARS, Clinical experiences, Demonstration, Discussion group, Feedback, Lecture Mentor/Preceptor, Readings | Int: Multiple time or repetitive | Change in physicians' attitudes about making mammography referrals | Attitudes | Yes | Physicians remained concerned about cost, radiation exposure, unnecessary biopsies, cost effectiveness, patient discomfort and sufficiency of physician exams, as well as insufficient time with patients. However, there was a statistically significant reduction in concern about cost, radiation exposure and cost-effectiveness in the intervention group whereas there was no significant change in any attitudes in the control sites. | Physicians in the interventions reported (self) an increase in the number of mammography referrals. | Int: NR
| Int: Live Print | Int: ARS, Clinical experiences, Demonstration, Discussion group, Feedback, Lecture, Mentor/Preceptor, Readings | Int: Multiple time or repetitive | | | | | | Int: NR
| Int: NA | Int: NA | Int: NO CME intervention, just free mammography | | | | | | Int: NA
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Andersen, 1990^36^ | Int: Live, Video | Int: Case-based learning, Lecture | Int: One time | Physicians' treatment recommendations for psychiatric conditions, as measured by pre- and post-tests incorporating multiple case vignettes | Attitudes | Yes | Compared with control, intervention physicians were significantly more inclined to refer patients to mental health professional and less inclined to treat them in primary care. Referral was high on pretest for both groups, but experimental group showed increase for 6 of 7 (1 tie) disorders while control did for 2 of 5 (3 ties). For medication, there were no significant effects. For behavioral therapy, there were significant increases for intervention group. | A brief, single-session intervention can have an impact on physicians' psychiatric diagnostic abilities. Additionally, physicians participating in the intervention were more likely to refer psychiatric patients. | Int: 1–8 weeks
| CC: NA | CC: NA | CC: NA | | Practice behavior | Yes | | | CC: NA
Attitudinal Objectives Met, Evaluation Duration Less Than or Equal to 30 Days
Harris, 2002^39^ | Int: Internet, not real time | Int: Case-based learning, Feedback, Readings | Int: Multiple time or repetitive | Physician knowledge, attitudes, and practice behaviors in managing domestic violence cases, as measured by survey | Knowledge | Yes | Compared with control group, intervention group had a statistically significant better improvement in scores regarding provider fear of offending patients (p=0.008) and victim-blaming (p=0.022). Compared with control group, intervention group had greater improvements in knowledge scores (p<0.001), but no statistically significant improvements in perceived system support or perceived frequency of asking about domestic violence. | “An on-line DV education program can improve physician confidence (as measured by self efficacy), attitudes, and self-reported knowledge in managing DV patients.” | Int: 3 weeks
| CC: NA | CC: NA | CC: NA | | Attitudes | Yes | | | CC: 3 weeks
Harris, 2002^39^ | Int: Internet, not real time | Int: Case-based learning, Feedback, Readings | Int: Multiple time or repetitive | Physician self-efficacy in managing domestic violence cases, as measured by survey | Attitudes | Yes | In the intervention group, self-efficacy improved by 17.8% versus -0.6% mean change in control group (p<0.001). | “An on-line DV education program can improve physician confidence (as measured by self efficacy), attitudes, and self-reported knowledge in managing DV patients.” | Int: 3 weeks
| CC: NA | CC: NA | CC: NA | | | | | | CC: 3 weeks
Attitudinal Objectives Met, Evaluation Duration Greater Than 30 Days
Doucet, 1998^40^ | Int: Live | Int: Problem-based learning or team-based learning | Int: Multiple time or repetitive | Program evaluation assessing satisfaction | Attitudes | Yes | 85% of the PBL respondents rated the program as excellent compared to 35% of the control group (p = 0.001). Except for “were well organized” and “facilitator presented concepts effectively,” there were highly statistically significant differences between the two groups' self-reported satisfaction with the program domains. These were: | “Tests of knowledge acquisition and the KFP tests of clinical reasoning skills indicated that the PBL group benefited more than the lecture group. In addition, physicians participating in the PBL sessions enjoyed the interactive approach and rated the program more highly. Participants in the PBL group rated the program sessions more favorably than did their counterparts in the lecture group across seven of the nine program dimensions. However, physicians in the lecture group did report that the program held their interest, contributed to their knowledge and skills and provided content useful to their practice. Physicians in the lecture group also agreed that the facilitators presented the concepts effectively, but were less inclined to agree that the discussion component of the lecture enhanced their learning.” | Int: 3 months
| CC: Live | CC: Discussion group, Lecture | CC: One time | | | | 1 “Met its objectives” - p = 0.013; 2 “Met my expectations” - p = 0.001; 3 “Contributed to my knowledge and skills” - p = 0.004; 4 “Program material was helpful” - p = 0.019; 5 “Discussions enhanced my learning” - p = 0.000 | | CC: 3 months
Lewis, 1993^70^ | Int: Live, Video | Int: Discussion group, Lecture | Int: One time | Physician attitudes toward the course on HIV | Attitudes | Yes | 58% approved of the activity, 20% were neutral, and 22% disapproved at the start. After the intervention, 68% approved, 18% were neutral, and 14% disapproved. This represented a positive impact of the intervention. | These results suggest that a medical education program that goes beyond standard lectures and incorporates interactive formats can change physician behaviors. | Int: 3 months
| Int: Print | Int: Readings | Int: One time | | | | | | Int: 3 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Kronick, 2003^71^ | Int: Live | Int: Case-based learning, Demonstration | Int: One time | Physician comfort level with accessing medical information via internet. | Attitudes | Yes | Intervention group physicians increased their frequency of and comfort with accessing Internet medical information. Statistically significant differences in change from baseline between intervention and control group were seen with frequency of use of the Internet to address patient related questions (p=.009), in the comfort level using online databases (p=.032) and in the frequency of accessing online databases (p=.044). Non-statistically significant differences were seen in frequency of accessing email to answer patient-related questions and comfort in using email, the Internet, opinion of the value of the Internet and in accessing online full-text journals. | “Rural physicians' comfort and competence in use of computers to address patient problems can be improved by an individualized 3-hour training session. These data suggest that physicians distant from medical libraries can have excellent access to evidence-based resources; as connection to the Internet becomes faster, more uniform, and reliable across communities, the training will become easier to deliver.” | Int: 3 months
| CC: NA | CC: NA | CC: NA | | Practice behavior | Mixed | | | CC: 3 months
Fordis, 2005^42^ | Int: Live, Print, Risk calculator | Int: Case-based learning, Lecture, Programmed learning, Readings | Int: One time | Participant satisfaction, as measured by questionnaire | Attitudes | Yes | All live CME participants and 94% of online CME participants rated the learning experience as “good” or “excellent.” Nonparametric correlations revealed no significant associations between course satisfaction and test performance. Nearly all of the 40 online CME participants (95%) who attended the live Web conference rated it as “useful” or “very useful” and indicated that it provided an opportunity to solidify guideline knowledge and obtain answers to questions. | Appropriately designed, evidence-based online CME can produce objectively measured changes in behavior as well as sustained gains in knowledge that are comparable or superior to those realized from effective live activities. | Int: 5 months
| Int: Internet, real time (e.g., streaming), Internet, not real time, Print, Risk calculator | Int: Case-based learning, Lecture, Programmed learning, Readings | Int: Multiple time or repetitive | | | | | | Int: 5 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Brown, 1999^72^ | Int: Live | Int: Clinical experiences, Discussion group, Lecture, Role play, Clinicians audiotaped interaction with patients and listened between workshops | Int: Multiple time or repetitive | Self-assessment of clinicians' communication skills, attitudes, and behavior, as measured by participant questionnaire | Attitudes Skills | Yes | Intervention group noted substantial improvements compared with control in 8 of 24 skills / attitudes / behaviors: awareness of and confidence in dealing with patients whom they found difficult; abilities to compliment patients' efforts, ask open-ended questions, address psychosocial factors, express empathy and reassurance, and clarify expectations. 33% of clinicians reported that fewer than 5% of visits were frustrating after the program (compared with 21% of clinicians at baseline). Three months after the program, clinicians in the intervention group reported that it had improved communication with patients. On average, however, the scores for clinicians' rating of improvement in patient satisfaction and improvement in clinicians' personal satisfaction in their work decreased below the midpoint on the five-point scale (mean rating, 2.85 for both items). | “Thriving in a Busy Practice: Physician-Patient Communication,” a typical continuing medical education program geared toward developing clinicians' communication skills, is not effective in improving general patient satisfaction. To improve global visit satisfaction, communication skills training programs may need to be longer and more intensive, teach a broader range of skills, and provide ongoing performance feedback. | Int: >=6 months
| CC: NA | CC: NA | CC: NA | | (psycho, motor, or procedural skills) | Yes | | | CC: NA
| | | | | Practice behavior | Yes
Lin, 1997^73^ | CC: NA | CC: NA | CC: NA | Physician attitudes toward the intervention | Attitudes | Yes | This outcome was alluded to in the study but was not a primary endpoint in this paper (it was reported elsewhere). However, immediately post-intervention, physicians did have significant improvements in how they felt about the depression care they were delivering. | The results do not support the concept that this complex and aggressive intervention effected a sustain change in practice behaviors 6 months after the intervention. In fact, some positive changes were noted immediately after the intervention (i.e. prescribing patterns) but were lost 6 months after the intervention was over | CC: NA
| Int: Live, Video, Print | Int: Academic detailing, Feedback, Lecture, Readings, Role play | Int: Multiple time or repetitive | | | | | | Int: 6 months
Maiman, 1988^47^ | Int: Live, Print, | Int: Discussion group, Lecture, Readings | Int: Multiple time or repetitive | Physician self-report of compliance enhancing behavior | Attitudes | Yes | 78.2% of physicians in tutorial group, 62.9% of pediatricians in print only group, and 45.9% of controls reported undertaking 8 or more specific behaviors in their practice related to enhancing compliance. | CME increased physician knowledge and compliance-enhancing practices and resulted in improvement in mothers' adherence to therapy. | Int: 6 months
| Int: Print | Int: Readings | Int: One time | | | | | | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Pinto, 1998^74^ | CC: Print | CC: Readings | CC: Given materials to read-exposure up to the physicians | Physician confidence in counseling on exercise | Attitudes | Yes | The intervention group had a statistically significant higher rating of confidence than the control group (p<.05). | The program improved physician confidence in counseling and patient satisfaction, but did not increase the physician reports of exercise counseling provided to all patients. | CC: 8 months
| Int: Live, Print | Int: Discussion group, Readings, Role play | Int: One time | | | | | | Int: 8 months
Short, 2006^50^ | Int: Internet, not real time | Int: Lecture, Problem-based learning or team-based learning, Readings, multiple media, interactivity | Int: Multiple time or repetitive | Educational outcome measure | Knowledge | Yes | The MANOVA results showed a significant time by group interaction for the overall physician PREMIS scores (Wilks's lambda = 0.274, p = 0.001), indicating a change over 12 months for the study group that was significantly greater than for the control group. There were significant positive changes for the two background PREMIS scales (perceived preparation, p = 0.000, and perceived knowledge, p = 0.000), five of the six opinion scales (preparation, p = 0.000; legal requirements, p = 0.011; workplace issues, p = 0.002; self-efficacy, p = 0.013; and victim understanding, p = 0.044); and the practice issues scale (p = 0.000). Actual knowledge also improved, but the change was only significant at p <= 0.10 (p = 0.06). The only scale that clearly showed no improvement was the opinions scale related to alcohol/drugs and IPV (p = 0.445). | This study shows that an asynchronous, interactive, online CME program developed by a cadre of national experts, in accordance with current online education best practices, can be successful in changing a number of physicians' IPV knowledge, attitudes, beliefs, and self-reported behaviors and practices, and that these changes can persist over >= 12 months. | Int: 12 months
| CC: NA | CC: NA | CC: NA | | Attitudes | Yes | | | CC: NA
Harris, 2005^75^ | Int: Live, Audio, Print, Teleconference | Int: Case-based learning, Lecture, Readings | Int: Multiple time or repetitive | Evaluation of quality of teleconferenced educational detailing CME | Attitudes | Yes | 65% of FPs felt their knowledge of the Canadian Diabetes Association guidelines was considerably increased, 76% (22/29) were stimulated to implement new office strategies, and 100% felt the specialist moderators were excellent. Half of the FPs felt they learned as effectively as at a typical CME event. | CME delivered by teleconference was feasible, well attended, well received by participants, and improved some key diabetes management practices and outcomes, although primary goal of improving HbA1C was not achieved. | Int: 12 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Jennett, 1988^76^ | Int: Live, Print, Teleconference | Int: Discussion group, Feedback, Mentor/Preceptor, Readings | Int: Multiple time or repetitive | Value of the educational experience in cardiovascular medicine | Attitudes | Yes | FPs rated the program as 4.3 for value and 4.4 for relevance on a scale of 1–5, with 5 at high end of scale. | A carefully planned CME program, adhering to essential learning principles, was effective in changing office practice of volunteer doctors as long as 12 months after the intervention. | Int: 12 months
| Int: Live, Print, Teleconference | Int: Discussion group, Feedback, Mentor/Preceptor, Readings | Int: Multiple time or repetitive | | | | | | Int: 12 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 12 months
Jennett, 1988^76^ | Int: Live, Print, Teleconference | Int: Discussion group, Feedback, Mentor/Preceptor, Readings, | Int: Multiple time or repetitive | Value of the educational experience in cancer medicine | Attitudes | Yes | FPs rated the value and relevance of the program as 3.4 and 3.5 on scale of 1–5, with 5 representing the high end of the scale. | A carefully planned CME program, adhering to essential learning principles, was effective in changing office practice of volunteer doctors as long as 12 months after the intervention. | Int: 12 months
| Int: Live, Print, Teleconference | Int: Discussion group, Feedback Mentor/Preceptor, Readings | Int: Multiple time or repetitive | | | | | | Int: 12 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 12 months
Mann, 1997^52^ | Int: Live, Video, Print | Int: Case-based learning, Demonstration, Discussion group, Readings, Simulation (other than standardized patient or role-play) | Int: Multiple time or repetitive | Physician attitude, as measured by posttests | Attitudes | Yes | Significant (p=0.03) group × time effect was seen in the overall attitude score. Pretest scores showed statistically significantly more positive attitudes (p=0.02) of some among the control group. Among other attitudes, the intervention groups had more positive attitudes (p=0.02) at posttest. | Educational training workshops appear to be effective in changing physicians' behavior, and should, thus, be continued along with additional research on the mechanisms of which behavior change occurs. | Int: 15 months
| Int: Live, Video, Print, Cue stickers on medical chart | Int: Case-based learning, Demonstration, Discussion group, Point of care, Readings, Simulation (other than standardized patient or role-play) | Int: Multiple time or repetitive | | | | | | Int: 15 months
| CC: NA | CC: NA | CC: NR | | | | | | CC: 15 months
Rodney, 1986^77^ | Int: Live, Video | Int: Demonstration, Lecture, Simulation (other than standardized patient or role-play) | Int: One time | Attitudes towards sigmoidoscopy, as measured by phone or written survey | Attitudes | Yes | Both small and large group learners reported that sigmoidoscopy was a positive contribution to practice. | Physicians who participate in courses in flexible sigmoidoscopy have a higher probability of office utilization of these skills than those who do not take courses. Minimal differences found between large and small group CME formats. | Int: 12–18 months
| Int: Live, Video | Int: Demonstration, Lecture, Simulation (other than standardized patient or role-play) | Int: One time | | | | | | Int: 12–18 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Rodney, 1986^77^ | Int: Live, Video | Int: Demonstration, Lecture, Simulation (other than standardized patient or role-play) | Int: One time | Behavior related to flexible sigmoidoscopy use, as measured by phone or written survey | Attitudes | Yes | Small group learners were more likely to acquire additional training and teaching attachments for their sigmoidoscopes, and less likely to use small (35 cm) scopes; there was no difference in biopsy utilization. 90% of large group learners acquired scopes after training vs. 40–56% of small groups. Small groups were associated with shorter procedure times (p<0.05) for first 10 procedures, but otherwise no differences in times, insertion depths, or number of exams performed. Compared to a randomly surveyed group of physicians, those with CME were significantly more likely to perform flexible sigmoidoscopy. | Physicians who participate in courses in flexible sigmoidoscopy have a higher probability of office utilization of these skills than those who do not take courses. Minimal differences found between large and small group CME formats. | Int: 12–18 months
| Int: Live, Video | Int: Demonstration, Lecture, Simulation (other than standardized patient or role-play) | Int: One time | | Cognitive skills | No | | | Int: 12–18 months
| CC: NA | CC: NA | CC: NA | | Practice behavior | Yes | | | CC: NA
Clark, 2000^78^ | Int: Live, Video | Int: Case-based learning, Demonstration, Lecture | Int: Multiple time or repetitive | Patient parent perception of physician performance. | Attitudes | Yes | Parents of patients of physicians in the intervention group were more likely to report that the doctor had communicated and educated effectively, and that the physician paid close attention to the family. | Participating physicians reported that they communicated and taught patients in a more sophisticated way. Parents of intervention patients reported that physicians used a range of communication and education strategies to enhance patient learning and satisfaction. Intervention patients showed a decrease in hospitalization. | Int: 2 years
| CC: NA | CC: NA | CC: NA | | | | | | CC: 2 years
Gerstein, 1999^53^ | Int: Live | Int: Case-based learning, Discussion group | Int: One time | Knowledge, attitudes, and practice behavior regarding diabetes care, based on participant questionnaire | Knowledge | Yes | After 40 days, participants' overall scores improved significantly while there was no change in the controls' scores (F =24.14; p<0.0001). Significant improvement was also noted in domains of attitude (F=31.75; p<0.0001), knowledge (F=4.23; P =0.041), and practice behavior (F=10.43; p=0.0014). | An interactive, small group, diabetes continuing education program effectively disseminates practice guidelines to family physicians. The impact of such a program declines after 1 year. | Int: 24 months
| CC: NA | CC: NA | CC: NA | | Attitudes | Yes | However, improvement was not apparent after a year. Participants who completed 425-day assessment scored lower in attitude subscale compared to controls, despite having initially scored higher at the 40-day assessment. | | CC: NA
| | | | | Practice behavior | Yes
Attitudinal Objectives Not Met, Evaluation Duration Not Reported
Block, 1988^37^ | Int: Live, Print | Int: Lecture, Point of care | Int: Multiple time or repetitive | Impact of CME on physician attitudes and behaviors as measured by questionnaire | Attitudes | No | Physicians in demonstration project felt equally strong influence of CME courses and consensus statements on their practice behaviors compared with physicians in control group. | MDs in a community with both physician and public education reported changing their practice more significantly than MDs in a comparison community. | Int: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Attitudinal Objectives Not Met, Evaluation Duration Greater Than 30 Days
Chodosh, 2006^62^ | Int: Live, Internet, not real time, Print | Int: Discussion group, Lecture | Int: Multiple time or repetitive | Providers' perceptions of care quality, as measured by questionnaire | Attitudes | No | No difference in providers' perceptions existed about quality of care. | Despite a successful intervention demonstrating significant improvements in quality of care for patients with dementia, providers' knowledge and attitudes were minimally affected. | Int: 9 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Elliott, 1997^55^ | CC: NA | CC: NA | CC: NA | Physician and nurse attitudes toward CPM | Attitudes | No | There was a trend toward improved attitudes in the intervention group, but it was not statistically significant. | With the exception of attitudes of patients and caregivers, there was a trend toward improvement in pain ratings as well as provider attitudes and knowledge but the effect was minor and the overall results were not overwhelmingly convincing | CC: NA
| Int: Live, Print | Int: Case-based learning, Clinical experiences, Discussion group, Lecture, Readings | Int: Multiple time or repetitive | | | | | | Int: 15 months
Mann, 1997^52^ | Int: Live, Video, Print | Int: Case-based learning, Demonstration, Discussion group, Readings, Simulation (other than standardized patient or role-play) | Int: Multiple time or repetitive | Physicians' perceptions of self-efficacy in cholesterol-lowering practices, as measured on Likert scale survey (14 items) | Attitudes | No | Overall posttest scores did not differ between intervention and control groups. Intervention groups (workshop and workshop + chart cue) had statistically significantly higher confidence on 1 of 14 practices at posttest 1 (dietary counseling) and 2 of 14 practices at posttest 2 (identifying patients to be screened and interpreting test results to patient). Results possibly due to multiple comparisons. | Educational training workshops appear to be effective in changing physician behavior, and should, thus, be continued along with additional research on the mechanisms of which behavior change occurs. | Int: 15 months
| Int: Live, Video, Print, Cue stickers on medical chart | Int: Case-based learning, Demonstration, Discussion group, Point of care, Readings, Simulation (other than standardized patient or role-play) | Int: Multiple time or repetitive | | | | | | Int: 15 months
| CC: NA | CC: NA | CC: NR | | | | | | CC: 15 months
Attitudinal Objectives With No Control Group, Evaluation Duration Not Reported
Grady, 1997^79^ | CC: Live, Print | CC: Lecture, Readings | CC: One time | Physician acceptance of the intervention | Attitudes | No control group | Overall 38.7% of physicians used the educational materials and the Likert scale ratings of the cueing procedures, feedback, etc ranged from 2.9–3.8 (scale 1–5). | Cueing (posters and chart stickers) had a positive impact on mammography referral, completion, and compliance above and beyond education only. However, there was no added benefit from feedback and financial rewards for compliance. In addition, physician acceptance of the interventions was marginal. There also appears to be a complex impact of the physician characteristics on the results of the intervention | CC: NR
| Int: Live, Print | Int: Lecture, Point of care, Readings | Int: Multiple time or repetitive | | | | | | Int: NR
| Int: Live, Print | Int: Feedback, Lecture, Point of care, Readings, Financial reward for compliance | Int: Multiple time or repetitive | | | | | | Int: NR
Kemper, 2006^58^ | Int: Internet, not real time | Int: Discussion group, Problem-based learning or team-based learning | Int: Online discussions; case-based, self-instructional modules | Differences of the three types of scores between the four groups | Knowledge | No control group | No significant difference in any of the three outcome scores by delivery strategy. | Results from this study have important implications for professional education & future research. Educators wishing to use the Internet can be confident that improvements are not heavily dependent on the curriculum delivery strategy. The delivery method that is easiest for instructors (boluspush), may present the fewest barriers for completion (such as full mailboxes & institutional firewalls), particularly for short, introductory courses. The delivery strategy that is easiest does not appear to result in substantially worse outcomes. Additional interventions are needed to improve clinicians' communication behavior. This study demonstrated that Internet education can substantially improve clinicians' knowledge & confidence regardless of the delivery strategy. | Int: NR
| Int: Internet, not real time | Int: Discussion group, Problem-based learning or team-based learning | Int: Online discussions; case-based, self-instructional modules | | Attitudes | | | | Int: NR
| Int: Internet, not real time | Int: Discussion group, Problem-based learning or team-based learning | Int: Online discussions; case-based, self-instructional modules | | | | | | Int: NR
| Int: Internet, not real time | Int: Discussion group, Problem-based learning or team-based learning | Int: Online discussions; case-based, self-instructional modules | | | | | | Int: NR
Kemper, 2006^58^ | Int: Internet, not real time | Int: Discussion group, Problem-based learning or team-based learning | Int: Online discussions; case-based, self-instructional modules | Changes in knowledge, confidence and communication scores | Knowledge | No control group | Statistically significant improvement in scores after they were taken. | Results from this study have important implications for professional education & future research. Educators wishing to use the Internet can be confident that improvements are not heavily dependent on the curriculum delivery strategy. The delivery method that is easiest for instructors (boluspush), may present the fewest barriers for completion (such as full mailboxes & institutional firewalls), particularly for short, introductory courses. The delivery strategy that is easiest does not appear to result in substantially worse outcomes. Additional interventions are needed to improve clinicians' communication behavior. This study demonstrated that Internet education can substantially improve clinicians' knowledge & confidence regardless of the delivery strategy. | Int: NR
| Int: Internet, not real time | Int: Discussion group, Problem-based learning or team-based learning | Int: Online discussions; case-based, self-instructional modules | | Attitudes | | | | Int: NR
| Int: Internet, not real time | Int: Discussion group, Problem-based learning or team-based learning | Int: Online discussions; case-based, self-instructional modules | | | | | | Int: NR
| Int: Internet, not real time | Int: Discussion group, Problem-based learning or team-based learning | Int: Online discussions; case-based, self-instructional modules | | | | | | Int: NR
Rosenthal, 2005^59^ | Int: Live, Handheld, Review of data | Int: Lecture, Readings, Review of practice's data | Int: Multiple time or repetitive | Parent reports of preventive health behaviors | Attitudes | No control group | For parents of both 1-month-olds and 6-month-olds, the control and intervention parents did not differ in the adjusted change in the proportion of parents reporting parent behaviors in age-specific topics. | An office system intervention improved parent reports of quantity of anticipatory guidance but did not change parent knowledge or parent behavior. | Int: NR
| CC: Review of data | CC: Review of practice data | CC: One time | | | | | | CC: NR
Leopold, 2005^80^ | Int: Print, | Int: Readings | Int: NA | Confidence in task | Attitudes | No control group | Before the instruction, confidence skills did not differ between the three randomized groups. When stratified by demographic variables, gender and type of practitioner were considered to be significantly different with confidence of skill prior to instruction. | Even low-intensity forms of instruction improve individuals' confidence, competence, and self-assessment of their skill in performing the fairly straightforward psychomotor task of simulated knee injection. However, men and physicians disproportionately overestimated their skills both before and after training, a finding that worsened as confidence increased. The inverse relationship between confidence and competence that we observed before the educational intervention as well as the demographic differences that we noted should raise questions about how complex new procedures should be introduced and when self-trained practitioners should begin to perform them. | Int: NR
| Int: Computer-based off-line | Int: Demonstration, Readings | Int: NA | | | | After instruction, confidence levels increased for all groups. | | Int: NR
| Int: Live | Int: Demonstration, Feedback, Mentor/Preceptor, Simulation (other than standardized patient or role-play) | Int: One time | | | | | | Int: NR
Attitudinal Objectives With Mixed Results, Evaluation Duration Greater Than 30 Days
Norris, 2000^81^ | Int: Live, Print, Followup phone calls about protocol | Int: Lecture, Point of care, Opinion-leader from clinic teaching | Int: Multiple time or repetitive | Physician self-reported knowledge, attitudes, skills, and behavior in counseling patients about physical activity, as measured by questionnaire | Attitudes | Mixed | Significant differences in 3 of 10 reported items: Intervention providers perceived themselves to be more knowledgeable about physical activity counseling (p=0.002), perceived time and effectiveness to be less of a barrier to counseling (p=0.003), and were 22% more likely to counsel patients about physical activity (p=0.03) than control physicians. | “A one-time PACE counseling session with minimal reinforcement, in a setting with high baseline levels of activity, does not further increase activity. Contemplators advanced in stage of behavior change.” | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Chodosh, 2006^62^ | Int: Live, Internet, not real time, Print | Int: Discussion group, Lecture | Int: Multiple time or repetitive | Providers' attitudes regarding dementia care, as measured by questionnaire | Attitudes | Mixed | More intervention physicians strongly endorsed statement “Older patients with dementia are difficult to manage in primary care” (p=0.03). No other differences in attitude between intervention and usual-care providers were observed. | Despite a successful intervention demonstrating significant improvements in quality of care for patients with dementia, providers' knowledge and attitudes were minimally affected. | Int: 9 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Unclear if Attitudinal Objectives Met, Evaluation Duration Greater Than 30 Days
Schroy, 1999^82^ | Int: Live | Int: Academic detailing, Discussion group, Lecture | Int: One time | Provider attitudes or practices related to colorectal cancer screening as determined from a pre-educational vs. post-educational survey instrument, based on an instrument that was similar to one used by the American Cancer Society in 1989 | Attitudes | Unclear | At year 1, there were no significant differences in concern about patient fear and discomfort, time, procedural skills, or cost. However, the mean scores for equipment availability, efficacy, and yield were all significantly higher in the noncompliant group than the compliant group (p = 0.001). Most of the compliant providers were at the intervention sites, which indicate that availability of on-site screening may trump perceived barriers for sigmoidoscopy adherence. At baseline, 24% of providers at intervention sites and 19% at comparison sites reported recommending screening sigmoidoscopy. Overall, self-reported compliance rates increased by 36% at the intervention site, vs. 7% at the comparison site (p = 0.001). | “In summary, this study clearly shows that academic detailing in the form of an outreach didactic educational seminar followed by the implementation of on-site sigmoidoscopy services is an effective strategy for enhancing provider compliance with screening guidelines.” | Int: 1 year
| CC: NA | CC: NA | CC: NA | | Practice behavior | Yes | | | CC: 1 year
Schroy, 1999^82^ | Int: Live | Int: Academic detailing, Discussion group, Lecture | Int: One time | Physician concerns about patient fear, discomfort, time, procedural skill, cost, equipment availability, evidence and yield | Attitudes | Unclear | Providers were asked to rate their concerns on a Likert scale survey pre and one year post intervention. Results were NR by study groups but by compliant vs. noncompliant providers, with the statement that more compliant providers were in the intervention group. | “In summary, this study clearly shows that academic detailing in the form of an outreach didactic educational seminar followed by the implementation of on-site sigmoidoscopy services is an effective strategy for enhancing provider compliance with screening guidelines.” | Int: 1 year
| CC: NA | CC: NA | CC: NA | | | | | | CC: 1 year
Attitudinal Objectives With No Control Group, Evaluation Duration Greater Than 30 Days
White, 2004^63^ | Int: Live | Int: Case-based learning, Discussion group | Int: One time | Program evaluation | Attitudes | No control group | There was no significant difference between the two groups with respect to the overall rating of the CME program or to the knowledge gained at each test administration. | This study found no evidence that PBL is any better than more didactic learning sessions in facilitating knowledge gain, knowledge retention, or changes in attitude about asthma management. | Int: 3 months
| CC: Live | CC: Case-based learning, Discussion group, Lecture | CC: One time | | | | The only statistically significant difference was found in the subjective assessment of the educational value of the program (4.36 vs. 3.93; p=.04) in the PBL session. The attrition rates for the third test administration for the lecture-based participants were higher than the attrition rate of PBL participants. | However, this study, similar to other studies, suggests that there is weak evidence that physicians attribute additional value to the more interactive PBL approach to CME. | CC: 3 months
Lockyer, 2002^64^ | Int: Live | Int: Case-based learning, Discussion group, Lecture, Role play | Int: One time | Physician practice behaviors: comfort level | Attitudes | No control group | Both track 1 (introductory course) and track 2 (advanced course) participants improved statistically significantly between pre and post-test scores; track 1 had a moderate effect size difference (0.5), and track 2 a minimal effect size (0.2). Between tracks comparisons showed statistically significant differences between tracks for both precourse and postcourse assessment of comfort. | Track 1 (introductory course) physicians improved moderately, while track 2 (advanced course) physicians showed a small or negligible change in knowledge, comfort, and involvement in patient care for dementia patients. Tracking in CME - assigning physicians to courses based on pre-course ability, interest, or skill - needs further study. | Int: 3 months
| Int: Live | Int: Case-based learning, Discussion group, Lecture | Int: One time | | | | | | Int: 3 months
Cherkin, 1991^83^ | Int: Live, Video | Int: Demonstration, Discussion group, Lecture | Int: Multiple time or repetitive | Self-assessment of provider knowledge of how to manage back pain | Attitudes | No control group | The percentage of providers who believed they knew exactly what they needed to do to effectively manage patients with low back pain increased from 32% to 71% (p<0.01). | Both HMO and private practice achieved the first goal. As a result of the intervention about 50% of the physicians felt more confident in their ability to manage back pain. | Int: 4 months
| Int: Live, Video | Int: Demonstration, Discussion group, Lecture | Int: One time | | | | | | Int: 1–2 months
Cherkin, 1991^83^ | Int: Live, Video | Int: Demonstration, Discussion group, Lecture | Int: Multiple time or repetitive | Satisfaction with the intervention | Attitudes | No control group | 85% of the providers felt the 3 didactic components to have been “somewhat” useful, almost half (46–48%) found the first two components to be “very” useful. | Both HMO and private practice achieved the first goal. As a result of the intervention about 50% of the physicians felt more confident in their ability to manage back pain. | Int: 4 months
| Int: Live, Video | Int: Demonstration, Discussion group, Lecture | Int: One time | | | | | | Int: 1–2 months
Cherkin, 1991^83^ | Int: Live, Video | Int: Demonstration, Discussion group, Lecture | Int: Multiple time or repetitive | Level of physician comfort in the management of back pain | Attitudes | No control group | 62% of participants felt “somewhat” more confident with back-pain management. About 50% felt more knowledgeable about the psychosocial and scientific aspects of low back pain. | Both HMO and private practice achieved the first goal. As a result of the intervention about 50% of the physicians felt more confident in their ability to manage back pain. | Int: 4 months
| Int: Live, Video | Int: Demonstration, Discussion group, Lecture | Int: One time | | | | | | Int: 1–2 months
Heale, 1988^66^ | Int: Live | Int: Lecture | Int: One time | Perception of the program by participants | Attitudes | No control group (yes for technique) | The small group problem-based learning participants differed significantly, and gave the CME day the highest rating (p value not provided). | Within a one day CME course in family medicine, the learning format had no effect on acquired or retained knowledge or on physician performance in three patient problems. Physicians rated the small group problem based format higher. | Int: 7 months
| Int: Live | Int: Case-based learning, Discussion group | Int: One time | | | | | | Int: 7 months
| Int: Live | Int: Problem-based learning or team-based learning | Int: One time | | | | | | Int: 7 months

ARS = audience response system; ATP = allergy trial pack; CC = concurrent control; CME = continuing medical education; DV = domestic violence; FP = family practitioner; Int = intervention group; IPV = intimate partner violence; KFP = Key Features Program; MANOVA = multiple analysis of variance; NA = not applicable; NR = not reported; PBL = problem-based learning; PCP = primary care provider; SD = standard deviation; WBJC = Weekly Browsing Journal Club;

Table 10 Evidence Table. Effectiveness Of continuing medical education on short-term and long-term skill outcomes

Author, year | Media used | Educational techniques | Amount of exposure | Main outcome measure | Type of objective | Objectives met | Summary of results | Overall conclusions | Evaluation duration
Skills Objectives Met, Evaluation Duration Not Reported
Frush, 2006^87^ | Int: Internet, not real time, Video | Int: Lecture, case-based learning | Int: Education was available for 3 months | Time to determine dose | Cognitive skills | Yes | We also found a significant decrease in the time it took clinicians to determine (prescribe) a dose in the education group after having received the intervention, as compared with the control group. | The Web-based education program on the proper use of the Broselow Pediatric Resuscitation Tape could improve dosing accuracy and reduce dosing time. | Int: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Kiang, 2005^33^ | Int: NA | Int: NA | Int: NA | Responses to adult case scenarios for URI | Cognitive skills | Yes | Both Minnesota and Wisconsin clinicians improved in their responses to the adult case scenarios for URI and bronchitis. The magnitude of improvement was greater for Wisconsin clinicians, but the improvement in Wisconsin was not significant after accounting for the secular trend in Minnesota. In the pediatric case scenarios, Wisconsin clinicians improved from 1999 to 2002 (p = 0.058), while the responses of Minnesota clinicians were essentially unchanged (p = 0.807). | In conclusion, this study suggests that the WARN campaign had at least a modest positive effect on the knowledge and decision-making of primary care clinicians in Wisconsin. | Int: NA
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
| Int: Many things were made available but it is not reported as to which groups used what methods, options included live, regional meetings, CD-ROMs, mailings, grandrounds | Int: Not clear | Int: Not clear | | | | | | Int: NR
| CC: NA | CC: NA | CC: Not clear | | | | | | CC: NA
Kiang, 2005^33^ | Int: NA | Int: NA | Int: NA | Responses to questions about nonpredictive clinical factors and social factors | Knowledge | Yes | In Wisconsin, significant improvement occurred in the responses to the 2 questions about nonpredictive clinical factors and the social factor that may increase the likelihood of prescribing antimicrobial agents. | In conclusion, this study suggests that the WARN campaign had at least a modest positive effect on the knowledge and decision-making of primary care clinicians in Wisconsin. | Int: NA
| CC: NA | CC: NA | CC: NA | | Cognitive skills | Yes | Overall, Wisconsin clinicians demonstrated significant improvement regarding the influence of purulent nasal discharge (p = 0.044) and productive cough (p = 0.010) after accounting for temporal changes in Minnesota. | | CC: NA
| Int: Many things were made available but it is not reported as to which groups used what methods, options included live, regional meetings, CD-ROMs, mailings, grandrounds | Int: Not clear | Int: Not clear | | | | | | Int: NR
| CC: NA | CC: NA | CC: Not clear | | | | | | CC: NA
Gerrity, 1999^32^ | Int: Live, Video, Audio, Print | Int: Clinical experiences, Discussion group, Feedback, Lecture, Readings, Role play | Int: Multiple time or repetitive | Communication skills for diagnosis and management of depression, as assessed by unannounced standardized patients' ratings | Cognitive skills | Yes | Intervention physicians performed better than control physicians in 4 of 6 rated areas for female SP: assessing criteria of depression, suicidal ideation, and stress at home and considering diagnosis of depression. Intervention physicians performed better than control physicians in 2 of 6 rated areas for male SP: assessing stress at home and scheduling followup visit in 2 weeks. | The Depression Education Program changed physicians' behavior and may be an important component in the efforts to improve the care of depressed patients. | Int: 2–6 weeks
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Andersen, 1990^36^ | Int: Live, Video | Int: Case-based learning, Lecture | Int: One time | Physicians' diagnostic accuracy for psychiatric conditions, as measured by pre and post-tests incorporating multiple clinical vignettes | Knowledge | Yes | Compared with control, intervention physicians had significantly better post-test composite scores for affective and anxiety disorders; differences significant in 2 of 4 affective disorders (major depression and dysthymic disorder but not depression with psychotic features or bipolar), no specific anxiety disorders (0 of 4), and no somatic disorders. Pre-test scores negatively correlated with improvement in accuracy (more improvement on incorrect pre-test cases). | A brief, single-session intervention can have an impact on physicians' psychiatric diagnostic abilities. Additionally, physicians participating in the intervention were more likely to refer psychiatric patients. | Int: 1–8 weeks
| CC: NA | CC: NA | CC: NA | | Cognitive skills | Yes | | | CC: NA
Skills Objectives Met, Evaluation Duration Greater Than 30 Days
Macrae, 2004^85^ | Int: Print | Int: Readings, Listserv discussion group with moderator | Int: Multiple time or repetitive | Skills for critically appraising articles, as measured by examination | Cognitive skills | Yes | In general, surgeons in the intervention group performed better on the test of critical appraisal than did those in the control group (with mean examination scores of 58%+-8 AND 50% +-8, respectively, t=3.92, p<0.0001). | “The results of the trial suggest that the intervention was effective in enhancing critical appraisal skills. The effect size seen in this trial was quite large. In this case, the mean of the treatment group was a full standard deviation higher than the mean of the control group. Despite the large number of potential sources of variation, a large proportion of the variance was accounted for by the training condition (intervention or control group) alone. Thus, enhancing critical appraisal skills in the medical community at large likely is of value, and complements other sources in ensuring high levels of evidence-based care. This study is one of the first in the literature to show that it is possible to enhance the critical appraisal skills of practicing physicians with a targeted, Internet-based intervention that can be undertaken in one's own practice setting.” | Int: 6 weeks
| CC: Print | CC: Readings | CC: Multiple time or repetitive | | | | | | CC: 6 weeks
Gerbert, 2002^86^ | Int: Internet, not real time | Int: Case-based learning, Feedback, Programmed learning, Readings | Int: Multiple time or repetitive | Diagnosis and evaluation planning of skin cancer | Cognitive skills | Yes | Overall diagnosis and evaluation planning showed significantly greater improvement from pretest to posttest I comparing the intervention to the control group. There was still greater improvement maintained by posttest II, but only in 5 of 9 outcomes. | “The intervention-group physicians in this study significantly improved in nine of the 14 outcomes, including their overall diagnosis and overall evaluation planning.” | Int: 8 weeks
| CC: NA | CC: NA | CC: NA | | | | | | CC: 8 weeks
Doucet, 1998^40^ | Int: Live | Int: Problem-based learning or team-based learning | Int: Multiple time or repetitive | The Key Feature Problems examination (evaluation of clinical reasoning skills) | Knowledge | Yes | Whereas those enrolled in the lecture group had a mean score of 28 (SD = 5.23), participants of the PBL group had a mean examination score of 34.76 (SD = 5.96). This represents a 25% difference, deemed educationally significant. The difference in scores between the intervention and control groups was highly statistically significant (p = 0.001). | “Tests of knowledge acquisition and the KFP tests of clinical reasoning skills indicated that the PBL group benefited more than the lecture group. In addition, physicians participating in the PBL sessions enjoyed the interactive approach and rated the program more highly. Participants in the PBL group rated the program sessions more favorably than did their counterparts in the lecture group across seven of the nine program dimensions. However, physicians in the lecture group did report that the program held their interest, contributed to their knowledge and skills and provided content useful to their practice. Physicians in the lecture group also agreed that the facilitators presented the concepts effectively, but were less inclined to agree that the discussion component of the lecture enhanced their learning.” | Int: 3 months
| CC: Live | CC: Discussion group, Lecture | CC: One time | | Cognitive skills | Yes | | | CC: 3 months
Brown, 1999^72^ | Int: Live | Int: Clinical experiences, Discussion group, Lecture, Role play, Clinicians audiotaped interaction with patients and listened between workshops | Int: Multiple time or repetitive | Self-assessment of clinicians' communication skills, attitudes, and behavior, as measured by participant questionnaire | Attitudes Skills | Yes | Intervention group noted substantial improvements compared with control in 8 of 24 skills / attitudes / behaviors: awareness of and confidence in dealing with patients whom they found difficult; abilities to compliment patients' efforts, ask open-ended questions, address psychosocial factors, express empathy and reassurance, and clarify expectations. 33% of clinicians reported that fewer than 5% of visits were frustrating after the program (compared with 21% of clinicians at baseline). Three months after the program, clinicians in the intervention group reported that it had improved communication with patients. On average, however, the scores for clinicians' rating of improvement in patient satisfaction and improvement in clinicians' personal satisfaction in their work decreased below the midpoint on the five-point scale (mean rating, 2.85 for both items). | “Thriving in a Busy Practice: Physician-Patient Communication,” a typical continuing medical education program geared toward developing clinicians' communication skills, is not effective in improving general patient satisfaction. To improve global visit satisfaction, communication skills training programs may need to be longer and more intensive, teach a broader range of skills, and provide ongoing performance feedback. | Int: >=6 months
| CC: NA | CC: NA | CC: NA | | (psychomotor or procedural skills) | Yes | | | CC: NA
| | | | | Practice behavior | Yes
Roter, 1995^84^ | Int: Live | Int: Discussion group, Lecture, Role play, Standardized patient | Int: Multiple time or repetitive | Physician use of emotion handling and problem defining skills measured from the audiotape analysis and simulated patients | Cognitive skills | Yes | Emotion handling group used significantly more EH skills than control group; PD group fell in between. Problem defining group used significantly more PD behaviors than the control group with EH group falling between. | Physicians' use of communication skills in their practices changed as a result of an 8-hour CME program. Physicians trained in specific communication skills recognized more psychological problems in their patients than did untrained physicians. Trained physicians showed greater clinical proficiency in the management of a simulated patient compared with control group physicians. The patients of trained physicians compared with untrained physicians showed greater reduction in emotional distress for as long as 6 months after their medical visit. | Int: Participant questionnaire was conducted in between sessions. When the simulated patient occurred was not reported. The last patient assessment was 6 months after their audiotaped visit, which occurred during the CME
| Int: Live | Int: Discussion group, Lecture, Role play, Standardized patient | Int: Multiple time or repetitive
| CC: NA | CC: NA | CC: NA
Roter, 1995^84^ | Int: Live | Int: Discussion group, Lecture, Role play, Standardized patient | Int: Multiple time or repetitive | Recognition & management of emotional problems | Cognitive skills | Yes | Recognition of emotional problems and distress was higher among PD physicians than among control physicians. PD physicians also used more management strategies for emotional problems than control group (p=0.03). EH physicians were not significantly different than control physicians in terms of recognizing emotional problems & distress (p=0.18) and using any of the management strategies. | Physicians' use of communication skills in their practices changed as a result of an 8-hour CME program. Physicians trained in specific communication skills recognized more psychological problems in their patients than did untrained physicians. Trained physicians showed greater clinical proficiency in the management of a simulated patient compared with control group physicians. The patients of trained physicians compared with untrained physicians showed greater reduction in emotional distress for as long as 6 months after their medical visit. | Int: Participant questionnaire was conducted in between sessions. When the simulated patient occurred was not reported. The last patient assessment was 6 months after their audiotaped visit, which occurred during the CME
| Int: Live | Int: Discussion group, Lecture, Role play, Standardized patient | Int: Multiple time or repetitive
| CC: NA | CC: NA | CC: NA
Roter, 1995^84^ | Int: Live | Int: Discussion group, Lecture, Role play, Standardized patient | Int: Multiple time or repetitive | Clinical proficiency | Cognitive skills | Yes | PD physicians had significantly higher scores than the control group. EH physicians had slightly higher scores than control, but the difference was not statistically significant. | Physicians' use of communication skills in their practices changed as a result of an 8-hour CME program. Physicians trained in specific communication skills recognized more psychological problems in their patients than did untrained physicians. Trained physicians showed greater clinical proficiency in the management of a simulated patient compared with control group physicians. The patients of trained physicians compared with untrained physicians showed greater reduction in emotional distress for as long as 6 months after their medical visit. | Int: Participant questionnaire was conducted in between sessions. When the simulated patient occurred was Not reported. The last patient assessment was 6 months after their audiotaped visit, which occurred during the CME
| Int: Live | Int: Discussion group, Lecture, Role play, Standardized patient | Int: Multiple time or repetitive
| CC: NA | CC: NA | CC: NA
Terry, 1981^49^ | Int: Live, Audio, Print | Int: Case-based learning, Discussion group, Feedback Lecture, Readings | Int: Multiple time or repetitive | Knowledge and judgment in COPD management, as measured by self-assessment questionnaires at baseline, 8 months, and 18 months | Knowledge | Yes | Intervention groups showed a 23% significant increase in scores on posttest 1 to match those of pulmonologists, while there was no improvement for control groups (p>0.05 for group differences). Intervention groups receiving feedback had similar scores on posttest 2 to intervention groups not receiving feedback. Among intervention physicians who did not agree to participate in standardized patients, posttest scores dropped to baseline. | Physicians completing a home study AV program increased knowledge about diagnosis and treatment of COPD, but their behavior in simulated exercises was not different from controls. Experimental group physicians did use more patient-education and smoking cessation information during patient visits. Group meetings for needs assessment and feedback (given 2 weeks after tests) had no apparent effect beyond the audiovisual materials. | Int: 6 months
| Int: Live, Audio, Print | Int: Case-based learning, Discussion group, Lecture, Readings | Int: Multiple time or repetitive | | Cognitive skills | Yes | | | Int: 6 months
| Int: Audio, Print | Int: Case-based learning, Feedback, Lecture, Readings | Int: Multiple time or repetitive | | | | | | Int: 6 months
| Int: Live, Audio, Print | Int: Case-based learning, Lecture, Readings | Int: Multiple time or repetitive | | | | | | Int: 6 months
| CC: Audio, Print | CC: Case-based learning, Lecture, Readings | CC: Multiple time or repetitive | | | | | | CC: 6 months
Skills Objectives Not Met, Evaluation Duration Not Reported
Mukohara, 2005^13^ | Int: Computer-based off-line | Int: Readings | Int: Multiple time or repetitive | Frequency of finding answers to clinical questions | Cognitive skills | No | By the end of the 3-month trial, there were no significant differences within or between the WBJC and control groups in the frequency of finding an answer to clinical questions. | While doctors appreciated these summaries, which improved their reading efficiency, the intervention had little impact on their use of research evidence in practice. | Int: NR
| CC: Computer-based off-line | CC: Readings | CC: Multiple time or repetitive | | | | | | CC: NR
Skills Objectives Not Met, Evaluation Duration Greater Than 30 Days
Rodney, 1986^77^ | Int: Live, Video | Int: Demonstration, Lecture, Simulation (other than standardized patient or role-play) | Int: One time | Behavior related to flexible sigmoidoscopy use, as measured by phone or written survey | Attitudes | Yes | Small group learners were more likely to acquire additional training and teaching attachments for their sigmoidoscopes, and less likely to use small (35 cm) scopes; there was no difference in biopsy utilization. 90% of large group learners acquired scopes after training vs. 40–56% of small groups. Small groups were associated with shorter procedure times (p<0.05) for first 10 procedures, but otherwise no differences in times, insertion depths, or number of exams performed. Compared to a randomly surveyed group of physicians, those with CME were significantly more likely to perform flexible sigmoidoscopy. | Physicians who participate in courses in flexible sigmoidoscopy have a higher probability of office utilization of these skills than those who do not take courses. Minimal differences found between large and small group CME formats. | Int: 12–18 months
| Int: Live, Video | Int: Demonstration, Lecture, Simulation (other than standardized patient or role-play) | Int: One time | | Cognitive skills | No | | | Int: 12–18 months
| CC: NA | CC: NA | CC: NA | | Practice behavior | Yes | | | CC: NA
Skills Objectives With Mixed Results, Evaluation Duration Greater Than 30 Days
Carney, 1995^88^ | Int: Live, Video | Int: Demonstration, Discussion group, Feedback, Lecture Programmed learning, Role play | Int: One time | Which CME techniques had the greatest effect on physician cancer screening and prevention counseling skills | Cognitive skills | Mixed | Performance of intervention physicians was consistently better though only 4 of 19 measured endpoints of the physicians' behavior by the SP reached statistical significance. | Performance based CME techniques have a positive influence on physicians' performance (especially in skills training). Using unannounced standardized patients is a feasible method to assess performance within the practice environment. | Int: 1 year
| CC: NA | CC: NA | CC: NA | | Practice behavior | Mixed | | | CC: NA
Skills Objectives With No Control Group, Evaluation Duration Not Reported
Leopold, 2005^80^ | Int: Print | Int: Readings | Int: NA | Competence in task | Skills (psychomotor or procedural skills) | No control group | Before the instruction, competence skills did not differ between the three randomized groups. After the instruction, competence skills increased for all groups. | Even low-intensity forms of instruction improve individuals' confidence, competence, and self-assessment of their skill in performing the fairly straightforward psychomotor task of simulated knee injection. However, men and physicians disproportionately overestimated their skills both before and after training, a finding that worsened as confidence increased. The inverse relationship between confidence and competence that we observed before the educational intervention as well as the demographic differences that we noted should raise questions about how complex new procedures should be introduced and when self-trained practitioners should begin to perform them. | Int: NR
| Int: Computer-based off-line | Int: Demonstration, Readings | Int: NA | | | | | | Int: NR
| Int: Live | Int: Demonstration, Feedback, Mentor/Preceptor, Simulation (other than standardized patient or role-play) | Int: One time | | | | | | Int: NR
Hergenroeder, 2002^60^ | Int: Video, Print | Int: Demonstration | Int: One time | Physician skills in performing a physical exam | Skills (psychomotor or procedural skills) | No control group | There was a statistically significant increase between baseline and followup in clinical skills assessment examination scores for both intervention groups, and there was a significant difference between the groups at followup. | “This study demonstrated that improvements in physicians' knowledge and skills in performing ankle and knee physical examinations were associated with the physicians' participation in either intervention. The improvements in physicians' knowledge and skills in the ankle and knee examinations were greater in the videotape plus skills intervention group than in the videotape-alone group.” | Int: NR
| Int: Live, Video, Print | Int: Demonstration, Feedback, Simulation (other than standardized patient or role-play) | Int: One time | | | | | | Int: NR

AV = audiovisual; CC = concurrent control; CME = continuing medical education; COPD = chronic obstructive pulmonary disease; EH = emotion handling; Int =intervention group; KFP = Key Features Problems; NA = not applicable; NR = not reported; PBL = problem-based learning; PD = problem defining; SD = standard deviation; SP = standardized patient; URI = upper respiratory infection; WARN = Wisconsin Antibiotic Resistance Network

Table 11 Evidence Table. Effectiveness of continuing medial education on short-term and long-term practice behavior outcomes

Author, year | Media used | Educational techniques | Amount of exposure | Main outcome measure | Type of objective | Objectives met | Summary of results | Overall conclusions | Evaluation duration
Practice Behavior Objectives Met, Evaluation Duration Not Reported
Frush, 2006^87^ | Int: Internet, not real time, Video | Int: Lecture, Simulated scenario | Int: Education was available for 3 months | Dosing deviation from accepted dose range | Practice behavior | Yes | In this randomized, controlled clinical trial, we found a significant reduction in medication dosing deviation when emergency providers received education about proper use of one resuscitation aid (the Broselow Pediatric Resuscitation Tape) as compared with no education being offered. | The Web-based education program on the proper use of the Broselow Pediatric Resuscitation Tape could improve dosing accuracy and reduce dosing time. | Int: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Juzych, 2005^92^ | Int: Live, Print | Int: Case-based learning, Lecture, Readings | Int: Single half day session | Prescription rates of antibiotics | Practice behavior | Yes | Among physicians in the intervention population, the overall prescribing rates of antibiotics declined 24.6% from 49.9% to 37.6% (P<.0001). Between the control and intervention groups, the decline in prescribing rates for antibiotics was significant (P<.0001). | This study suggests that an educational intervention on appropriate antibiotic use reduced antibiotic use in treating uncomplicated URIs. A significant difference in changes in prescribing rates between the intervention and control populations was found only for URIsnos. | Int: NR
| CC: NA | CC: NA | CC: NA | | | | Statistically significant declines in prescribing of antibiotics were seen among physicians in the intervention group for pharyngitis (P=.007), otitis media (P=.001), and URIsnos (P=.001). For bronchitis, there was no significant change in prescribing of antibiotics in the intervention group (P=.84). | This confirms previous studies of educational interventions to reduce antimicrobial use in treating URIs and demonstrates that a meaningful reduction is achievable when the program is applied to all staff members at a Medicaid HMO. Educational efforts to improve prescribing of antibiotics for treating uncomplicated viral URIs should be expanded, and should include all health care staff. Such programs should provide physicians and staff with the tools to diagnose URIs appropriately and teach them how to convey to patients why antimicrobials may not be appropriate. | CC: NA
Bloomfield, 2005^68^ | Int: Live, Print, Patient letter prompting patient to discuss with provider about letter contents (treatment) | Int: Discussion group, Lecture, Patient informs provider | Int: One time | Prescription rates | Practice behavior | Yes | The prescription rate at the control sites did not change between the two time periods (pre-intervention period 18.9%, intervention period, 17.7%, p=0.19), but it increased from 8.3% to 39.1% (OR=6.5, 95% CI 5.2 to 8.2, p=0.0001) at the intervention sites. There was a significant interaction between group and time period (p=0.0001). The adjusted odds of receiving a prescription during the intervention period was 3.1 times higher at the intervention sites than at the control sites (95% CI 2.1 to 4.7). | In conclusion, this study shows that a relatively simple intervention (an educational workshop, opinion leader influence and prompts) based on a theoretical model of provider behavior, which is designed to address empirically identified barriers, can result in substantial improvement in provider prescription behavior. | Int: NR
| Int: Live, Print, Chart reminders appearing on cover page of patient's computerized medical record | Int: Discussion group, Lecture, Point of care | Int: One time | | | | Overall, there was no statistically significant difference in prescription rates among the three prompt groups (40.7% for progress notes, 36.9% for patient letters, and 39.4% for reminders, p=0.60). However, there was a significant interaction between group and site, indicating that the efficacy of the prompts differed by site. | | Int: NR
| Int: Live, Print, Progress notes reminding primary care clinician about appropriate approach | Int: Discussion group, Lecture, Point of care | Int: One time | | | | | | Int: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Dormuth, 2004^15^ | Int: Print | Int: Readings | Int: Multiple time or repetitive | Proportion receiving drugs recommended from letter | Practice behavior | Yes | A significant change was observed in the proportion of newly treated patients receiving the analysis drugs as first-line therapy. The preference for the analysis drugs was 1.3 times more in the predicted direction in the intervention group of physicians than in the control group (95% CI: 1.13–1.52). | The results of this randomized controlled trial demonstrate a significant change in prescribing to newly treated patients when the impact of a series of 12 letters was subjected to a combined analysis. | Int: NR
| CC: Print | CC: Readings | CC: Multiple time or repetitive | | | | | We conclude that printed letters distributed as an ongoing series from a credible and trusted source can have a clinically significant impact on prescribing to newly treated patients. | CC: NR
Goldberg, 2001^93^ | Int: Live, Video, Print | Int: Academic detailing, Discussion group, Lecture | Int: Multiple time or repetitive | Quarterly observations of surgical rates | Practice behavior | Yes | After the intervention, the rates of surgery went down in the intervention group practices, while rates went up in the control group practices. Reduction in surgical rate: 8.9% (p=0.01) | After implementation of the intervention, surgery rates declined in the intervention communities but increased slightly in the control communities. The net effect of the intervention is estimated to be a decline of 20.9 operations per 100,000, a relative reduction of 8.9% (P = 0.01). Conclusion. We were able to use scientific evidence to engender voluntary change in back pain practice patterns across entire communities. | Int: NA
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Gerrity, 1999^32^ | Int: Live, Video, Audio, Print | Int: Clinical experiences, Discussion group, Feedback, Lecture, Readings, Role play | Int: Multiple time or repetitive | Participatory decision making | Practice behavior | Yes | Intervention physicians scored higher than control physicians on the Participatory Decision-Making Scale (p=.017 and p=.014 in two SP cases). | The Depression Education Program changed physicians' behavior and may be an important component in the efforts to improve the care of depressed patients. | Int: 2–6 weeks
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Grady, 1997^79^ | CC: Live, Print | CC: Lecture, Readings | CC: One time | Effect of intervention on mammography referral, completion, and compliance rates at the practice level | Practice behavior | Yes | Mammography referral, completion and compliance were all higher at one year at the experimental groups (i.e. cue) than at the control groups. However, no significant difference was seen between the two experimental groups (i.e. no extra effect from feedback and rewards). | Cueing (posters and chart stickers) had a positive impact on mammography referral, completion, and compliance above and beyond education only. However, there was no added benefit from feedback and financial rewards for compliance. In addition, physician acceptance of the interventions was marginal. There also appears to be a complex impact of the physician characteristics on the results of the intervention | CC: NR
| Int: Live, Print | Int: Lecture, Point of care, Readings | Int: Multiple time or repetitive | | | | | | Int: NR
| Int: Live, Print | Int: Feedback, Lecture, Point of care, Readings Financial reward for compliance | Int: Multiple time or repetitive | | | | | | Int: NR
Grady, 1997^79^ | CC: Live, Print | CC: Lecture, Readings | CC: One time | Impact of interventions at the physician level | Practice behavior | Yes | Same result as above-the pattern was the same for physicians | Cueing (posters and chart stickers) had a positive impact on mammography referral, completion, and compliance above and beyond education only. However, there was no added benefit from feedback and financial rewards for compliance. In addition, physician acceptance of the interventions was marginal. There also appears to be a complex impact of the physician characteristics on the results of the intervention | CC: NR
| Int: Live, Print | Int: Lecture, Point of care, Readings | Int: Multiple time or repetitive | | | | | | Int: NR
| Int: Live, Print | Int: Feedback, Lecture, Point of care, Readings Financial reward for compliance | Int: Multiple time or repetitive | | | | | | Int: NR
Costanza, 1992^35^ | Int: Live, Print | Int: Discussion group, Lecture, Point of care, Simulation (other than standardized patient or role-play) | Int: Multiple time or repetitive | Physician's self report of screening practice changes | Practice behavior | Yes | An adjusted odds ratio of 7.85 was obtained when comparing the improvement in self-reported screening behavior among physicians in the intervention group to that in the control group. | This study demonstrates that primary care physicians will change their screening practice in response to interventions aimed at altering beliefs regarding mammography benefits or to barriers and their sense of consensus development. | Int: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Lane, 1991^69^ | Int: Live, Print | Int: Audience response systems, Clinical experiences, Demonstration, Discussion group, Feedback, Lecture, Mentor/Preceptor, Readings | Int: Multiple time or repetitive | Change in mammography referrals | Practice behavior | Yes | Physicians across specialties reported an increase in mammography screening referrals. | Physicians in the interventions reported (self) an increase in the number of mammography referrals. | Int: NR
| Int: Live, Print | Int: Audience response systems, Clinical experiences, Demonstration, Discussion group, Feedback, Lecture, Mentor/Preceptor, Readings | Int: Multiple time or repetitive | | | | | | Int: NR
| Int: NA | Int: NA | Int: No CME intervention, just free mammography | | | | | | Int: NA
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Andersen, 1990^36^ | Int: Live, Video | Int: Case-based learning Lecture | Int: One time | Physicians' treatment recommendations for psychiatric conditions, as measured by pre- and post-tests incorporating multiple case vignettes | Attitudes | Yes | Compared with control, intervention physicians were significantly more inclined to refer patients to mental health professional and less inclined to treat them in primary care. Referral was high on pretest for both groups, but experimental group showed increase for 6 of 7 (1 tie) disorders while control did for 2 of 5 (3 ties). For medication, there were no significant effects. For behavioral therapy, there were significant increases for intervention group. | A brief, single-session intervention can have an impact on physicians' psychiatric diagnostic abilities. Additionally, physicians participating in the intervention were more likely to refer psychiatric patients. | Int: 1–8 weeks
| CC: NA | CC: NA | CC: NA | | Practice behavior | Yes | | | CC: NA
Practice Behavior Objectives Met, Evaluation Duration Less Than or Equal to 30 Days
Sharif, 2002^94^ | Int: Live | Int: Lecture, Role play | Int: One time | Smoking cessation behavior and documentation, as measured by standardized chart abstraction of medical records for all scheduled visits 3 weeks before and 3 weeks after workshop training | Practice behavior | Yes | Posttraining, workshop attendees were significantly more likely to do 3 of 6 behaviors: inquire about parental smoking status (RR 3.06, 1.86–4.87), to identify smokers (RR 8.89, 2.79–28.40), and to offer advice about the effects of environmental tobacco smoke exposure (RR 2.33, 1.15–4.72). | AAPP physician training in smoking cessation counseling was effective in changing physician behavior at this institution | Int: 3 weeks
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Practice Behavior Objectives Met, Evaluation Duration Greater Than 30 Days
Stein, 2001^95^ | Int: Live, Handheld, By phone | Int: Readings, study physician visit, algorithm | Int: Multiple time or repetitive | Amount of NSAID use before and after the intervention | Practice behavior | Yes | The intervention resulted in fewer NSAIDS and more acetaminophen being used in the intervention homes (p=0.0001). | An educational intervention effectively reduced NSAID use in nursing homes without worsening of arthritis pain. | Int: 3 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Maclure, 1998^96^ | CC: NA | CC: NA | CC: NA | Pooled impact of all three interventions | Practice behavior | Yes | There was a statistically significant decrease in the prescription of calcium channel blockers (and an increase in the prescription of diuretics) | There was a general trend toward the desired effect by the educational interventions. | CC: 3 months
| Int: Live, Video | Int: Lecture, teleconference | Int: One time | | | | Increase in preference for thiazides by a factor of 1.28 (95% CI 1.02–1.61), and decrease in preference for CCBs by 0.64 (95% CI 0.41–1.0). | | Int: 3 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 3 months
| Int: Live | Int: Discussion group, Lecture | Int: NR | | | | | | Int: 3 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 3 months
| Int: Print | Int: Readings | Int: Multiple time or repetitive | | | | | | Int: 3 months
Rabin, 1998^97^ | CC: NA | CC: NA | CC: NA | Simulated patient evaluation of physician practice 3 months after the intervention | Practice behavior | Yes | The simulated patient assessment showed significant improvement in physician behaviors related to STD risk in patients in the physician group who received simulated patient instruction during the intervention. There was no significant difference between the education material only group and the control group. | Simulated patient instructors did improve performance relative to no intervention and educational materials only. However, there were still deficiencies in performance which led to the subsequent train-the-trainers intervention that was the focus of the second part of the article. | CC: NA
| Int: Print | Int: Readings | Int: NR | | | | | | Int: 3 months
| Int: Live, Print | Int: Readings, Standardized patient | Int: Multiple time or repetitive | | | | | | Int: 3 months
Rabin, 1998^97^ | CC: NA | CC: NA | CC: NA | Physician self-report of practice behaviors | Practice behavior | Yes | Physicians in the educational materials only group did not improve relative to controls. However, physicians who were in the simulated patient groups did show significant improvement in self-rated behaviors relative to the other two groups. | Simulated patient instructors did improve performance relative to no intervention and educational materials only. However, there were still deficiencies in performance which led to the subsequent train-the-trainers intervention that was the focus of the second part of the article. | CC: NA
| Int: Print | Int: Readings | Int: NR | | | | | | Int: 3 months
| Int: Live, Print | Int: Readings, Standardized patient | Int: Multiple time or repetitive | | | | | | Int: 3 months
Schwartzberg, 1997^98^ | CC: NA | CC: NA | CC: NA | Physician self-report of home care activity in their practice | Practice behavior | Yes | Physicians in the IG were statistically significantly more likely to report making house calls, referred to community agencies, and changed their office practice at 3 months. | The seminars improved physicians' attitudes toward home care, and provided a change in practice behaviors regarding home care at 3 months relative to controls. | CC: NA
| Int: Live, Print | Int: Case-based learning, Lecture, Readings | Int: One time | | | | | | Int: 3 months
Lewis, 1993^70^ | Int: Live, Video | Int: Discussion group, Lecture | Int: One time | Percentages of new patients reporting they were asked sexual history questions by their physicians (internists) | Practice behavior | Yes | There was a statistically significant increase in the proportion of new patients seen by internists at the experimental site who reported being asked sexual history questions. | These results suggest that a medical education program that goes beyond standard lectures and incorporates interactive formats can change physician behaviors. | Int: 3 months
| Int: Print | Int: Readings | Int: One time | | | | | | Int: 3 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Mehler, 2005^99^ | Int: Internet, not real time, Print | Int: Academic detailing, Readings | Int: Multiple time or repetitive | Likelihood of lipid testing | Practice behavior | Yes | They observed a 3.0 (1.62–5.66) times greater likelihood of lipid testing in the electronic group compared with the control group, adjusting for type of site and race. There was a moderate difference between the direct group and control group (P=.09); however, there was no evidence of a difference between the electronic and direct groups (P=.17). | A simple educational intervention seems to positively influence provider behavior in the area of lipid management in diabetes mellitus. Both electronic and direct detailing seem to be viable approaches. Future studies to determine optimal educational components that facilitate appropriate provider actions to initiate or intensify lipid treatment seem warranted given the burgeoning population of diabetic patients at risk for coronary heart disease morbidity and mortality. | Int: 3 months
| Int: Live, Print | Int: Academic detailing, Lecture | Int: Multiple time or repetitive | | | | Last, the change in the proportion of patients experiencing at least one of the favorable provider actions for the pre- and post-intervention periods was significantly greater in the combined direct and electronic groups versus control (P=.01). | | Int: 3 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 3 months
Rahme, 2005^100^ | Int: Live, Print | Int: Discussion group, Lecture, Readings | Int: One time | Evaluation of NSAIDS, COX_2 inhibitors and acetaminophen dispensed prescriptions | Practice behavior | Yes | There was a greater improvement in scores for both NSAIDs and COX-2 inhibitors and an increase in the number of acetaminophen prescriptions in the workshop groups over the control & decision tree groups. The Bayesian hierarchical model showed that there were improvements in all groups over time, with stronger evidence in the workshop & tree group. The adjusted odds (95% CI) of adequate prescribing in the post- versus pre-intervention periods in the workshop & tree group was 1.8 (1.3, 2.4). This odds was higher than that found in the control group 1.3 (0.9, 1.8); but, the odds ratio, 1.5 (0.9, 2.3), indicated only moderate evidence for the workshop & tree group over control. | In summary, this study found some weak evidence that an educational package in which the general practitioner shows an opportunity to discuss related issues can be more effective in changing prescribing practices compared with the distribution of guidelines. Physician attendance is, perhaps, key to the success of any interactive intervention. | Int: 5 months
| Int: Live | Int: Discussion group, Lecture | Int: One time | | | | | | Int: 5 months
| Int: Print | Int: Readings | Int: NA | | | | | | Int: 5 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Davis, 2004^101^ | Int: Live, Video, Audio, Audio teleconferencing | Int: Case-based learning, Discussion group, Problem-based learning or team-based learning | Int: Multiple time or repetitive | Change in prescribing patterns with respect to use of LTRAs | Practice behavior | Yes | A statistically significant (p<0.005) increase in LTRAs were prescribed by study physicians after the intervention compared to before the intervention while no statistically significant change in prescribing patterns of LTRAs was experienced by control physicians. | We report the first PBL-style teleconference series to demonstrate a significant change in physician prescribing habits toward better concordance with current asthma guidelines. This study demonstrated the powerful impact that the PBL format has on physician learning that actually translated into action—a measurable change in beliefs and behavior that led to changes in the number of prescriptions written by the participants. Although standard, traditional, didactic lectures remain the norm for CME across the US and credits are given for attendance, many studies have now shown that PBL is actually more effective at enhancing physicians learning. In the US, CME offices should plan more small-group workshops or teleconferences integrating the PBL format, with skilled facilitators trained to develop the cases and moderate the sessions, ultimately to improve the quality of CME in the US. | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 6 months
Herbert, 2004^102^ | Int: Live | Int: Case-based learning, Clinical experiences, Demonstration, Discussion group, Problem-based learning or team-based learning, Readings | Int: One time | Physician prescribing preference. | Practice behavior | Yes | In the 6 months following the intervention module, physicians' preference for thiazides increased by 6.8% (95% CI: 2.2%, 11.5%) after controlling for the control group's preference. The portrait was similarly associated with a 6.5% increase in preference for thiazides (95% CI: 1.8%, 11.1%). The group of physicians who received both interventions had an 11.5% increase in preference (95% CI: 4%, 18.9%). | “This study demonstrated that educational interventions with clear messages can lead to meaningful changes in physician prescribing behavior. In this trial, both interventions were associated with significant absolute increases in the use of thiazides as first-line therapy for hypertension—modules (6.8%) and portraits (6.5%). The combined intervention, consisting of both the educational module and portrait, had the strongest impact (11.5%).” | Int: 6 months
| Int: Live | Int: Clinical experiences, Feedback, Readings | Int: One time | | | | | | Int: 6 months
| Int: Live | Int: Case-based learning, Clinical experiences, Demonstration, Discussion group, Problem-based learning or team-based learning | Int: One time | | | | | | Int: 6 months
| CC: Live | CC: NA | CC: One time | | | | | | CC: 6 months
Beaulieu, 2004^44^ | Int: Live, Print | Int: Case-based learning, Discussion, group, Problem-based learning or team-based learning, Programmed learning, Readings | Int: One time | Medication prescriptions | Practice behavior | Yes | In ITT analysis, there was an adjusted statistically significant 8% improvement (p=0.003) on mean scores (scores to evaluate impact on medication prescription) between both the control group and the workshop and workshop and decision tree groups combined. (PP analysis showed a 12% improvement (p=0.008)). | “The results of the initial evaluations have demonstrated that these evidence-based interventions were successful not only in improving physicians' knowledge regarding the diagnosis and management of OA, but also—more importantly—in changing their behavior to make more appropriate therapy choices for their patients. The observed modification of their prescription patterns reflects an improvement in their medical practice, which may lead to better patient outcomes and generate greater cost efficiencies for the health care system.” | Int: 6 months
| Int: Live | Int: Case-based learning, Discussion group, Problem-based learning or team-based learning, Readings | Int: One time | | | | | | Int: 6 months
| Int: Print | Int: Discussion group, Programmed learning, Readings | Int: One time | | | | | | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 6 months
Cohn, 2002^19^ | Int: Live, Print | Int: Academic detailing | Int: Multiple time or repetitive | Provider practices | Practice behavior | Yes | Data show evidence that the intervention group providers improved their practices about asking about DES while the control group didn't improve. No mention of statistical significance was made. | “Academic detailing can increase DES knowledge and history taking among primary care providers.” | Int: 3–6 months
| Int: Live, Print | Int: Academic detailing | Int: Multiple time or repetitive | | | | | | Int: 3–6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 3–6 months
Lane, 2001^45^ | Int: Live | Int: Lecture, Standardized patient | Int: One time | One main outcome measure was whether or not physicians referred 90–100% of women over age 50 to get a mammogram every 1–2 years. The other main outcome was a reduction in the score of needing the CME activity (improved knowledge and understanding) | Knowledge | Yes | There was improvement in the need for CME scores of more physicians in the intervention group than the control group. The intervention significantly improved knowledge and behaviors about breast cancer screening practices. | Participation in the CME activity improved physicians' awareness, knowledge, and behaviors regarding clinical breast exams and breast cancer screening practices, as compared to a control group. | Int: 6 months
| CC: NA | CC: NA | CC: NA | | Practice behavior | Yes | | | CC: NA
Norris, 2000^81^ | Int: Live, Print, F/U phone calls about protocol | Int: Lecture, Point of care, Opinion-leader from clinic teaching | Int: Multiple time or repetitive | Physician behavior in counseling patients about physical activity, as reported on patient questionnaire | Practice behavior | Yes | Both intervention and control physicians asked and counseled about physical activity more frequently at 6-month follow-up, but the increase was significantly higher for intervention providers (p=0.001). Inquiring change from baseline to f/u: intervention 48–>79% vs. control 64–>64% inquiring. Counseling change from baseline to followup: intervention 42–>94% vs. control 55–>81%. | “A one-time PACE counseling session with minimal reinforcement, in a setting with high baseline levels of activity, does not further increase activity ... Contemplators advanced in stage of behavior change.” | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Brown, 1999^72^ | Int: Live | Int: Clinical experiences, Discussion group, Lecture, Role play, Clinicians audiotaped interaction with patients and listened between workshops | Int: Multiple time or repetitive | Self-assessment of clinicians' communication skills, attitudes, and behavior, as measured by participant questionnaire | Attitudes | Yes | Intervention group noted substantial improvements compared with control in 8 of 24 skills / attitudes / behaviors: awareness of and confidence in dealing with patients whom they found difficult; abilities to compliment patients' efforts, ask open-ended questions, address psychosocial factors, express empathy and reassurance, and clarify expectations. 33% of clinicians reported that fewer than 5% of visits were frustrating after the program (compared with 21% of clinicians at baseline). Three months after the program, clinicians in the intervention group reported that it had improved communication with patients. On average, however, the scores for clinicians' rating of improvement in patient satisfaction and improvement in clinicians' personal satisfaction in their work decreased below the midpoint on the five-point scale (mean rating, 2.85 for both items). | “Thriving in a Busy Practice: Physician-Patient Communication,” a typical continuing medical education program geared toward developing clinicians' communication skills, is not effective in improving general patient satisfaction. To improve global visit satisfaction, communication skills training programs may need to be longer and more intensive, teach a broader range of skills, and provide ongoing performance feedback. | Int: >=6 months
| CC: NA | CC: NA | CC: NA | | Skills (psychomotor or procedural skills) | Yes | | | CC: NA
| | | | | Practice behavior | Yes
Gifford, 1996^46^ | Int: Video, Print | Int: Programmed learning, Readings | Int: Multiple time or repetitive | Neurologists adherences to practice recommendations for movement disorders, as measured by test | Practice behavior | Yes | For 9 of the 16 recommendations, a higher proportion of the intervention group compared with controls reported clinical decisions that were adherent to the practice recommendations; for all 9 differences p<.05. Range of adherence for intervention was 41–98% and for control 22–97%. | The educational course improved neurologists' reported decision-making. | Int: 4–5 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 4–5 months
Anderson, 1996^103^ | Int: Live, Video | Int: Case-based learning, Discussion group, Lecture | Int: One time | Change in physician prescribing patterns of regulated drugs | Practice behavior | Yes | There was a 33% reduction in the number of prescriptions written in the education plus notification group, a 25% reduction in the notification only group, and a slight increase in the control group. Both the education plus notification and notification only groups wrote significantly fewer prescriptions than the control group (p<0.003 and p<0.008 respectively). There was not a significant difference between the number of prescriptions written by the education plus notification group and the notification only groups (p<0.719). | Notification that the number of prescriptions they had written was abnormally high was as effective in significantly reducing the number of prescriptions written during the subsequent 6 months as notification combined with a well-designed group-education activity. | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Maiman, 1988^47^ | Int: Live, Print | Int: Discussion group, Lecture, Readings | Int: Multiple time or repetitive | Mother report of quantity of physician compliance enhancing behavior | Practice behavior | Yes | Significant association between study group and extent of behaviors reported by mothers (patients). | CME increased physician knowledge and compliance-enhancing practices and resulted in improvement in mothers' adherence to therapy. | Int: 6 months
| Int: Print | Int: Readings | Int: One time | | | | | | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
White, 1985^48^ | Int: Live | Int: Case-based learning, Discussion group, Lecture | Int: One time | Desired patient care practices in hospital care of patients with acute myocardial infarction, as measured by chart review | Practice behavior | Yes | Intervention group had statistically significantly higher percent of desired care practices (60%, 56.6–63.3) vs. control group (46.3%, 40.4–52.3)[p-value <0.001 for post-test comparisons). Intervention group had statistically significant gains in 3 of 8 objectives: prophylactic use of lidocaine, avoidance of intramuscular medications, and appropriate length of stay. | “A carefully conceived and executed traditional CME program can result not only in significant increases in physician's knowledge but also in related changes in their patient care practices” ... “both knowledge and behavioral change can persist for at least 6 months” | Int: 6 months
| CC: Live, NA | CC: NA | CC: NA | | | | | | CC: NA
| Int: Live | Int: NR | Int: One time | | | | | | Int: 6 months
| Int: Live | Int: NR | Int: One time | | | | | | Int: 6 months
Terry, 1981^49^ | Int: Live, Audio, Print | Int: Case-based learning, Discussion group, Feedback, Lecture, Readings | Int: Multiple time or repetitive | Skill and behavior in COPD management, as measured by analysis of audiotaped standardized patient (SP) interaction | Practice behavior | Yes | Physicians were not blinded due to audiotaping. Intervention and control groups did not differ on diagnostics / therapeutics scores, but intervention group used strategies for patient understanding and compliance more frequently (37% vs. 22%, p<0.01)[9 of 16 specific tasks significantly improved - explaining how medications would help, instructing on use of medications, repeating / summarizing / answering, discussing benefits of smoking cessation]. | Physicians completing a home study AV program increased knowledge about diagnosis and treatment of COPD, but their behavior in simulated exercises was not different from controls. Experimental group physicians did use more patient-education and smoking cessation information during patient visits. Group meetings for needs assessment and feedback (given 2 weeks after tests) had no apparent effect beyond the audiovisual materials. | Int: 6 months
| Int: Live, Audio, Print | Int: Case-based learning, Discussion group, Lecture, Readings | Int: Multiple time or repetitive | | | | | | Int: 6 months
| Int: Audio, Print | Int: Case-based learning, Feedback, Lecture, Readings | Int: Multiple time or repetitive | | | | | | Int: 6 months
| Int: Live, Audio, Print | Int: Case-based learning, Lecture, Readings | Int: Multiple time or repetitive | | | | | | Int: 6 months
| CC: Audio, Print | CC: Case-based learning, Lecture, Readings | CC: Multiple time or repetitive | | | | | | CC: 6 months
Chodosh, 2006^62^ | Int: Live, Internet, not real time, Print | Int: Discussion group, Lecture | Int: Multiple time or repetitive | Quality of care, as measured by adherence to guidelines (as reported in prior manuscript) | Practice behavior | Yes | Intervention group had significantly higher rates of guideline-adherent care for 21 of 29 care processes (e.g., management of behavior problems, use of respite, development of ongoing treatment plan) than usual care group (all p<0.05) at 1-year followup. | Despite a successful intervention demonstrating significant improvements in quality of care for patients with dementia, providers' knowledge and attitudes were minimally affected. | Int: 9 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Ozer, 2005^104^ | Int: Live, Print | Int: Discussion group, Lecture, Role play, Screening and charting tools | Int: One time | Screening rates | Practice behavior | Yes | Screening rates for different health behaviors (tobacco use, alcohol use, drug use, sexual behavior, seatbelt and helmet use) increased after the first intervention but remained stable after the second intervention (of screening and charting tools) compared to the comparison group. | The results of the ANCOVAs demonstrated that (1) screening and counseling rates were significantly higher in the intervention group than in the comparison group after the full implementation of the intervention (T2); (2) screening and counseling rates were significantly higher in the intervention group than in the comparison group after the training component alone (T1); and (3) screening and counseling rates did not increase significantly in the intervention group, in relation to the comparison group, after the addition of the tools component. | Int: 8 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Ozer, 2005^104^ | Int: Live, Print | Int: Discussion group, Lecture, Role play, Screening and charting tools | Int: One time | Counseling rates | Practice behavior | Yes | Counseling rates for different health behaviors (tobacco use, alcohol use, drug use, sexual behavior, seatbelt and helmet use) increased after the first intervention but remained stable after the second intervention (of screening and charting tools) compared to the comparison group. | The results of the ANCOVAs demonstrated that (1) screening and counseling rates were significantly higher in the intervention group than in the comparison group after the full implementation of the intervention (T2); (2) screening and counseling rates were significantly higher in the intervention group than in the comparison group after the training component alone (T1); and (3) screening and counseling rates did not increase significantly in the intervention group, in relation to the comparison group, after the addition of the tools component. | Int: 8 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Soumerai, 1987^105^ | Int: Live, Print | Int: Academic detailing, Readings, Brochures | Int: Multiple time or repetitive | To reduce inappropriate prescribing of 3 target drugs. | Practice behavior | Yes | Reduction in prescribing was highly significant -8 to -20%, p<.025) in 11 of the 14 physician groups. The presence of a followup reinforcement visit was strong independent predictor of prescribing change (p<0.05) | Face to face pharmaceutical education is an effective quality-assurance and cost-containment strategy for a wide variety of physicians, regardless of their background and baseline prescribing practices. | Int: 9 months
| Int: Print | Int: Readings, Brochures | Int: Multiple time or repetitive | | | | | Reinforcement visits may be necessary to achieve economically or clinically important improvements in physician drug prescribing patterns. An increase from one visit to 2 visits was associated with an approximate doubling of the size of the program effect. | Int: 9 months
| CC: NA | CC: NA | CC: NA | | | | | Long visits with physicians (more than 10–15 minutes) do not appear to increase prescribing improvements. | CC: 9 months
Chassin, 1986^106^ | Int: Live, Print | Int: Feedback, Lecture, 16 of 64 hospitals received only print mailings to physicians with privileges, without lecture | Int: One time | Pelvimetry rates, as measured by chart abstraction from radiology and obstetrical delivery logs | Practice behavior | Yes | Intervention group hospitals had 86% reduction in pelvimetry rate compared with 53% in control group (p<0.00001). Findings slightly tempered by increased baseline pelvimetry rate in control group (p<0.001) and general trend toward decreased pelvimetry in both groups prior to intervention. | An educational program followed by feedback of data can markedly improve physician performance by decreasing inappropriate pelvimetry at a hospital level. | Int: 10 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Perera, 1983^107^ | Int: Live | Int: Clinical experiences, Demonstration | Int: One time | Sigmoidoscopy rate and sigmoidoscopy: barium enema ratio, as measured by clinic nurses before and after training | Practice behavior | Yes | Baseline rates were similar between two intervention groups and control. Intervention group had significantly higher post-intervention sigmoidoscopy rate (13.5/1000 vs. 9.8/1000 pre-intervention, p <0.05). The rate in the intervention group declined to 11.1/1000 by 7–10 months. The group receiving training later increased from 6.2 to 8.4/1000, and the control decreased from 8.5 to 7.4/1000. The sigmoidoscopy to barium enema ratio significantly increased in first study group from 0.62 to 0.90 (p < .05). The second study group increased from 0.59 to 0.79, and the control group decreased from 0.69 to 0.67. | “program increases the rate of sigmoidoscopies done by physicians and improves the process of medical care (at least over the short term)” | Int: 7–10 months
| Int: Live | Int: Clinical experiences, Demonstration | Int: One time | | | | | | Int: 3 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Schectman, 2003^108^ | Int: Live, Video, Print | Int: Lecture, Readings | Int: Multiple time or repetitive | Physician behaviors: the adherence of utilization services to guidelines for low back pain. | Practice behavior | Yes | There was a significant increase in guideline-consistent behavior among intervention physicians while there was a decrease in the control group. | “An intervention based on accepted strategies of physician education, practice audit with performance feedback, and peer opinion leader use produced a modest but significant increase in physician actions consistent with a clinical guideline for the care of acute low back pain.” | Int: 1 year
| CC: Video, Print, NA | CC: NA | CC: NA | | | | | | CC: 1 year
Ray, 2001^109^ | Int: Live, Print | Int: Academic detailing, Readings, Chart reminders | Int: Multiple time or repetitive | Change between baseline and follow-up years in: days of prescribed NSAIDs, acetaminophen, other drugs for musculoskeletal disorders, and GI drugs; outpatient visits and inpatient days of stay | Practice behavior | Yes | Intervention-attributable reduction of 7% (95% CI, 3% to 11%) in days of prescribed NSAIDs use with concomitant increase in acetaminophen use. | The educational program modestly reduced NSAID exposure in community-dwelling elderly patients without undesirable substitution of other medications or detectable worsening of musculoskeletal symptoms. | Int: 1 year
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Dietrich, 2000^110^ | Int: Live, Print, Telephone call | Int: Academic detailing, Lecture, Problem-based learning or team-based learning, Readings | Int: Multiple time or repetitive | Percent of parents counseled on sun protection by clinicians, as measured by parent self-report survey | Practice behavior | Yes | Intervention community parents reported similar rates of counseling to control parents (25% and 26%, p=0.68), but significantly higher counseling after intervention (34% vs. 27%, p=0.03). | The SunSafe primary care intervention increased sun protection counseling activities of participating clinicians. Conclusions limited by participation rate in survey (69% for baseline survey; of intervention community clinicians who participated in baseline, only 59% on f/u survey). Also unclear what component of parent report may relate to other community interventions, rather than practice intervention. | Int: about 1 year
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Dietrich, 2000^110^ | Int: Live, Print, Telephone call | Int: Academic detailing, Lecture, Problem-based learning or team-based learning, Readings | Int: Multiple time or repetitive | Improvement from baseline in provision of sun protection services to patients /families, as measured by clinician self-report | Practice behavior | Yes | Greater improvement for intervention vs. control clinicians in the availability of educational materials (91% vs. 43%, p=0.02), distribution (74% vs. 0%, p=0.001) of educational materials, and distribution of sunscreen samples (69% vs. 13%, p=0.02). Unclear if intention-to-treat analysis done for providers in intervention communities who declined to participate in practice intervention. Consideration of baseline practices unclear in the calculation of “improvement from baseline.” | The SunSafe primary care intervention increased sun protection counseling activities of participating clinicians. Conclusions limited by participation rate in survey (69% for baseline survey; of intervention community clinicians who participated in baseline, only 59% on f/u survey). Also unclear what component of parent report may relate to other community interventions, rather than practice intervention. | Int: about 1 year
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Schroy, 1999^82^ | Int: Live | Int: Academic detailing, Discussion group, Lecture | Int: One time | Provider utilization of screening sigmoidoscopy as determined by appointment schedules | Practice behavior | Yes | Use of on-site sigmoidoscopy was monitored by review of appointment schedules every 3 months after initiation of the program (for the intervention sites). Use of outside sigmoidoscopy services was monitored through the NHC's scheduling secretary and/or contact with all off-site endoscopists identified by referring primary care providers. There was substantial agreement between self-reported compliance rates and actual utilization; namely, 78% of those reporting compliance with sigmoidoscopy recommendations actually referred 1 or more asymptomatic average-risk persons for screening examinations. 90% of those reporting noncompliance were not referring patients for screening. Overall compliance, using utilization as the outcome of interest, was 47% in the intervention group, vs. 4% in the comparison group at year 1 (p<0.001). | “In summary, this study clearly shows that academic detailing in the form of an outreach didactic educational seminar followed by the implementation of on-site sigmoidoscopy services is an effective strategy for enhancing provider compliance with screening guidelines.” | Int: 1 year
| CC: NA | CC: NA | CC: NA | | | | | | CC: 1 year
Gonzales, 1999^111^ | Int: Live, Print | Int: Academic detailing, Demonstration, Lecture, Point of care | Int: One time | Antibiotic prescriptions for incident visits | Practice behavior | Yes | Full intervention demonstrated a significant decrease in the number of prescriptions. Other groups did not show a significant difference. | Antibiotic treatment of adults diagnosed as having uncomplicated acute bronchitis can be safely reduced using a combination of patient and practitioner interventions. | Int: 1 year
| Int: Print | Int: Academic detailing, Point of care | Int: NA | | | | | | Int: 1 year
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Cummings, 1989^112^ | Int: Live, Video, Print | Int: Demonstration, Discussion group, Lecture, Role play | Int: Multiple time or repetitive | Effectiveness of smoking cessation counseling | Practice behavior | Yes | Physicians participating in the intervention increased their effectiveness of smoking cessation counseling. Specifically, they discussed cessation with patients more often and longer, set more quit dates, and gave out more self-help materials. | Intervention physicians discussed smoking at a greater rate than did control physicians. Intervention physicians spent more time discussing smoking with their patients. More smoking patients of the intervention physicians set quit dates and had more follow-up with their physicians. Rates of smoking cessation among patients at one year were no different between control and intervention physicians. | Int: 1 year
| CC: NA | CC: NA | CC: NA | | | | | | CC: 1 year
Cummings, 1989^113^ | Int: Live, Video, Print | Int: Case-based learning, Demonstration, Discussion group, Lecture, Role play | Int: Multiple time or repetitive | Effectiveness of smoking cessation counseling | Practice behavior | Yes | Physicians involved in the intervention improved aspects of their smoking cessation counseling. Specifically, they were more likely to set quit dates, were more likely to use nicotine gum appropriately, spent more time discussing smoking cessation with patients, and gave out more self-help brochures. | Intervention physicians discussed smoking cessation at a higher rate than did control physicians. They spent more time discussing smoking overall, and more of their patients set quit dates. Overall, smoking cessation rates of patients at one year did not differ between groups. | Int: 1 Year
| CC: NA | CC: NA | CC: NA | | | | | | CC: 1 year
Kottke, 1989^114^ | Int: Live, Print | Int: Demonstration, Discussion group, Lecture, Readings | Int: One time | Physician behaviors regarding counseling for smoking cessation | Practice behavior | Yes | Patients of physicians in the workshop group and materials-only group reported their physicians were more likely to have asked them to quit smoking (p < 0.025)and were more likely to report agreeing to quit smoking (p < 0.025) when compared to the control group. Patients of physicians in the workshop group report they were asked to set a quit date (p < 0.005) compared to materials-only group and control group. There was no difference between groups regarding patient reports of being asked if they smoked and patients being given follow-up appointments. | A brief training program and/or the distribution of education materials marginally increased smoking cessation behaviors among volunteer physicians but did not result in increased smoking cessation rates at one year. | Int: 1 year
| Int: Print | Int: Readings | Int: Amount of exposure determined by participant | | | | | | Int: 1 year
| CC: NA | CC: NA | CC: NA | | | | | | CC: 1 year
Jennett, 1988^76^ | Int: Live, Print, Teleconference | Int: Discussion group, Feedback, Mentor/Preceptor, Readings | Int: Multiple time or repetitive | Percentage of recommended behaviors in cancer medicine carried out at the specified time period | Practice behavior | Yes | The performance of study offices improved 6 months following the education by 35%. | A carefully planned CME program, adhering to essential learning principles, was effective in changing office practice of volunteer doctors as long as 12 months after the intervention. | Int: 12 months
| Int: Live, Print, Teleconference | Int: Discussion group, Feedback Mentor/Preceptor, Readings | Int: Multiple time or repetitive | | | | | | Int: 12 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 12 months
Jennett, 1988^76^ | Int: Live, Print, Teleconference | Int: Discussion group, Feedback, Mentor/Preceptor, Readings | Int: Multiple time or repetitive | Performance of recommended behaviors in cardiovascular medicine carried out at the specified time period | Practice behavior | Yes | Performance of recommended behaviors in study offices improved 44.5% as compared to controls, 4.0%. | A carefully planned CME program, adhering to essential learning principles, was effective in changing office practice of volunteer doctors as long as 12 months after the intervention. | Int: 12 months
| Int: Live, Print, Teleconference | Int: Discussion group, Feedback Mentor/Preceptor, Readings | Int: Multiple time or repetitive | | | | | | Int: 12 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 12 months
Harris, 2005^75^ | Int: Live, Audio, Print, Teleconference | Int: Case-based learning, Lecture, Readings | Int: Multiple time or repetitive | Documentation of tests performed | Practice behavior | Yes | Significantly more patient records in the intervention group had documentation of BMI, eye exams, communication of a treatment plan, and used a flow sheet. | CME delivered by teleconference was feasible, well attended, well received by participants, and improved some key diabetes management practices and outcomes, although primary goal of improving HbA1C was not achieved. | Int: 12 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Lindsay-McIntyre, 1987^115^ | Int: Print | Int: Point of care | Int: Multiple time or repetitive | Smoking cessation counseling behaviors by family physicians, as measured by chart review using intervention flowsheet (intervention) or medical records (control) | Practice behavior | Yes | Physician discussed smoking in 85.4% of patients of trained physicians, vs. 70.2% of gum-only physicians and 31.1% of usual care physicians. Gum offered by >60% of gum-only and trained physicians vs. 9% for usual care physicians. Trained physicians reported patients wanted to see them again more often and to offer take-home materials compared with gum only or usual care. (p-values NR) | Nicotine gum with chart cues helped stimulate patient smoking cessation attempts, but physician training in counseling with a more intensive flowsheet produced more successful short-term cessation. | Int: 1 year
| Int: Live, Video, Print | Int: Demonstration, Lecture, Point of care, Standardized patient | Int: Training 1 time, cueing with each patient | | | | | | Int: 1 year
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Stross, 1985^116^ | Int: Live, Print, “Audiovisual materials” | Int: Feedback, Readings, Use of “educationally influential” physician | Int: Multiple time or repetitive | Inpatient care of osteoarthritis patients, as measured by chart audit of hospital and outpatient data | Practice behavior | Yes | Intervention hospitals had statistically significant (all p<0.05) increased use of intraarticular corticosteroids (40% vs. 11%), decreased use of systemic steroids (3% vs. 22%), and increased pre-op PT (97% vs. 40%) compared with control; non-significant in 8 other areas, including pre-op / post-op management and length of stay. Use of intraarticular corticosteroids also increased in outpatients in intervention vs. control (23.9% vs. 14.6%, p<0.05). | Educationally influential physician peers may influence use of intraarticular and systemic steroids in osteoarthritis management within their communities. | Int: 1 year
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Cummings, 1989^117^ | Int: Live, Video, Patient education materials | Int: Case-based learning, Demonstration, Role play, Self-reflection | Int: Multiple time or repetitive | Physician smoking cessation counseling behaviors, as measured by patient interviews | Practice behavior | Yes | Intervention group was more likely to discuss smoking with patients who smoked (64% vs. 44%), spent more time counseling smokers about quitting (7.5 vs. 5.2 minutes), helped set more quit dates (29% vs. 5%), gave out more booklets (37% vs. 9%), and more likely to make followup appointments about quitting (19 vs. 11%). | 3-hour continuing education program combined with supportive materials for offices changed the way physicians in private practice counseled about smoking, but had no statistically significant effects on patient outcomes. Some significant differences physicians and patients in intervention vs. control group related to drop-out, but adjustment for factors did not affect outcomes. | Int: 1 year
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Schroy, 1999^82^ | Int: Live | Int: Academic detailing, Discussion group, Lecture | Int: One time | Provider attitudes or practices related to colorectal cancer screening as determined from a pre-educational vs. post-educational survey instrument, based on an instrument that was similar to one used by the American Cancer Society in 1989 | Attitudes | Unclear | At year 1, there were no significant differences in concern about patient fear and discomfort, time, procedural skills, or cost. However, the mean scores for equipment availability, efficacy, and yield were all significantly higher in the noncompliant group than the compliant group (p = 0.001). Most of the compliant providers were at the intervention sites, which indicate that availability of on-site screening may trump perceived barriers for sigmoidoscopy adherence. At baseline, 24% of providers at intervention sites, and 19% at comparison sites, reported recommending screening sigmoidoscopy. Significant differences in compliance were observed at the year 1 follow-up survey. Overall self-reported compliance rates increased by 36% at the intervention site, vs. 7% at the comparison site (p = 0.001). | “In summary, this study clearly shows that academic detailing in the form of an outreach didactic educational seminar followed by the implementation of on-site sigmoidoscopy services is an effective strategy for enhancing provider compliance with screening guidelines.” | Int: 1 year
| CC: NA | CC: NA | CC: NA | | Practice behavior | Yes | | | CC: 1 year
Margolis, 2004^118^ | Int: Live, Organized set of tools otherwise unspecified | Int: Academic detailing, Feedback, Lecture, Unspecified organized set of tools | Int: Multiple time or repetitive | Proportion of children who received all four preventive services (immunizations and screening for anemia, lead, and tuberculosis) | Practice behavior | Yes | The change in the prevalence of all four services between the beginning and end of the study was 4.6 fold greater (95% CI 1.6 to 13.2) in the intervention practices than in the control practices. | A continuing education program designed to assist primary care practices in testing and implementing office systems for preventive health care produced clinically and statistically significant improvement in rates of preventive care for children. | Int: 18 months (30 months-12 months of implementation)
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
McClellan, 2003^119^ | Int: Video, Print | Int: Feedback, Readings | Int: Multiple time or repetitive | HbA1c tests ordering | Practice behavior | Yes | Statistically significant increase | “The main result of our study was that a population-based quality improvement intervention based on applying the HCQIP model to ambulatory care was associated with improved processes of care of diabetes mellitus.” | Int: 1.5–2 years
| CC: NA | CC: NA | CC: NA | | | | | | CC: 1.5–2 years
McClellan, 2003^119^ | Int: Video, Print | Int: Feedback, Readings | Int: Multiple time or repetitive | Usage related to physician behavior in monitoring diabetic patients | Practice behavior | Yes | Usage of HbA1c testing increased among both the intervention and control groups; usage among the intervention group was statistically significantly greater than the control group (p=0.02 unadjusted, p=0.03 adjusted). Other indicators (eye examinations, urine testing) also increased in both groups, though the differences between intervention and control were positive, but not statistically significant. | “The main result of our study was that a population-based quality improvement intervention based on applying the HCQIP model to ambulatory care was associated with improved processes of care of diabetes mellitus.” | Int: 1.5–2 years
| CC: NA | CC: NA | CC: NA | | | | | | CC: 1.5–2 years
Mann, 1997^52^ | Int: Live, Video, Print | Int: Case-based learning, Demonstration, Discussion group, Readings, Simulation (other than standardized patient or role-play) | Int: Multiple time or repetitive | Physicians dietary counseling practices, as measured by self-report. | Practice behavior | Yes | Physicians in both intervention groups scored statistically significantly higher than the controls in dietary counseling practice evaluation (p=0.0005). | Educational training workshops appear to be effective in changing physician behavior, and should thus, be continued along with additional research on the mechanisms of which behavior change occurs. | Int: 15 months
| Int: Live, Video, Print Cue stickers on medical chart | Int: Case-based learning, Demonstration, Discussion group, Point of care, Readings, Simulation (other than standardized patient or role-play) | Int: Multiple time or repetitive | | | | | | Int: 15 months
| CC: NA | CC: NA | CC: NR | | | | | | CC: 15 months
Clark, 1998^120^ | CC: NA | CC: NA | CC: NA | Impact if intervention on physician self-report of practice behaviors at 5 months | Practice behavior | Yes | Physicians in the intervention group were significantly more likely to use anti-inflammatory agents, address fears about meds, give written instructions, how to adjust meds in flair. Interestingly, intervention physicians also reported spending less time with asthma patients. | The intervention had a positive impact on both physician and parent reported behaviors, and patient outcomes were also positively impacted by the intervention. In addition, the impact appeared to be more than just that resulting from the increased use of anti-inflammatory medication and the change in practice behavior and the disease management model seems to be important as well. | CC: 22 months
| Int: Live, Video | Int: Case-based learning, Clinical experiences, Lecture | Int: Multiple time or repetitive | | | | | | Int: 22 months
Clark, 1998^120^ | CC: NA | CC: NA | CC: NA | Parent (patient) views of physician behavior | Practice behavior | Yes | Intervention physicians were statistically significantly more likely to be reassuring and encouraging, stating a goal that the child be active, were more likely to have prescribed anti-inflammatory medication, and to have provided a written plan. | The intervention had a positive impact on both physician and parent reported behaviors, and patient outcomes were also positively impacted by the intervention. In addition, the impact appeared to be more than just that resulting from the increased use of anti-inflammatory medication and the change in practice behavior and the disease management model seems to be important as well. | CC: 22 months
| Int: Live, Video | Int: Case-based learning, Clinical experiences, Lecture | Int: Multiple time or repetitive | | | | | | Int: 22 months
Moran, 1996^121^ | Int: Live | Int: Case-based learning Discussion group | Int: Multiple time or repetitive | Changes in score for dimensions of care (clinical patient care), charting, prevention, and drug use | Practice behavior | Yes | Average scores increased significantly and approached average Manitoba scores by 18 months. | This study demonstrates the feasibility of improving physician performance through a form of CME that is designed to be supportive, non-punitive, and learner-focused. | Int: 18 months
| CC: Live | CC: Case-based learning Discussion group | CC: Multiple time or repetitive | | | | | | CC: NR
Browner, 1994^122^ | Int: Live, Print | Int: Lecture, Readings | Int: One time | Proportion of patients with high cholesterol management in compliance with NCEP recommendations | Practice behavior | Yes | Trend toward better compliance in the two CME groups (p=.07). Compliance rates were 6% higher (95% CI 1% –11%, p=.02) in the intensive CME group than in the control group. | CME was not particularly effective in improving compliance with NCEP guidelines among non university affiliated community physicians who practice primary care. | Int: 18 months
| Int: Live, Print | Int: Academic detailing, Case-based learning, Lecture, Point of care, Readings | Int: Multiple time or repetitive | | | | | | Int: 18 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Rodney, 1986^77^ | Int: Live, Video | Int: Demonstration, Lecture, Simulation (other than standardized patient or role-play) | Int: One time | Behavior related to flexible sigmoidoscopy use, as measured by phone or written survey | Attitudes | Yes | Small group learners were more likely to acquire additional training and teaching attachments for their sigmoidoscopes, and less likely to use small (35 cm) scopes; there was no difference in biopsy utilization. 90% of large group learners acquired scopes after training vs. 40–56% of small groups. Small groups were associated with shorter procedure times (p<0.05) for first 10 procedures, but otherwise no differences in times, insertion depths, or number of exams performed. Compared to a randomly surveyed group of physicians, those with CME were significantly more likely to perform flexible sigmoidoscopy. | Physicians who participate in courses in flexible sigmoidoscopy have a higher probability of office utilization of these skills than those who do not take courses. Minimal differences found between large and small group CME formats. | Int: 12–18 months
| Int: Live, Video | Int: Demonstration, Lecture, Simulation (other than standardized patient or role-play) | Int: One time | | Cognitive skills | No | | | Int: 12–18 months
| CC: NA | CC: NA | CC: NA | | Practice behavior | Yes | | | CC: NA
Bunting, 2004^123^ | Int: Live, Print | Int: Feedback, Readings | Int: Multiple time or repetitive | Physician laboratory test ordering behavior | Practice behavior | Yes | Though both intervention and control group test utilization rate declined soon after the intervention, both also showed trends back towards baseline values with increasing time post intervention. However, the intervention group declined to a greater degree than the control group (which had nonsignificant reductions compared to baseline), and a 7.9% (p<0.0001) relative reduction resulted from the intervention. | “We found that a multifaceted education and feedback strategy significantly and persistently decreased laboratory utilization among practicing community physicians. In conclusion, this study showed a statistically significant effect of a simple feedback and education intervention on the ordering of laboratory tests by high-volume community physicians.” | Int: 2 years
| CC: NA | CC: NA | CC: NA | | | | | | CC: 2 years
Clark, 2000^78^ | Int: Live, Video | Int: Case-based learning, Demonstration, Lecture | Int: Multiple time or repetitive | Physician behavior change in teaching patients and increase in communication skills | Practice behavior | Yes | Intervention physicians were more likely to use protocols for delivering asthma education (OR 4.9, p=.2), write down for patients how to adjust medicines when symptoms change (OR 5.8, p=.05), and provide more guidelines for modifying therapy (OR 3.8, p=0.06). | Participating physicians reported that they communicated and taught patients in a more sophisticated way. Parents of intervention patients reported that physicians used a range of communication and education strategies to enhance patient learning and satisfaction. Intervention patients showed a decrease in hospitalization. | Int: 2 years
| CC: NA | CC: NA | CC: NA | | | | Increase in communication skills in the intervention group: more wrote down dose adjustment and timing info for patients; provided guidelines for patients to use when conditions change. No difference in the amount of time physicians spent with patients between groups and no difference in the proportion of physicians prescribing anti-inflammatories. | | CC: 2 years
Gerstein, 1999^53^ | Int: Live | Int: Case-based learning, Discussion group | Int: One time | Knowledge, attitudes, and practice behavior regarding diabetes care, based on participant questionnaire | Knowledge | Yes | After 40 days, participants' overall scores improved significantly while there was no change in the controls' scores (F =24.14; p<0.0001). Significant improvement was also noted in domains of attitude (F=31.75; p<0.0001), knowledge (F=4.23; P =0.041), and practice behavior (F=10.43; p=0.0014). | An interactive, small group, diabetes continuing education program effectively disseminates practice guidelines to family physicians. The impact of such a program declines after 1 year. | Int: 24 months
| CC: NA | CC: NA | CC: NA | | Attitudes | Yes | However, improvement was not apparent after a year. Participants who completed 425-day assessment scored lower in attitude subscale compared to controls, despite having initially scored higher at the 40-day assessment. | | CC: NA
| | | | | Practice behavior | Yes
Ockene, 1996^124^ | CC: NA | CC: NA | CC: NA | Mean number of physician nutrition counseling steps | Practice behavior | Yes | Physicians who received both the nutrition counseling training and the practice management system performed, on average, more counseling steps (adjusted mean = 6.28 out of a possible 10 steps, p<0.0001). Those who received no intervention or who received nutrition counseling training only performed fewer steps. | Primary care internists, when provided with both training in counseling techniques and a supportive office environment, will carry out patient counseling appropriately. Training alone, however, is not sufficient and may be counterproductive. | CC: NA
| Int: Live, Video | Int: Feedback, Lecture, Role play, Standardized patient | Int: 2 types of training sessions, each provided once | | | | | | Int: evaluation was conducted over a 2 year time span
| Int: Live, Video | Int: Feedback, Lecture, Role play, Standardized patient | Int: 2 types of training sessions, each provided once | | | | | | Int: evaluation was conducted over a 2 year time span
Adams, 1998^125^ | CC: Live | CC: Lecture | CC: NR | Impact of educational intervention on patient exit interview rating of physician counseling behaviors | Practice behavior | Yes | There was a statistically significant increase in physician counseling ratings by patients in the intervention group. The mean number of patient exit interview steps completed (total possible 15) was 2.4 in Usual Care group vs. 10.3 in Special Intervention group (p = .0001) In addition, this effect remained constant for the full 32 months that patients exit interviews continued to be monitored. | The educational intervention did improve patient-rated physician performance of counseling on alcohol use. | CC: 32 months
| Int: Live | Int: Lecture, Mentor/Preceptor, Office system: cuing | Int: Multiple time or repetitive | | | | | | Int: 32 months
Myers, 2004^148^ | Int: Live, Audio, Print | Int: Academic detailing, Feedback, Lecture, Readings | Int: Multiple time or repetitive | Complete diagnostic exam (CDE) performance rates | Practice behavior | Yes | CDE performance rates for eligible patients increased for both intervention and control group, but only to a statistically significant degree among the intervention group (adjusted post/pre OR = 1.71, p<0.03). Intervention to control group OR of CDE recommendation was 1.63, p=0.03. | “Use of a physician-oriented intervention substantially and significantly increased CDE recommendation and performance in Intervention Group practices as compared to Control Group practices. These findings demonstrate that targeting PCPs for delivery of a combined CDE reminder feedback and educational outreach intervention can have a meaningful impact on physician behavior and patient followup in colorectal cancer screening. It is notable that the magnitude of the intervention impact was greater for CDE recommendation than CDE performance. The intervention also had a statistically significant impact on CDE recommendation rates when the combined timeframe (Periods 2 and 3) was compared to Period 1.” | Int: 6 years
| CC: NA | CC: Readings | CC: NA | | | | | | CC: 6 years
Myers, 2004^148^ | Int: Live, Audio, Print | Int: Academic detailing, Feedback, Lecture, Readings | Int: Multiple time or repetitive | Complete diagnostic exam (CDE) recommendation rates for eligible patients | Practice behavior | Yes | CDE recommendation rates for eligible patients increased for patients whose physicians received the intervention (adjusted post/pre OR = 2.11, p <0.001), but not for those in the control group. Intervention to control group OR of CDE recommendation was 2.28, p=0.002. | “Use of a physician-oriented intervention substantially and significantly increased CDE recommendation and performance in Intervention Group practices as compared to Control Group practices. These findings demonstrate that targeting PCPs for delivery of a combined CDE reminder feedback and educational outreach intervention can have a meaningful impact on physician behavior and patient followup in colorectal cancer screening. It is notable that the magnitude of the intervention impact was greater for CDE recommendation than CDE performance. The intervention also had a statistically significant impact on CDE recommendation rates when the combined timeframe (Periods 2 and 3) was compared to Period 1.” | Int: 6 years
| CC: NA | CC: Readings | CC: NA | | | | | | CC: 6 years
Practice Behavior Objectives Not Met, Evaluation Duration Not Reported
Mukohara, 2005^13^ | Int: Computer-based off-line | Int: Readings | Int: Multiple time or repetitive | Proportion of patients for whom physicians incorporated or read published evidence for medical decision making | Practice behavior | No | There were no significant differences within or between groups in the proportion of patients for whom they incorporated or read published evidence for medical decision making. | While doctors appreciated these summaries, which improved their reading efficiency, the intervention had little impact on their use of research evidence in practice. | Int: NR
| CC: Computer-based off-line | CC: Readings | CC: Multiple time or repetitive | | | | | | CC: NR
Schectman, 1991^139^ | Int: Print | Int: Readings,: Directed physicians to use ATPs | Int: NR | Prescribing patterns of antihistamines | Practice behavior | No | There were no significant differences between the three groups in the rate of prescribing more expensive antihistamines compared to the preferred antihistamines in the study. | The intervention was met favorably by the physicians, but there was no impact of the intervention on antihistamine prescribing patterns | Int: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Maxwell, 1984^57^ | Int: Live | Int: Case-based learning, Discussion group | Int: Multiple time or repetitive | Practice behavior on key topics, as measured by chart review and qualitative interviews | Practice behavior | No | Unsuccessful data collection due to insufficient numbers. Anecdotal evidence of behavior change from stories from 12 committee members. | Medical care evaluation meetings have educational value | Int: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NR
Practice Behavior Objectives Not Met, Evaluation Duration Less Than or Equal to 30 Days
Zuckerman, 2004^18^ | Int: Print | Int: Readings | Int: One time | Patient factors: percent filling prescription for beta-blocker within 7–30 days. | Practice behavior | No | There was an increase in post-AMI hospitalization beta-blocker prescribing after the intervention, though this increase was not statistically significant (p=0.13 at 30 days, p=0.12 at 7 days). | “The systemwide physician education program in Pennsylvania Medicaid program increased beta-blocker prescribing after AMI hospitalization by increasing physicians' awareness of the guidelines for treatment of AMI survivors. The educational intervention also improved patients' compliance with beta-blocker therapy. These effects are likely to apply to AMI patients well beyond the study population. Besides clinical effects, this intervention program also led to cost savings for the Pennsylvania Medicaid program, as well as avoidance of a few deaths.” | Int: 30 days
| Int: Print | Int: Readings | Int: One time | | | | | | Int: 30 days
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Levinson, 1993^138^ | Int: Live | Int: Case-based learning, Lecture | Int: One time | Change scores in 34 categories of physician-patient communication | Practice behavior | No | There was no evidence of an effect from the short program training in any of the RIAS content analyses, looking at differences in posttest scores between groups, controlling for pretest scores as a covariate. | The study concluded that the long program resulted in significant changes in physicians and patients communication, looking at pre/post comparisons only (no control). The authors wrote, This study demonstrates some potentially important changes in physicians' and patients' communication after a 2.5 day CME program. The changes demonstrated in both content and affect may have important influences on both biologic outcome and physician and patient satisfaction. However, in the study that was abstracted (i.e. the one with a control group) no impact of the short CME intervention was seen. | Int: 1 month
| CC: NA | CC: NA | CC: NA | | | | | | CC: 1 month
Practice Behavior Objectives Not Met, Evaluation Duration Greater Than 30 Days
Mehler, 2005^99^ | Int: Internet, not real time, Print | Int: Academic detailing, Readings | Int: Multiple time or repetitive | Proportion of patients receiving lipid testing | Practice behavior | No | A favorable trend was observed for a larger increase in frequency of lipid testing at intervention sites (+23% combination of electronic and direct detailing) compared with control sites (+11%), although the difference was not statistically significant (p = 0.06). | A simple educational intervention seems to positively influence provider behavior in the area of lipid management in diabetes mellitus. Both electronic and direct detailing seem to be viable approaches. Future studies to determine optimal educational components that facilitate appropriate provider actions to initiate or intensify lipid treatment seem warranted given the burgeoning population of diabetic patients at risk for coronary heart disease morbidity and mortality. | Int: 3 months
| Int: Live, Print | Int: Academic detailing, Lecture | Int: Multiple time or repetitive | | | | | | Int: 3 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 3 months
Maclure, 1998^96^ | CC: NA | CC: NA | CC: NA | Impact of teleconference on prescribing pattern | Practice behavior | No | There was a trend toward increased use of calcium channel blockers, but it was not statistically significant. | There was a general trend toward the desired effect by the educational interventions. | CC: 3 months
| Int: Live, Video | Int: Lecture, Teleconference | Int: One time | | | | Participants in the teleconference showed a shift from ACEI to thiazides, compared with matched controls. | | Int: 3 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 3 months
| Int: Live | Int: Discussion group, Lecture | Int: NR | | | | | | Int: 3 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 3 months
| Int: Print | Int: Readings | Int: Multiple time or repetitive | | | | | | Int: 3 months
Maclure, 1998^96^ | CC: NA | CC: NA | CC: NA | Impact of newsletters on prescribing pattern | Practice behavior | No | There was a trend to decreased prescribing of calcium channel blockers, (shift from preference for first-line CCBs to first-line thiazides) but it was not statistically significant | There was a general trend toward the desired effect by the educational interventions. | CC: 3 months
| Int: Live, Video | Int: Lecture, Teleconference | Int: One time | | | | | | Int: 3 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 3 months
| Int: Live | Int: Discussion group, Lecture | Int: NR | | | | | | Int: 3 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 3 months
| Int: Print | Int: Readings | Int: Multiple time or repetitive | | | | | | Int: 3 months
Maclure, 1998^96^ | CC: NA | CC: NA | CC: NA | Impact of small group on prescribing pattern | Practice behavior | No | There was a trend to decreased prescribing of calcium channel blockers, (a shift from preference for first-line CCBs to first-line thiazides) but it was not statistically significant | There was a general trend toward the desired effect by the educational interventions. | CC: 3 months
| Int: Live, Video | Int: Lecture, Teleconference | Int: One time | | | | | | Int: 3 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 3 months
| Int: Live | Int: Discussion group, Lecture | Int: NR | | | | | | Int: 3 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 3 months
| Int: Print | Int: Readings | Int: Multiple time or repetitive | | | | | | Int: 3 months
Lewis, 1993^70^ | Int: Live, Video | Int: Discussion group, Lecture | Int: One time | Percentages of new patients reporting they were asked sexual history questions by their physicians (family physicians) | Practice behavior | No | The program had no apparent impact on family physicians. | These results suggest that a medical education program that goes beyond standard lectures and incorporates interactive formats can change physician behaviors. | Int: 3 months
| Int: Print | Int: Readings | Int: One time | | | | | | Int: 3 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Lewis, 1993^70^ | Int: Live, Video | Int: Discussion group, Lecture | Int: One time | Percentages of new patients reporting they were asked sexual history questions by their physicians (obstetriccians/gynecologists) | Practice behavior | No | Practitioners of obstetrics and gynecology at all sites demonstrated a relatively high frequency of asking sexual history questions before the program, but these rates did not change. | These results suggest that a medical education program that goes beyond standard lectures and incorporates interactive formats can change physician behaviors. | Int: 3 months
| Int: Print | Int: Readings | Int: One time | | | | | | Int: 3 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Hagen, 2005^126^ | Int: Live, Print, laminated copies to be posted at stations and in charts | Int: Lecture, Readings | Int: Multiple time or repetitive | Dose of benzodiazepines | Practice behavior | No | The total doses of benzodiazepines remained largely unchanged over time in control and experimental facilities, although the control group experienced two decreases post-intervention at Times 4 and 6. | Our finding that the intervention did not reduce the percentage of residents on neuroleptics or benzodiazepines or the dosages administered, is inconsistent with the findings of Avorn et al. (1992), who reported that provider education reduced the use of psychotropic drugs in nursing homes. | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | R-ANOVA conducted for 4 months post-intervention (Time 3 vs. Time 5) found no significant effects for either time (F (1.734)=2.08, p=0.15) or time by facility (F (1.734)=3.00, p=0.083). R-ANOVA conducted for 6 months post-intervention (Time 3 vs. Time 6) revealed significant effects for time by facility (F (1.699)=4.77, p=0.029) but not for time alone (F (1.699)=0.18, p=0.67). | | CC: NA
Hagen, 2005^126^ | Int: Live, Print, laminated copies to be posted at stations and in charts | Int: Lecture, Readings | Int: Multiple time or repetitive | Effect of educational intervention upon use of psychotropics | Practice behavior | No | The primary hypothesis, that the intervention facilities would show less postintervention use of psychotropics than the control facilities, was not supported. Rather, both control and experimental LTC (long-term care) facilities experienced a small rise in the percentage of residents receiving neuroleptics after the education intervention between Time 3 and Time 4, although the increases were only significant in the control group. | Our finding that the intervention did not reduce the percentage of residents on neuroleptics or benzodiazepines or the dosages administered, is inconsistent with the findings of Avorn et al. (1992), who reported that provider education reduced the use of psychotropic drugs in nursing homes. | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Davis, 2004^101^ | Int: Live, Video, Audio, audio teleconferencing | Int: Case-based learning, Discussion group, Problem-based learning or team-based learning | Int: Multiple time or repetitive | Change in prescribing patterns with respect to use of SABAs | Practice behavior | No | Neither the study nor the control group demonstrated a statistically significant change in the use of SABAs before and after the intervention. (Study group prescriptions decreased between 6 months before and 6 months after, while control group prescriptions of SABAs increased. No level of statistical significance was given for these changes.) | “We report the first PBL-style teleconference series to demonstrate a significant change in physician prescribing habits toward better concordance with current asthma guidelines. This study demonstrated the powerful impact that the PBL format has on physician learning that actually translated into action—a measurable change in beliefs and behavior that led to changes in the number of prescriptions written by the participants. Although standard, traditional, didactic lectures remain the norm for CME across the US and credits are given for attendance, many studies have now shown that PBL is actually more effective at enhancing physicians learning. CME offices should plan more small-group workshops or teleconferences integrating the PBL format, with skilled facilitators trained to develop the cases and moderate the sessions, ultimately to improve the quality of CME.” | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 6 months
Solomon, 2004^127^ | Int: Live, Print | Int: Discussion group, Lecture, Readings | Int: Multiple time or repetitive | Osteoporosis management: proportion who underwent bone densitometry | Practice behavior | No | After the intervention, the proportion of patients undergoing bone densitometry was not statistically different between the groups (p=0.9). | “In conclusion, we conducted a randomized controlled trial of a multifaceted intervention for GIOP. This intervention was not associated with any increase in use of osteoporosis medications or bone densitometry over a 6-month postintervention observation period. Based on several potential explanations for these findings, we are considering future interventions that rely on direct-to-patient educational mailings as well as the use of rheumatology nurses to recognize at-risk patients and initiate a diagnostic workup.” | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 6 months
Solomon, 2004^127^ | Int: Live, Print | Int: Discussion group, Lecture, Readings | Int: Multiple time or repetitive | Osteoporosis management: proportion prescribed a medication for osteoporosis | Practice behavior | No | Although the proportion of pts who were prescribed a medication for osteoporosis did increase (between 6 months before and 6 months after the intervention) in both the intervention and control groups, neither of them increased in a statistically significant fashion, nor were they statistically significantly different from one another (p=0.3). | “In conclusion, we conducted a randomized controlled trial of a multifaceted intervention for GIOP. This intervention was not associated with any increase in use of osteoporosis medications or bone densitometry over a 6-month postintervention observation period. Based on several potential explanations for these findings, we are considering future interventions that rely on direct-to-patient educational mailings as well as the use of rheumatology nurses to recognize at-risk patients and initiate a diagnostic workup.” | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 6 months
Pazirandeh, 2002^128^ | Int: Live, Print | Int: Lecture, Readings, Q & A period | Int: One time | Physician initiation of osteoporosis discussion and screening orders | Practice behavior | No | The discussion of osteoporosis and orders for bone mineral density tests increased for both control and intervention group. However, this is likely a result of the patient education intervention, not the physician intervention which did not show evidence of affecting practice patterns. | “In summary, in this nonrandomized controlled study, there was some evidence supporting the generally recognized belief that didactic lectures are not effective in modifying physician practice patterns.” | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 6 months
Thom, 2000^129^ | Int: Live, Video | Int: Demonstration, Discussion group, Lecture, Role play | Int: One time | Modification of physician behaviors that affect patient trust | Practice behavior | No | Five behaviors correlated with patient trust: “letting you tell the story”; listening carefully; never interrupting; answering questions clearly showed the least net difference between groups, but are very important to patients. | This study did not find any effect from a one-day physician training intervention on patient-physician trust, physician or patient satisfaction, utilization, continuity or adherence. | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 6 months
Schectman, 1996^16^ | Int: Print, Samples of first generation antihistamines to use with patients | Int: Readings | Int: One time | Antihistamine prescribing costs per member per month, as measured from health plan database. | Practice behavior | No | Education and providing drug samples had no substantial effect on prescribing behavior between intervention and control sites. Both groups decreased costs 2% in the study period. | Education and providing samples did not result in decreased antihistamine prescribing costs. An effective intervention would require targeting of major patient-related barriers (e.g. patient expectations) to clinician behavior change. | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 6 months
Bjornson, 1990^14^ | Int: Print | Int: Readings | Int: One time | Change in physician prescribing patterns | Practice behavior | No | There was no statistical difference between the number of physicians in the intervention and control groups who made full changes (switching patients to both hydralazine and isosorbide), but the number who made full and partial changes approached significance (p=0.07). | The intervention was not successful in modifying the prescribing practices of physicians with respect to CHF patients. | Int: 4 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 4 months
Stewart, 2005^43^ | Int: Internet, not real time, | Int: Case-based learning, Discussion group, Reading | Int: Multiple time or repetitive | Physician behaviors | Practice behavior | No | Scores on the standardized patient checklist were not significantly different in the intervention group than in the control group. | The case-based on-line discussion demonstrated a mixed effect, with significant differences on only one of two cases and for only two of the three outcomes (family physicians' knowledge and quality of practice). | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | The study identified a promising continuing education format (case-based, on-line learning), as well as questions for future research regarding the content and order of cases presented in on-line education. | CC: NA
Lin, 1997^73^ | CC: NA | CC: NA | CC: NA | Change in depression practice behaviors as a result of the intervention | Practice behavior | No | There was no difference between the two groups in number of follow-up visits for depression, or in the number of educational messages received by patients. | The results do not support the concept that this complex and aggressive intervention effected a sustain change in practice behaviors 6 months after the intervention. In fact, some positive changes were noted immediately after the intervention (i.e. prescribing patterns) but were lost 6 months after the intervention was over. | CC: NA
| Int: Live, Video, Print | Int: Academic detailing, Feedback, Lecture, Readings, Role play | Int: Multiple time or repetitive | | | | | | Int: 6 months
Schectman, 1995^130^ | Int: Print | Int: Feedback, Readings | Int: Multiple time or repetitive | Change in prescribing patterns of H2 blockers | Practice behavior | No | Education: memo alone v. memo plus feedback; no difference across groups. | A simple educational intervention to change physician prescribing patterns can be modestly effective. In this study only group-model physicians changed their behavior and individual feedback did not lead to a higher percentage of physicians responding to the intervention among the total study population. | Int: 6 months
| Int: Print | Int: Feedback, Readings | Int: Multiple time or repetitive | | | | Group model physicians did respond to the intervention and network physicians did not. | | Int: 6 months
| Int: Print | Int: Feedback, Readings | Int: Multiple time or repetitive | | | | | | Int: 6 months
| CC: Print | CC: Readings | CC: Multiple time or repetitive | | | | | | CC: 6 months
| CC: Print | CC: Readings | CC: Multiple time or repetitive | | | | | | CC: 6 months
| CC: Print | CC: Readings | CC: Multiple time or repetitive | | | | | | CC: 6 months
Casebeer, 1999^131^ | Int: Audio, Telephone conferences | Int: Case-based learning, Discussion group, Point of care | Int: Multiple time or repetitive | Physician strategies in enhancing adherence to hypercholesterolemic treatment, as measured by standardized patients pre- and 3 months post-intervention | Practice behavior | No | No significant differences between groups in use of seven communication strategies. Intervention group had significant pre- to post- improvements in facilitating patients' understanding of hypercholesterolemia (p=0.009) and interpersonal interaction (p=0.28). | Combining a series of interactive case audio-conferences with chart reminders shows promise in increasing physicians' adherence-enhancing strategies. | Int: 9 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Pinto, 1998^74^ | CC: Prin,t | CC: Readings, | CC: Amount of exposure up to the physicians | Report of actual counseling activities by physicians | Practice behavior | No | The intervention group had a slight increase in actual self-reported counseling by physicians, but it was not statistically significant over the control group. | The program improved physician confidence in counseling and patient satisfaction, but did not increase the physician reports of exercise counseling provided to all patients. | CC: 8 months
| Int: Live, Print | Int: Discussion group, Readings, Role play | Int: One time | | | | | | Int: 8 months
Gullion, 1988^132^ | Int: Print, Telephone conference | Int: Discussion group, Feedback, Readings | Int: Multiple time or repetitive | Physician behavior regarding behavioral management of hypertension, as assessed by chart review | Practice behavior | No | Using adjusted p-value (p<0.0025) for multiple comparisons, there were no significant differences. Patients of physicians who received behavioral education had higher weight scores (p<0.005) and were slightly more likely to be heavy drinkers (p<0.09) compared with physicians who did not receive behavioral education. They were also more likely to have received advice about how to take medications (p<0.04), about side effects (p<0.006), and about sodium intake (p<0.04). Patients who were most overweight lost weight if physicians received behavioral education and gained weight if not; slightly overweight patients gained weight regardless of MD training. | An education program combining an individualized feedback report of performance, a peer-reviewed syllabus, and an educational session in the form of a telephone conference call had no significant impact on patients' hypertension. | Int: 11 months
| Int: Print, Telephone conference | Int: Discussion group, Feedback, Readings | Int: Multiple time or repetitive | | | | | | Int: 11 months
| Int: Print, Telephone conference | Int: Discussion group, Feedback, Readings | Int: Multiple time or repetitive | | | | | | Int: 11 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Gullion, 1988^132^ | Int: Print, Telephone conference | Int: Discussion group, Feedback, Readings | Int: Multiple time or repetitive | Physician behavior regarding medication management for hypertension, as assessed by chart review | Practice behavior | No | Using adjusted p-value (p<0.0056) for multiple comparisons, there were no significant differences. Physicians receiving medication education were more likely to take correct actions with abnormal labs compared with no medication education groups (p<0.03), but no other significant differences on other 8 measures. | An education program combining an individualized feedback report of performance, a peer-reviewed syllabus, and an educational session in the form of a telephone conference call had no significant impact on patients' hypertension. | Int: 11 months
| Int: Print, Telephone conference | Int: Discussion group, Feedback, Readings | Int: Multiple time or repetitive | | | | | | Int: 11 months
| Int: Print, Telephone conference | Int: Discussion group, Feedback, Readings | Int: Multiple time or repetitive | | | | | | Int: 11 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Lin, 2001^133^ | Int: Live | Int: Academic detailing, Case-based learning, Demonstration, Discussion group, Role play | Int: Multiple time or repetitive | Characteristics related to physician practices regarding diagnosis and treatment of depression | Practice behavior | No | While both groups slightly increased in both their rate of diagnosing depression and the rate of new Rx's of antidepressants for new diagnoses, the intervention group decreased slightly while the usual care group increased slightly in their rate of antidepressant prescriptions. | “After education on optimal management of depression, intervention physicians did not differ from their usual care colleagues in depression diagnosis or pharmacotherapy.” | Int: 1 year
| CC: Live NA | CC: NA | CC: Multiple time or repetitive | | | | However, pre-to-post changes were not statistically significantly different between intervention and usual care group when it came to any of these 3 outcome measures (rate of diagnosing depression, Rx rate of antidepressant meds, or rate of new Rx of antidepressants for new diagnoses of depression). | | CC: 1 year
Socolar, 1998^134^ | CC: NA | CC: NA | CC: NA | Impact of the intervention on history and physical exam scores from the chart audit | Practice behavior | No | There was no difference in charting of the history and physical exam between the groups. Also, there was no difference in the pre and post knowledge tests between the groups. | The intervention seemed to have no effect. However, having CME credit in child abuse was associated with improved documentation which may indicate that the chart audit technique of providing feedback and education may not be the optimal method of providing education. | CC: 1 year
| Int: Print | Int: Feedback, Readings | Int: Multiple time or repetitive | | | | | | Int: 1 year
Socolar, 1998^134^ | CC: NA | CC: NA | CC: NA | Variables that did correlate with improved documentation | Practice behavior | No | There was an overall improvement in documentation by both groups during the study, so correlates of this improvement were sought as the intervention itself seemed to have no impact. The statistically significant associations were having obtained CME credit in child abuse evaluation, a structured medical record, and female gender. | The intervention seemed to have no effect. However, having CME credit in child abuse was associated with improved documentation which may indicate that the chart audit technique of providing feedback and education may not be the optimal method of providing education. | CC: 1 year
| Int: Print | Int: Feedback, Readings | Int: Multiple time or repetitive | | | | | | Int: 1 year
Brown, 2004^135^ | Int: Live, Video, Print | Int: Case-based learning, Demonstration, Lecture, Problem-based learning or team-based learning, Readings | Int: Multiple time or repetitive | see comments regarding parents and patients | Practice behavior | No | Treatment group parents more often reported that their children were prescribed anti-inflammatory therapy from physicians compared to parents in the intervention group, though these differences were not statistically significant. However, other measures of clinical outcomes, such as urgent health care services were compared, but level of statistical significance was only given within groups (from baseline to follow-up), and not for comparing between intervention and control groups. | “The physician's interactive seminar has been shown to enhance asthma care and outcomes. The impact of the program is not reserved merely for those patients with more resources. The greatest decline in emergency department use was in children from low-income families.” | Int: 22 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 22 months
McClellan, 2003^119^ | Int: Video, Print | Int: Feedback, Readings | Int: Multiple time or repetitive | Eye exams ordering | Practice behavior | No | not statistically significant | “The main result of our study was that a population-based quality improvement intervention based on applying the HCQIP model to ambulatory care was associated with improved processes of care of diabetes mellitus.” | Int: 1.5–2 years
| CC: NA | CC: NA | CC: NA | | | | | | CC: 1.5–2 years
McClellan, 2003^119^ | Int: Video, Print | Int: Feedback, Readings | Int: Multiple time or repetitive | Quantitative urine ordering | Practice behavior | No | not statistically significant | “The main result of our study was that a population-based quality improvement intervention based on applying the HCQIP model to ambulatory care was associated with improved processes of care of diabetes mellitus.” | Int: 1.5–2 years
| CC: NA | CC: NA | CC: NA | | | | | | CC: 1.5–2 years
Browner, 1994^122^ | Int: Live, Print | Int: Lecture, Readings | Int: One time | Proportion of patients screened for high cholesterol | Practice behavior | No | No differences between control and intervention groups, p>.25. | CME was not particularly effective in improving compliance with NCEP guidelines among non university affiliated community physicians who practice primary care. | Int: 18 months
| Int: Live, Print | Int: Academic detailing, Case-based learning, Lecture, Point of care, Readings | Int: Multiple time or repetitive | | | | | | Int: 18 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Browner, 1994^122^ | Int: Live, Print | Int: Lecture, Readings | Int: One time | Proportion of screened patients who were managed in compliance with NCEP recommendations | Practice behavior | No | No difference between groups, p>.25. | CME was not particularly effective in improving compliance with NCEP guidelines among non university affiliated community physicians who practice primary care. | Int: 18 months
| Int: Live, Print | Int: Academic detailing, Case-based learning, Lecture, Point of care, Readings | Int: Multiple time or repetitive | | | | | | Int: 18 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Sibley, 1982^136^ | Int: Audio, Print | Int: Case-based learning, Lecture, Readings | Int: Multiple time or repetitive | Quality of care processes on common medical conditions, as measured by chart audit | Practice behavior | No | No significant difference in the improvement of proportion of physicians providing adequate or superior care comparing intervention (5% improvement) vs. control (2%). Preplanned analysis revealed equivalent improvements in high-preference topics (6% both groups), but statistically significantly higher improvement for low-preference topics in study (10% improvement) vs. control (1% worsening)[p=0.01]. | “Despite statistically significant gains in their knowledge of how to evaluate and manage a variety of indicator conditions, the study physicians in this trial had neither clinically important nor statistically significant improvements in the documented overall quality of care ... wanting continuing education about a high-preference condition was as good as getting it; it worked when it was not particularly wanted; and its effects did not extend beyond the topics covered.” | Int: 18 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Evans CE, 1986^56^ | Int: Print | Int: Readings, Chart cue materials offered, but not necessarily implemented | Int: Multiple time or repetitive | Proportion of patients prescribed antihypertensive medications by a study physician, as assessed by patient interview and chart audit | Practice behavior | No | Proportion rose from 57 to 76% in the study group and from 54 to 79% in the control group (p<0.01 overall), but difference between groups not significant. | “Our study demonstrates no influence of a mailed continuing medical education program on the practices of physicians or on the control of blood pressure of hypertensive patients referred from a community survey to these physicians after the program was begun.” | Int: 21 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 21 months
Kim, 1999^137^ | Int: Live, Print | Int: Academic detailing, Feedback, Readings | Int: Multiple time or repetitive | Preventative services, as observed in chart review | Practice behavior | No | No significant increases in offered procedures and actual declines in mammography and clinical breast exam in both groups; discrepancies noted between patient self-report and chart review | A physician-targeted approach of education, peer-comparison feedback, and academic detailing has modest effects on patient satisfaction and possibly on the offering of selected preventative care services. The lack of agreement between patient reports and medical records review raises concerns about current methods of ascertaining compliance with guidelines for preventative care. | Int: 2–2.5 years
| CC: Print | CC: Readings | CC: Multiple time or repetitive | | | | | | CC: 2–2.5 years
Practice Behavior Objectives With Mixed Results, Evaluation Duration Greater Than 30 Days
Kronick, 2003^71^ | Int: Live | Int: Case-based learning, Demonstration | Int: One time | Physician comfort level with accessing medical information via internet. | Attitudes | Yes | Intervention group physicians increased their frequency of and comfort with accessing Internet medical information. Statistically significant differences in change from baseline between intervention and control group were seen with frequency of use of www to address patient related questions (p=.009), in the comfort level using online databases (p=.032) and in the frequency of accessing online databases (p=.044). Non-statistically significant differences were seen in frequency of accessing email to answer pt-related questions and comfort in using email, the internet, opinion of the value of the internet and in accessing online full-text journals. | “Rural physicians' comfort and competence in use of computers to address patient problems can be improved by an individualized 3-hour training session. These data suggest that physicians distant from medical libraries can have excellent access to evidence-based resources; as connection to the Internet becomes faster, more uniform, and reliable across communities, the training will become easier to deliver.” | Int: 3 months
| CC: NA | CC: NA | CC: NA | | Practice behavior | Mixed | | | CC: 3 months
Fordis, 2005^42^ | Int: Live, Print, Risk calculator | Int: Case-based learning, Lecture, Programmed learning, Readings | Int: One time | Appropriate screening and management of high-risk patients, as measured by chart review | Practice behavior | Mixed | For appropriate screening for lipid abnormalities, there were high baseline screening rates >=93% with no significant post-intervention change. The online CME group did not differ significantly from the live CME and control groups (P = .24). The live CME group did not differ from the control group (P=.16). | Appropriately designed, evidence-based online CME can produce objectively measured changes in behavior as well as sustained gains in knowledge that are comparable or superior to those realized from effective live activities. | Int: 5 months
| Int: Internet, real time (e.g., streaming), Internet, not real time, Print, Risk calculator | Int: Case-based learning, Lecture, Programmed learning, Readings | Int: Multiple time or repetitive | | | | Regarding drug treatment for patients at high risk, there was a statistically significant though relatively small increase (5.0% (95% CI, 1.0%–9.1%); pre 85.3% –> 90.3% post) in the percentage of patients appropriately treated by the online CME group when compared with the live CME and control groups (partial w2=0.16, P=.04). The live CME and control groups did not differ significantly in treatment of patients. | | Int: 5 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Beaulieu, 2002^140^ | Int: Live | Int: Case-based learning, Problem-based learning or team-based learning, Readings, Role play | Int: One time | Guideline-appropriate screening in the periodic health exam, as measured by number of screening items ordered. | Practice behavior | Mixed | Exposure to the workshop had no impact on the total number of items recommended for inclusion in periodic health exam, but did impact the total number of items recommended for exclusion as well as the secondary outcome of total number of other tests ordered. | “Results suggest that a short interactive workshop can decrease the ordering of unnecessary screening tests for adults who consult for check-ups.” | Int: 4–6 months
| CC: NA | CC: | CC: NA | | | | | | CC: 4–6 months
Tziraki, 2000^141^ | Int: Live, Print | Int: Discussion group, Lecture, Problem-based learning or team-based learning, Role play | Int: One time | Adherence to NCI manual's recommendations for nutrition counseling, as measured by physician / office staff questionnaire and blinded observation of practices and charts | Practice behavior | Mixed | Training group had significantly higher adherence (28.5%) to office organization recommendations (3.8% more than manual-only[p=0.005] and 5.5% more than control[p<0.001]). Training group had significantly higher adherence to nutrition screening (2.5% more than manual-only[p=0.046] and 3% more than control[p=0.012]). But no differences in advice/referral (52.3–57% adherence) or patient follow-up (13.6–14.6% adherence). | “The impact of the training was moderate and not statistically significant for nutrition advice/referral or patient follow-up, which are important in achieving long-term dietary change in patients.” | Int: 4–6 months
| Int: Print | Int: Readings | Int: One time | | | | | | Int: 4–6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Gifford, 1999^142^ | HC: NA | HC: NA | HC: NA | Neurologists' adherence to guidelines, as measured by participant survey using clinical scenarios | Practice behavior | Mixed | Compared with the combined baseline/ control group, the intervention group was significantly more likely to adhere to 3 of 6 practice recommendations: use of neuroimaging (adjusted OR 4.3; 95% CI: 1.9–9.8), referral to the Alzheimer's Association (2.7; 95% CI: 1.5–4.7), and referral to the Safe Return Program (9.7; 95% CI: 3.1–30.5). For the other recommendations, adherence did not differ between groups. For 2 of these, adherence was high (>80%) in all 3 groups. The intervention group had higher adherence with 1 of 3 recommendations designed to reduce overuse (significant for use of neuroimaging but not for use of EEG and APOE genotype testing) and 2 of 3 recommendations designed to increase use (significant for referral to the Alzheimer's Association and the Safe Return Program but not for diagnosis and treatment of depression). | A multifaceted educational program can improve physician adoption of practice guidelines. | HC: NA
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
| Int: Live, Print | Int: Case-based learning, Discussion group, Lecture, Readings, mailings | Int: One time | | | | | | Int: 6 months
Lin, 1997^73^ | CC: NA | CC: NA | CC: NA | Pattern of antidepressant prescriptions | Practice behavior | Mixed | There was an increase in imipramine and a decrease in amitryptilline/doxepin use during the intervention (a goal of the study), but this effect was lost 6 months after the intervention. There was no difference in the use of Prozac between the control and intervention. There was also no difference in adequacy of antidepressant medication use at 6 months between the two groups. | The results do not support the concept that this complex and aggressive intervention effected a sustain change in practice behaviors 6 months after the intervention. In fact, some positive changes were noted immediately after the intervention (i.e. prescribing patterns) but were lost 6 months after the intervention was over | CC: NA
| Int: Live, Video, Print | Int: Academic detailing, Feedback, Lecture, Readings, Role play | Int: Multiple time or repetitive | | | | | | Int: 6 months
Carney, 1995^88^ | Int: Live, Video | Int: Demonstration, Discussion group, Feedback, Lecture, Programmed learning, Role play | Int: One time | Which CME techniques had the greatest effect on physician cancer screening and prevention counseling skills | Cognitive skills | Mixed | Performance of intervention physicians was consistently better though only 4 of 19 measured endpoints of the physicians' behavior by the SP reached statistical significance. | Performance based CME techniques have a positive influence on physicians' performance (especially in skills training). Using unannounced standardized patients is a feasible method to assess performance within the practice environment. | Int: 1 year
| CC: NA | CC: NA | CC: NA | | Practice behavior | Mixed | | | CC: NA
Ray, 1985^20^ | CC: NA | CC: NA | CC: NA | Prescribing of contraindicated antibiotics and oral cephalosporins, as measured by Medicaid data | Practice behavior | Mixed | Drug-educator group produced modest improvement in prescribing in year 1, but not year 2. Physician-counselor group had significant improvements in both drug classes in years 1 and 2 by “average prescription change index,” but not by proportion of doctors. Improvements in “average patient change index” in physician-counselor group were attenuated in year 2 for contraindicated antibiotics, but not oral cephalosporins. | “the beneficial impact on prescribing of a single physician-counselor visit of 15 minutes was both strong and lasting” “although some attenuation of effect was seen”; “no lasting beneficial effect of one visit by the drug educator” | CC: NA
| Int: Live | Int: Academic detailing | Int: One time | | | | | | Int: 2 years
| Int: Live | Int: Academic detailing | Int: One time | | | | | | Int: 2 years
Kim, 1999^137^ | Int: Live, Print | Int: Academic detailing, Feedback, Readings | Int: Multiple time or repetitive | Preventative care services offered, as reported by patient questionnaire | Practice behavior | Mixed | Proportions of patients reporting being offered services increased in both groups for influenza, pneumococcal, and tetanus immunization; in educational only group for mammography and clinical breast exam; in comprehensive group for exercise counseling; and for neither in smoking cessation. | A physician-targeted approach of education, peer-comparison feedback, and academic detailing has modest effects on patient satisfaction and possibly on the offering of selected preventative care services. The lack of agreement between patient reports and medical records review raises concerns about current methods of ascertaining compliance with guidelines for preventative care. | Int: 2–2.5 years
| CC: Print | CC: Readings | CC: Multiple time or repetitive | | | | | | CC: 2–2.5 years
Unclear if Practice Behavior Objectives Met, Evaluation Duration Greater Than 30 Days
Davis, 2004^101^ | Int: Live, Video, Audio, audio teleconferencing | Int: Case-based learning, Discussion group, Problem-based learning or team-based learning | Int: Multiple time or repetitive | Change in prescribing patterns with respect to use of ICSs | Practice behavior | Unclear | Most study group physicians increased their use of ICSs, all more so did the control group. No overall increase in the study group was given to compare to the control group's overall 24% increase in use (6 months before compared to 6 months after intervention), nor was any indication of statistical significance given (for between or with group differences). | “We report the first PBL-style teleconference series to demonstrate a significant change in physician prescribing habits toward better concordance with current asthma guidelines. This study demonstrated the powerful impact that the PBL format has on physician learning that actually translated into action—a measurable change in beliefs and behavior that led to changes in the number of prescriptions written by the participants. Although standard, traditional, didactic lectures remain the norm for CME and credits are given for attendance, many studies have now shown that PBL is actually more effective at enhancing physicians learning. CME offices should plan more small-group workshops or teleconferences integrating the PBL format, with skilled facilitators trained to develop the cases and moderate the sessions, ultimately to improve the quality of CME.” | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 6 months
Practice Behavior Objectives With No Control Group, Evaluation Duration Not Reported
Goldstein, 2005^146^ | Int: Live, Print | Int: Discussion group, Readings, packet which had patient-specific information form | Int: Not specified | Guideline concordance of clinician prescribing | Practice behavior | No control group | Concordance with the drug therapy guidelines for hypertension improved in both study groups, with substantially more improvement in the individualized intervention group compared with the general-intervention group. Concordance improved almost 11% with the individualized intervention compared with 4% with the general intervention (t=2.796, P=.008); this absolute increase of 11% represents a 26% relative improvement over baseline nonconcordance in the individualized group versus 7% in the general group. | Individualized recommendations about drug therapy for hypertension presented to clinicians at the time of a patient visit are effective in changing prescribing to achieve higher rates of guideline adherence. | Int: NR
| Int: Live, Print | Int: Discussion group, Readings, packet which had patient-specific information form and advisory about guideline concordance of patient's antihypertensive drug regimen | Int: Not specified | | | | Bootstrap analysis showed that being in the individualized-intervention group increased the odds of concordance 1.5-fold (2-sided P=.03, z=2.23; 95% CI: 0.05, 2.12). | Providing individualized recommendations to clinicians can be done in healthcare systems with electronic pharmacy and diagnostic data, even in the absence of a complete electronic health record. | Int: NR
| | | | | | | | Generation and distribution of recommendations can be done efficiently if these activities are integrated with existing procedures.
Rosenthal, 2005^59^ | Int: Live, Handheld, Review of data | Int: Lecture, Readings, Review of practice's data | Int: Multiple time or repetitive | Parent reports of anticipatory guidance | Practice behavior | No control group | The adjusted proportion of families of 1-month-olds who received 4 of the 5 age-appropriate anticipatory guidance items changed from 15.9% (95% CI: 8.9%–26.7%) to 10.0% (95% CI: 5.1%–18.8%) in the control practices and from 7.3% (95% CI: 4.1%–12.9%) to 24.0% (95% CI: 14.6%–36.9%) in the intervention practices (difference between two differences, p=.002). | An office system intervention improved parent reports of quantity of anticipatory guidance but did not change parent knowledge or parent behavior. | Int: NR
| CC: Review of data | CC: Review of practice's data | CC: One time | | | | The adjusted proportion of families of 6-month-olds who received all of the age-appropriate anticipatory guidance changed from 8.2% (95% CI, 3.6%–17.8%) to 5.4% (95% CI, 2.8%–10.2%) in the control practices and from 2.2% (95% CI, 0.8%–5.9%) to 18.1% (95% CI, 10.3%–29.9%) in the intervention practices (difference between two differences, P=.001). | | CC: NR
Allison, 2005^147^ | CC: Computer-based off-line | CC: Readings | CC: Multiple time or repetitive | Screening rates | Practice behavior | No control group | The mean screening rates before, during, and after the intervention for the comparison offices were 18.9%, 13.0%, and 12.4%, respectively, and for the intervention offices were 16.2%, 13.3%, and 15.5%, respectively, (p=0.044 for post-intervention differences after adjusting for baseline performance). The difference in post-intervention screening rates by study group remained significant when adjusting for both pre-intervention and intra-intervention screening rates using repeated-measures analysis (p=0.009). | This randomized trial of a multicomponent, Internet-based CME intervention found an attenuated decrease in screening rates for offices exposed to the intervention. The demonstrated impact on practice patterns coupled with low intervention intensity increases the potential importance of mCME as a learning method that is easy to disseminate. The appropriateness of mCME for other conditions and settings must be assessed. | CC: NR
| Int: Computer-based off-line | Int: Feedback (chlamydia screening rates for the physician's entire office), Readings | Int: Multiple time or repetitive | | | | | | Int: NR
Practice Behavior Objectives With No Control Group, Evaluation Duration Greater Than 30 Days
Lockyer, 2002^64^ | Int: Live | Int: Case-based learning, Discussion group, Lecture, Role play | Int: One time | Physician practice behaviors: involvement in patient care | Practice behavior | No control group | Both track 1 (introductory course) and track 2 (advanced course) participants improved statistically significantly between pre and post-test scores with a moderate effect size difference (0.7 & 0.4, respectively). Between tracks comparisons showed statistically significant differences between tracks for both precourse and postcourse assessment of involvement. | Track 1 (introductory course) physicians improved moderately, while track 2 (advanced course) physicians showed a small or negligible change in knowledge, comfort, and involvement in patient care for dementia patients. Tracking in CME - assigning physicians to courses based on pre-course ability, interest, or skill - needs further study. | Int: 3 months
| Int: Live | Int: Case-based learning, Discussion group, Lecture | Int: One time | | | | | | Int: 3 months
Mazmanian, 1998^24^ | CC: Live | CC: Lecture | CC: One time | Impact of CME content including barriers to practice change on actual self-reported practice change by physicians | Practice behavior | No control group | There was no difference between the control and intervention group and their self-reported practice change. | Including content on barriers to change in CME lecture material did not make physicians more likely to change their practice. However, physicians who report intent to change are more likely to actually change their practice patterns than those who don't. | CC: 45 days
| Int: Live | Int: Lecture | Int: One time | | | | | | Int: 45 days
Kutcher, 2002^65^ | Int: Live, Print | Int: Academic detailing, Discussion group, Lecture, Readings | Int: One time | Characteristics related to physician action such as use of a screening tool and optimal pharmacotherapy | Practice behavior | No control group | Enhanced intervention group was more likely to utilize depression diagnostic tool, optimize drug therapy, and use a checklist for adverse events (p<0.0001). | “A well-designed, directional, brief, simple, and low-cost educational program can increase family physicians' knowledge of depression, improve their diagnostic skills, and optimize their treatment of depression.” | Int: 6 months
| Int: Live, Print | Int: Discussion group, Lecture, Readings | Int: One time | | | | | | Int: 6 months
Pimlott, 2003^143^ | Int: Print | Int: Feedback, Readings | Int: Multiple time or repetitive | Characteristics of physician prescribing (of benzodiazepines to elderly) | Practice behavior | No control group | Though a small reduction in the prescribing of benzodiazepines was observed among the intervention group, and the mean change in percent from baseline to the end was significantly different (p=0.036) for the intervention and control groups, the intervention still had no significant impact on the proportion of seniors who received long-term benzodiazepine therapy (alone or in combination). | “We found that an intervention that had reasonable success in changing antibiotic prescribing patterns was unsuccessful when applied to benzodiazepine prescribing.” | Int: 6 months
| CC: Print | CC: Feedback, Readings | CC: Multiple time or repetitive | | | | | | CC: 6 months
McBride, 2000^144^ | Int: Live, Print | Int: Academic detailing, Discussion group, Feedback, Lecture, Point of care, Problem-based learning or team-based learning | Int: Multiple time or repetitive | Changes in documentation of screening of cardiovascular risk factors, as measured by medical record audit at baseline, 12 months, and 18 months | Practice behavior | No control group | Tripled in combined intervention group, with significance at 18 months. Prevention coordinator group had significant increase at 12 months and slight decrease at 18 months. Consultation group increases did not reach significance. No changes in conference-only group. | Practices can set goals, make changes in practice organization for prevention services, and increase risk factor screening and management documentation. Consultation practices set more goals, but prevention coordinator practices achieved greater increases in the use of medical record tools and documentation of screening and management. | Int: 6 months
| Int: Live, Print | Int: Lecture, Point of care, Problem-based learning or team-based learning, Patient education | Int: Multiple time or repetitive | | | | | | Int: 6 months
| Int: Live, Print | Int: Academic detailing, Discussion group, Feedback, Lecture, Problem-based learning or team-based learning, Patient education | Int: Multiple time or repetitive | | | | | | Int: 6 months
| CC: Live, Print | CC: Lecture, Point of care | CC: One time | | | | | | CC: 18 months
McBride, 2000^144^ | Int: Live, Print | Int: Academic detailing, Discussion group, Feedback, Lecture, Point of care, Problem-based learning or team-based learning | Int: Multiple time or repetitive | Improved use of cardiovascular risk assessment tools, as measured by medical record audit at baseline, 12 months, and 18 months | Practice behavior | No control group | Increases in cardiovascular disease risk documentation were greatest in combined intervention group at 12 months (21–35% in different locations in chart) and maintained at 18 months. Prevention coordinator group had largest increases flowsheet (22%) and second-largest in patient questionnaire, problem list, and chart label (10–22%), with most changes maintained at 18 months. Documentation increased to lesser degree in consultation group. Conference-only group demonstrated small increase in questionnaires, flowhseets, but not in chart labels or problem list. | Practices can set goals, make changes in practice organization for prevention services, and increase risk factor screening and management documentation. Consultation practices set more goals, but prevention coordinator practices achieved greater increases in the use of medical record tools and documentation of screening and management. | Int: 6 months
| Int: Live, Print | Int: Lecture, Point of care, Problem-based learning or team-based learning, Patient education | Int: Multiple time or repetitive | | | | | | Int: 6 months
| Int: Live, Print | Int: Academic detailing, Discussion group, Feedback, Lecture, Problem-based learning or team-based learning, Patient education | Int: Multiple time or repetitive | | | | | | Int: 6 months
| CC: Live, Print | CC: Lecture, Point of care | CC: One time | | | | | | CC: 18 months
McBride, 2000^144^ | Int: Live, Print | Int: Academic detailing, Discussion group, Feedback, Lecture, Point of care, Problem-based learning or team-based learning | Int: Multiple time or repetitive | Goal setting by practices, as reported by physician and staff questionnaires | Practice behavior | No control group | Combined intervention and consultation groups set average of 7 goals, while coordinator group set 5 and conference-only group set 3. Conference-only group less likely to set screening tool goal (42% vs. 82–100% in other groups, p<0.05). | Practices can set goals, make changes in practice organization for prevention services, and increase risk factor screening and management documentation. Consultation practices set more goals, but prevention coordinator practices achieved greater increases in the use of medical record tools and documentation of screening and management. | Int: 6 months
| Int: Live, Print | Int: Lecture, Point of care, Problem-based learning or team-based learning, Patient education | Int: Multiple time or repetitive | | | | | | Int: 6 months
| Int: Live, Print | Int: Academic detailing, Discussion group, Feedback, Lecture, Problem-based learning or team-based learning, Patient education | Int: Multiple time or repetitive | | | | | | Int: 6 months
| CC: Live, Print | CC: Lecture, Point of care | CC: One time | | | | | | CC: 18 months
McBride, 2000^144^ | Int: Live, Print | Int: Academic detailing, Discussion group, Feedback, Lecture, Point of care, Problem-based learning or team-based learning | Int: Multiple time or repetitive | Changes in documentation of management of cardiovascular risk factors, as measured by medical record audit at baseline, 12 months, and 18 months | Practice behavior | No control group | Appropriate management documented for 65% of patients at baseline, with significant increase in combined intervention group (72%) at 12 months compared with conference-only group (64%, p<0.05). At 18 months, all intervention groups (88–95%) had increased documentation compared with control (71%), with significant difference in coordinator and consultation groups. | Practices can set goals, make changes in practice organization for prevention services, and increase risk factor screening and management documentation. Consultation practices set more goals, but prevention coordinator practices achieved greater increases in the use of medical record tools and documentation of screening and management. | Int: 6 months
| Int: Live, Print | Int: Lecture, Point of care, Problem-based learning or team-based learning, Patient education | Int: Multiple time or repetitive | | | | | | Int: 6 months
| Int: Live, Print | Int: Academic detailing, Discussion group, Feedback, Lecture, Problem-based learning or team-based learning, Patient education | Int: Multiple time or repetitive | | | | | | Int: 6 months
| CC: Live, Print | CC: Lecture, Point of care | CC: One time | | | | | | CC: 18 months
Cherkin, 1991^83^ | Int: Live, Video | Int: Demonstration, Discussion group, Lecture | Int: Multiple time or repetitive | Ordering spine radiographs | Practice behavior | No control group | Percentage of providers indicating they would order lumbosacral spine radiographs fell from 67% to 43% (not statistically significant). | Both HMO and private practice achieved the first goal. As a result of the intervention about 50% of the physicians felt more confident in their ability to manage back pain. | Int: 4 months
| Int: Live, Video | Int: Demonstration, Discussion group, Lecture | Int: One time | | | | | | Int: 1–2 months
Heale, 1988^66^ | Int: Live | Int: Lecture | Int: One time | Performance by participants with SPs in the office in 7 months | Practice behavior | No control group | There were no differences between groups on physician performance in test cases, but there were differences between cases, with physicians performing significantly lower (p<.001) on one case than on the other two cases. The small group problem-based group participants performed better on one item related to one case than other participants (p<.05). | Within a one day CME course in family medicine, the learning format had no effect on acquired or retained knowledge or on physician performance in three patient problems. Physicians rated the small group problem based format higher. | Int: 7 months
| Int: Live | Int: Case-based learning, Discussion group | Int: One time | | | | | | Int: 7 months
| Int: Live | Int: Problem-based learning or team-based learning | Int: One time | | | | | | Int: 7 months
Greenberg, 1985^25^ | Int: Live | Int: Lecture | Int: One time | documentation of appropriate management of common pediatric problems | Practice behavior | No control group | No statistically significant difference in recording diagnoses (case-based 70% vs. lecture-based 38%) or in accuracy of diagnosis (79 vs. 78%). Significantly more case-based learners recorded a plan than lecture-based learners (80 vs. 39%, p<0.02). Plans were appropriate in 63% case-based vs. 44% lecture-based learners, but no significance test was reported. | Case-based learning, compared with lecture-based learning, was associated with some significant advantages in teaching skills and behavior in management of common pediatrics problems. | Int: 6–9 months
| Int: Live | Int: Case-based learning | Int: One time | | | | | | Int: 6–9 months
Labelle, 2004^67^ | Int: Live, Print | Int: Case-based learning, Demonstration, Discussion group, Lecture, Problem-based learning or team-based learning, Role play, Standardized patient | Int: Multiple time or repetitive | Impact on prescribing practice, as assessed by OSCE | Practice behavior | No control group | Though the scores increased somewhat for both groups (reflecting increase in WAP use in practice), the change was marginally not significantly different between the intervention groups (p=0.052). | “This study demonstrated a positive impact of the combination of a case-based, interactive asthma workshop featuring a preformatted tool to aid in drafting of WAPs, with a reinforcing OSCE 6 months post-workshop, on GP knowledge and self-reported use of WAPs. These results support the conclusion of reviews of CME programs that interactive and sequential educational activities providing opportunities to practice appear promising in changing physician practice.” | Int: 12 months
| Int: Live | Int: Case-based learning, Role play, Standardized patient | Int: Multiple time or repetitive | | | | | | Int: 12 months
Winickoff, 1984^23^ | Int: Print | Int: Feedback | Int: Multiple time or repetitive | Compliance with colorectal screening, as measured by chart review / health plan records | Practice behavior | No control group | Intervention period 1: both intervention and control groups improved significantly (p<0.001) from rates of 66 and 67.5% to 79.9 and 76.6%, respectively. Intervention period 2: group 1 stabilized at 79.8%, while group 2 continued to improve to 84.1% (p<0.001 for improvement, p<0.025 compared with group 1). Rates sustained at 6 and 12 months post-intervention. | Peer comparison feedback may improve compliance with quality improvement | Int: 12 months
| Int: Print | Int: Feedback | Int: Multiple time or repetitive | | | | | | Int: 6 months
Howe, 1997^145^ | Int: NR | Int: Feedback, Point of care, Readings | Int: NR | Changes in breast cancer management practices before and after the intervention | Practice behavior | No control group | Statistically significant urban-rural discrepancies were eliminated by both interventions for many practices. | The intervention had some impact on individuals measures, but overall it did not have a measurable impact on the rural-urban difference | Int: 2 years
| Int: NR | Int: Feedback, Lecture, Point of care, Readings, (the major difference between groups was the intensity of the intervention with frequent seminars and more intensive outreach but with greater access to experts in breast cancer) | Int: Multiple time or repetitive | | | | | | Int: 2 years
| Int: NR | Int: Feedback, Point of care, Readings | Int: Multiple time or repetitive | | | | | | Int: 2 years
| Int: NR | Int: Feedback, Point of care, Readings | Int: NR | | | | | | Int: 2 years

AAP = American Academy of Pediatrics; ACEI = angiotensin-converting enzyme inhibitor; AMI = acute myocardial infarction; ANCOVA = analysis of covariance; ATP = allergy trial pack; CC = concurrent control; CCBs = calcium channel blocker; CDE = complete diagnostic exam; CHF = congestive heart failure; CI = confidence interval; CME = continuing medical education; COPD = chronic obstructive pulmonary diseases; COX-2 = cyclooxygenase-2; DES = diethylstilbestrol; GIOP = glucocorticoid-induced osteoporosis; HC = historical control; HCQIP = Health Care Quality Improvement Program; IG = intervention group; Int =intervention group; LTC = long-term care; LTRA = leukotriene antagonists; mCME = multicomponent Internet continuing medical education; NA = not applicable; NCEP = National Cholesterol Education Program;NHC = neighborhood health center; NR = not reported; NSAID = non-steroidal anti-inflammatory drugs; OA = osteoarthritis; OR = odds ratio; OSCE = objective structured clinical examination; PBL = problem-based learning; PCP = primary care provider; RCT = randomized controlled trial; RR = relative risk; R-ANOVA = repeated measures analysis of variance; SABA = short acting bronchodilators; SD = standard deviation; SP = standardized patient; URI = upper respiratory infection; WAP = written action plan

Table 12 Evidence Table. Effectiveness of continuing medical education on short-term and long-term clinical outcomes

Author, year | Media used | Educational techniques | Amount of exposure | Main outcome measure | Type of objective | Objectives met | Summary of results | Overall conclusions | Evaluation duration
Clinical Outcomes Objectives Met, Evaluation Duration Not Reported
Kiang*, 2005^33^ | Int: NA | Int: NA | Int: NA | Perception of prescription and prescription rates of antimicrobial drug use for upper respiratory infections among pediatric patients | Clinical outcome | Yes | In both states, a decline was noted in the perceived parental demand for antimicrobial agents to treat pediatric respiratory illness. The temporal change was significant in Wisconsin (p = 0.004) and approaching significance in Minnesota (p = 0.064). The median reported percentage of parents who requested an antimicrobial agent decreased from 25% in 1999 to 20% in 2002 in both states, but the distribution around the medians differed significantly between the states. | In conclusion, this study suggests that the WARN campaign had at least a modest positive effect on the knowledge and decision-making of primary care clinicians in Wisconsin. | Int: NA
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
| Int: many things were made available but it is not reported as to which groups used what methods, options included live, regional meetings, CD-ROMs, mailings, grandrounds | Int: not clear | Int: not clear | | | | | | Int: NR
| CC: NA | CC: NA | CC: not clear | | | | | | CC: NA
Kiang*, 2005^33^ | Int: NA | Int: NA | Int: NA | Perception of prescription and prescription rates of antimicrobial drug use for upper respiratory infections among adult patients | Clinical outcome | Yes | In 2002, Wisconsin clinicians perceived less demand for antimicrobial agents among adult patients compared with 1999 (p<0.001). Based on clinician estimates, the median percentage of patients who requested an antimicrobial agent for cough, cold, or flu symptoms decreased from 50% in 1999 to 30% in 2002. Minnesota clinicians also perceived a decrease in the percentage of patients who requested antimicrobial agents, but the difference was not significant (p = 0.152); the median percentage of Minnesota patients requesting antimicrobial agents decreased from 40% in 1999 to 30% in 2002. | In conclusion, this study suggests that the WARN campaign had at least a modest positive effect on the knowledge and decision-making of primary care clinicians in Wisconsin. | Int: NA
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
| Int: many things were made available but it is not reported as to which groups used what methods, options included live, regional meetings, CD-ROMs, mailings, grandrounds | Int: not clear | Int: not clear | | | | | | Int: NR
| CC: NA | CC: NA | CC: not clear | | | | | | CC: NA
Wells, 2000^151^ | Int: Live, Print | Int: Academic detailing, Discussion group, Feedback, Lecture, Point of care, Readings | Int: Multiple time or repetitive | Depression, as measured by patient survey (CES-D) | Clinical outcome | Yes | At 6 months, 39.9% of QI patients and 49.9% of controls still met criteria for probable depressive disorder (P = .001), with a similar pattern at 12 months (41.6% vs. 51.2%; P = .005). Intervention patients were less likely to have probable depression at 6- and 12-month follow-up by 7 to 10 percentage points. QI-therapy and QI-meds patients, each compared with controls, were 8 to 10 percentage points less likely to have probable disorder at 6 and 12 months (P = .03). | When these managed primary care practices implemented QI programs that improve opportunities for depression treatment without mandating it, quality of care, mental health outcomes, and retention of employment of depressed patients improved over a year, while medical visits did not increase overall. | Int: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Wells, 2000^151^ | Int: Live, Print | Int: Academic detailing, Discussion group, Feedback, Lecture, Point of care, Readings | Int: Multiple time or repetitive | Health care utilization, as measured by patient survey | Clinical outcome | Yes | There were no differences in probability of having any medical visit at any point (each P.21). At 6 months, 47.5% of QI patients and 36.6% of controls had a medical visit for mental health problems (P = .001), and QI patients were more likely to see a mental health specialist at 6 months (39.8% vs. 27.2%; P<.001) and at 12 months (29.1% vs. 22.7%; P = .03). At each follow-up, QI-meds patients had higher rates than controls of any specialty counseling (by 10–12 percentage points, P = .003). | When these managed primary care practices implemented QI programs that improve opportunities for depression treatment without mandating it, quality of care, mental health outcomes, and retention of employment of depressed patients improved over a year, while medical visits did not increase overall. | Int: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Wells, 2000^151^ | Int: Live, Print | Int: Academic detailing, Discussion group, Feedback, Lecture, Point of care, Readings | Int: Multiple time or repetitive | Appropriate management of depression, as measured by patient survey | Clinical outcome | Yes | At 6 months, 50.9% of QI patients and 39.7% of controls had counseling or used antidepressant medication at an appropriate dosage (P<.001), with a similar pattern at 12 months (59.2% vs. 50.1%; P = .006). At 6 months, rates of appropriate care were greater by 14% for QI-meds than controls (P<.001) and by 8% for QI-therapy patients than controls (P = .002). At 12 months, QI-meds patients had higher rates of appropriate care than did controls (P<.001) or QI-therapy patients (P = .02), who did not differ significantly from controls. At each follow-up, QI-meds patients had higher rates than controls of appropriate medication use (by 10–14 percentage points, P = .001). | When these managed primary care practices implemented QI programs that improve opportunities for depression treatment without mandating it, quality of care, mental health outcomes, and retention of employment of depressed patients improved over a year, while medical visits did not increase overall. | Int: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Clinical Outcomes Objectives Met, Evaluation Duration Less Than or Equal to 30 Days
Zuckerman, 2004^18^ | Int: Print | Int: Readings | Int: One time | Patient factors: compliance of beta-blocker users. | Clinical outcome | Yes | There was an 8.3% (p=0.02) increase in compliance among beta-blocker users from pre to post-intervention. | “The system wide physician education program in Pennsylvania Medicaid program increased beta-blocker prescribing after AMI hospitalization by increasing physicians' awareness of the guidelines for treatment of AMI survivors. The educational intervention also improved patients' compliance with beta-blocker therapy. These effects are likely to apply to AMI patients well beyond the study population. Besides clinical effects, this intervention program also led to cost savings for the Pennsylvania Medicaid program, as well as avoidance of a few deaths.” | Int: 30 days
| Int: Print | Int: Readings | Int: One time | | | | | | Int: 30 days
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Clinical Outcomes Objectives Met, Evaluation Duration Greater Than 30 Days
Stein, 2001^95^ | Int: Live, Handheld by phone | Int: Readings study, physician visit, algorithm | Int: Multiple time or repetitive | Among patients: scores on measures of pain, functioning, and disability before and after intervention. | Clinical outcome | Yes | Arthritis pain showed a similar profile in both intervention and control homes: for about 1/3 of subjects, pain worsened in both groups (p=0.81). | An educational intervention effectively reduced NSAID use in nursing homes without worsening of arthritis pain. | Int: 3 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Stewart, 2005^43^ | Int: Internet, not real time | Int: Case-based learning, Discussion group, Readings | Int: Multiple time or repetitive | Quality of practice | Clinical outcome | Yes | Participation in the intervention was associated with quality of practice on the prevention topic; the mean quality of practice score at 6 months for the intervention group was significantly greater than for the control group. However, there were no differences on the diabetes topic. | The case-based on-line discussion demonstrated a mixed effect, with significant differences on only one of two cases and for only two of the three outcomes (family physicians' knowledge and quality of practice). | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | In a multiple regression analysis assessing the relationship of the intervention on quality of practice at 2 months and 6 months, taking knowledge into account, we found that after controlling for 2-month knowledge (as well as solo/group and baseline knowledge), the quality of practice on the prevention topic was significantly better in the intervention group than in the control group at both 2 months (b=1.27, p=.028) and 6 months (b=1.25, p=.016). | The study identified a promising continuing education format (case-based, on-line learning), as well as questions for future research regarding the content and order of cases presented in on-line education. | CC: NA
Rost, 2001^22^ | Int: by phone | Int: conference calls | Int: Multiple time or repetitive | Improvement in patient depressive symptoms (for patients starting a new treatment episode) based on increased use of psychotherapy or medication and patient satisfaction with care. | Clinical outcome | Yes | Patients in the intervention practices starting a new treatment episode reported improvements of depressive symptoms, versus patients in the control practices (p=0.04). Patients who claimed that psychopharmacology was acceptable to use showed more improvement overall (p=0.007) and patients in the intervention group practices were more satisfied with their care than those in the control group practices (p=0.02), among those for whom medication was acceptable. However, patients who were already in treatment did not report improvements with the intervention. | Patients starting a new treatment episode for depression in the intervention practices (which were trained to re-determine practice team roles) were significantly more likely to show improvements of symptoms (mental and physical) than were those patients in the control practices. Those who were already in treatment showed no significant improvements, regardless of group. | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Worrall, 1999^152^ | Int: Live | Int: Case-based learning, Discussion group, Lecture | Int: One time | Number and percent of patients taking medication at 6 month follow-up | Clinical outcome | Yes | Significant difference with more patients in intervention group taking medication at 6 months, p<.05 | “The educational strategy had a modest beneficial effect on the outcomes of patients with depression, but there are still concerns regarding the low rates of drug treatment and referral to mental health professionals by family physicians.” | Int: 6 months
| CC: Print | CC: Readings | CC: One time | | | | | | CC: 6 months
Worrall, 1999^152^ | Int: Live | Int: Case-based learning, Discussion group, Lecture | Int: One time | The gain score, defined as the difference in the scores between the initial threshold score of depression on the Center for Epidemiologic Studies Depression Scale (CES-D, a 20-item self-report questionnaire) and the same score obtained 6 months later | Clinical outcome | Yes | Before treatment, the mean CES-D score for patients didn't differ. The mean scores at 6 months were lower overall, but the difference between the intervention and control groups was not statistically significant. However, the mean gain score for patients in the intervention group was significantly higher (p <0.05). | “The educational strategy had a modest beneficial effect on the outcomes of patients with depression, but there are still concerns regarding the low rates of drug treatment and referral to mental health professionals by family physicians.” | Int: 6 months
| CC: Print | CC: Readings | CC: One time | | | | | | CC: 6 months
Worrall, 1999^152^ | Int: Live | Int: Case-based learning, Discussion group, Lecture | Int: One time | The gain score, which is the difference between the score obtained from the initial subjective diagnosis of depressive symptoms (based on a 4-point ordinal scale where 1 = absence of depressive symptoms and 4= severely depressed) and the same measure taken 6 months later | Clinical outcome | Yes | A statistically significant difference between the intervention and control groups' mean gain scores for physicians' ratings of depression severity was observed (p = 0.02). | “The educational strategy had a modest beneficial effect on the outcomes of patients with depression, but there are still concerns regarding the low rates of drug treatment and referral to mental health professionals by family physicians.” | Int: 6 months
| CC: Print | CC: Readings | CC: One time | | | | | | CC: 6 months
Roter, 1995^84^ | Int: Live | Int: Discussion group, Lecture, Role play, Standardized patient | Int: Multiple time or repetitive | Effect on patients' emotional distress | Clinical outcome | Yes | There was a reduction in emotional distress for all patient groups. However, patients of PD physicians showed significantly greater reduction in distress at 2 weeks, 3 months, and 6 months (p<0.05). Although their scores were lower, the patients of EH physicians did not have significantly greater reductions in emotional distress than the patients of control physicians. | Physicians' use of communication skills in their practices changed as a result of an 8-hour CME program. Physicians trained in specific communication skills recognized more psychological problems in their patients than did untrained physicians. Trained physicians showed greater clinical proficiency in the management of a simulated patient compared with control group physicians. The patients of trained physicians compared with untrained physicians showed greater reduction in emotional distress for as long as 6 months after their medical visit. | Int: Participant questionnaire was conducted in between sessions. When the simulated patient occurred was not reported. The last patient assessment was 6 months after their audiotaped visit, which occurred during the CME.
| Int: Live | Int: Discussion group, Lecture, Role play, Standardized patient | Int: Multiple time or repetitive
| CC: NA | CC: NA | CC: NA
Maiman, 1988^47^ | Int: Live Print | Int: Discussion group, Lecture, Readings | Int: Multiple time or repetitive | Mothers (patient) compliance with antibiotics | Clinical outcome | Yes | Educational interventions were associated with increased adherence as measured by liquid/pill counts in the home, and mothers' report of missed doses. | CME increased physician knowledge and compliance-enhancing practices and resulted in improvement in mothers' adherence to therapy. | Int: 6 months
| Int: Print | Int: Readings | Int: One time | | | | | | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Pinto, 1998^74^ | CC: Print | CC: Readings | CC: Given materials to read-exposure up to the physicians | Patient satisfaction with care | Clinical outcome | Yes | Patients in the IG were statistically more likely to report an increase in their satisfaction with care than controls (t =4.55, df =255, p<.01). | The program improved physician confidence in counseling and patient satisfaction, but did not increase the physician reports of exercise counseling provided to all patients. | CC: 8 months
| Int: Live, Print | Int: Discussion group, Readings, Role play | Int: One time | | | | | | Int: 8 months
Derebery, 2002^153^ | Int: Live, Print | Int: Demonstration, Discussion group, Lecture, Problem-based learning or team-based learning, Readings, Simulation (other than standardized patient or role-play) | Int: In addition to workshop, physicians received updated LBP manual to read on their own within 2–3 months for additional CME credit | Characteristics related to physician management of lower back pain including restricted duty rate, duration of restricted work, off-duty rate, number of therapy visits, number of doc visits, & case duration. | Clinical outcome | Yes | There was a significant decrease in the outcomes (physician lower back pain management practices) of the study group while the control group experienced no significant changes between pre and post-training period. | “All the outcomes measured decreased significantly in the study group while the control group experienced no significant changes from the pretraining period to the posttraining period, with the exception of a significant increase in case duration.” | Int: 1 year
| CC: Print | CC: Readings | CC: NA | | | | | | CC: 1 year
Ray, 2001^109^ | Int: Live, Print | Int: Academic detailing, Readings, chart reminders | Int: Multiple time or repetitive | Change between baseline and follow-up years in: SF36 measures of general health, physical function, and bodily pain (from 40% random patient sample) | Clinical outcome | Yes | No change over time of pain, health, or functioning scores for either group. | The educational program modestly reduced NSAID exposure in community-dwelling elderly patients without undesirable substitution of other medications or detectable worsening of musculoskeletal symptoms. | Int: 1 year
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Gonzales, 1999^111^ | Int: Live, Print | Int: Academic detailing, Demonstration, Lecture, Point of care | Int: One time | Incidence of adult office visits (incident visits) for uncomplicated acute bronchitis and changes in return visit rates | Clinical outcome | Yes | No increase across sites. | Antibiotic treatment of adults diagnosed as having uncomplicated acute bronchitis can be safely reduced using a combination of patient and practitioner interventions. | Int: 1 year
| Int: Print | Int: Academic detailing, Point of care | Int: NA | | | | | | Int: 1 year
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Wilson, 1988^154^ | CC: NA | CC: NA | CC: NA | Smoking cessation quit rates | Clinical outcome | Yes | Patients of physicians in intervention group had higher rates of smoking cessation (8.8%) at 3 months than patients of non-intervention physicians (4.4% for usual care and 6.1% for gum only). | Patients of physicians in intervention group had higher rates of smoking cessation (8.8%) at 3 months than patients of non-intervention physicians (4.4% for usual care and 6.1% for gum only). | CC: NA
| CC: NR | CC: NR | CC: MDs were told to offer nicotine gum | | | | | | CC: NA
| Int: Live | Int: NR | Int: One time | | | | | | Int: 1 year
Lindsay-McIntyre, 1987^115^ | Int: Print | Int: Point of care | Int: Multiple time or repetitive | Patient smoking cessation behaviors, as measured by patient questionnaire at 2 months and 1 year | Clinical outcome | Yes | 17.8% of gum plus training patients reported successful smoking cessation at 2 months, vs. 4% of usual care and 7% of gum only (p=0.05), with preliminary 1-year analysis showing narrower but still statistically significant differences. No significant differences in attempts to quit between gum only group (62.8%) and gum plus training group (76.5%). | Nicotine gum with chart cues helped stimulate patient smoking cessation attempts, but physician training in counseling with a more intensive flow sheet produced more successful short-term cessation. | Int: 1 year
| Int: Live, Video, Print | Int: Demonstration, Lecture, Point of care, Standardized patient | Int: Training 1 time, cueing with each patient | | | | | | Int: 1 year
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Clark, 1998^120^ | CC: NA | CC: NA | CC: NA | Impact of the intervention independent of the prescription of inhaled anti-inflammatory devices. | Clinical outcome | Yes | This was a subgroup analysis of 72 children (combined intervention and control groups) who were started on anti-inflammatory devices during the study. Intervention group patients were statistically significantly more likely to have fewer symptomatic asthma days in spring, summer, and winter (but not in the fall). | The intervention had a positive impact on both physician and parent reported behaviors, and patient outcomes were also positively impacted by the intervention. In addition, the impact appeared to be more than just that resulting from the increased use of anti-inflammatory medication and the change in practice behavior and the disease management model seems to be important as well | CC: 22 months
| Int: Live, Video | Int: Case-based learning, Clinical experiences, Lecture | Int: Multiple time or repetitive | | | | | | Int: 22 months
McMahon, 1988^155^ | Int: Live | Int: Discussion group, Feedback, Lecture | Int: Multiple time or repetitive | Length of stay | Clinical outcome | Yes | LOS for patients discharged from the study unit dropped significantly (p<.001) when compared with pre-intervention. Between group differences were not measured/ only pre and post intervention. | The length of stay decreased significantly in the three targeted specialty services after a 2 pronged Int: 1 individual meeting with medical director, and a CME group meeting. | Int: 16 months
| Int: Live | Int: Discussion group, Lecture | Int: One time | | | | | | Int: 16 months
| CC: Live | CC: Discussion group, Lecture | CC: One time | | | | | | CC: 16 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 16 months
Clark, 2000^78^ | Int: Live, Video | Int: Case-based learning, Demonstration, Lecture | Int: Multiple time or repetitive | Patient use of healthcare for asthma | Clinical outcome | Yes | Intervention patients had fewer hospitalizations (p=.03). Intervention patients did not show less utilization of ED use, but high baseline users of the ED did show a decrease in use (p=.03). Number of office visits was not affected. | Participating physicians reported that they communicated and taught patients in a more sophisticated way. Parents of intervention patients reported that physicians used a range of communication and education strategies to enhance patient learning and satisfaction. Intervention patients showed a decrease in hospitalization. | Int: 2 years
| CC: NA | CC: NA | CC: NA | | | | | | CC: 2 years
Kim, 1999^137^ | Int: Live, Print | Int: Academic detailing, Feedback, Readings | Int: Multiple time or repetitive | Preventative services used by patients, as reported by patient questionnaire | Clinical outcome | Yes | Comprehensive group reported greater use of pneumococcal and tetanus vaccination, (p=.02 and p<.01, respectively) and decline in mammography not seen in comprehensive group but seen in education only group (p<.01) | A physician-targeted approach of education, peer-comparison feedback, and academic detailing has modest effects on patient satisfaction and possibly on the offering of selected preventative care services. The lack of agreement between patient reports and medical records review raises concerns about current methods of ascertaining compliance with guidelines for preventative care. | Int: 2–2.5 years
| CC: Print | CC: Readings | CC: Multiple time or repetitive | | | | | | CC: 2–2.5 years
Clinical Outcomes Objectives Not Met, Evaluation Duration Greater Than 30 Days
Mehler, 2005^99^ | Int: Internet, not real time, Print | Int: Academic detailing, Readings | Int: Multiple time or repetitive | Percent change in LDL-cholesterol levels | Clinical outcome | No | They observed a decrease in LDL-cholesterol levels in all groups (electronic 111 to 97 mg/dL, direct 115 to 104 mg/dL, and control 109 to 101 mg/dL), although there were no differences in magnitude between the groups (P =.4). | A simple educational intervention seems to positively influence provider behavior in the area of lipid management in diabetes mellitus. Both electronic and direct detailing seem to be viable approaches. Future studies to determine optimal educational components that facilitate appropriate provider actions to initiate or intensify lipid treatment seem warranted given the burgeoning population of diabetic patients at risk for coronary heart disease morbidity and mortality. | Int: 3 months
| Int: Live, Print | Int: Academic detailing, Lecture | Int: Multiple time or repetitive | | | | | | Int: 3 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 3 months
Norris, 2000^81^ | Int: Live, Print F/U phone calls about protocol | Int: Lecture, Point of care, Opinion-leader from clinic teaching | Int: Multiple time or repetitive | Patient self-reported physical activity, as reported on telephone questionnaire at 6-month f/u | Clinical outcome | No | No differences in energy expenditure at 6 months (p=0.77) or other measures of physical activity, although intervention patients had higher stages of change scores among subset of patients classified as Contemplators (p=0.03). | “a one-time PACE counseling session with minimal reinforcement, in a setting with high baseline levels of activity, does not further increase activity of Contemplators advanced in stage of behavior change.” | Int: 6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Brown, 1999^72^ | Int: Live | Int: Clinical experiences, Discussion group, Lecture, Role play, Clinicians audio taped interaction with patients and listened between workshops | Int: Multiple time or repetitive | Patient satisfaction scores as measured by change in mean score on Art of Medicine survey during 6-month periods pre- and post- workshop | Clinical outcome | No | The mean score on the Art of Medicine survey improved more in the control group (0.072[0.030 + 0.042,CI, -0.010 to 0.154]) than in the intervention group (0.030[CI, -0.060 to 0.120]). The difference in these changes was 0.042 (CI, -0.080 to 0.164). Exposure to the communication skills program therefore did not affect changes in patient satisfaction scores. | “Thriving in a Busy Practice: Physician-Patient Communication,” a typical continuing medical education program geared toward developing clinicians' communication skills, is not effective in improving general patient satisfaction. To improve global visit satisfaction, communication skills training programs may need to be longer and more intensive, teach a broader range of skills, and provide ongoing performance feedback. | Int: >=6 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Lin, 1997^73^ | CC: NA | CC: NA | CC: NA | Patient satisfaction | Clinical outcome | No | There was no difference in patient satisfaction with their PCP or in the care they received. | The results do not support the concept that this complex and aggressive intervention effected a sustained change in practice behaviors 6 months after the intervention. In fact, some positive changes were noted immediately after the intervention (i.e. prescribing patterns) but were lost 6 months after the intervention was over. | CC: NA
| Int: Live, Video, Print | Int: Academic detailing, Feedback, Lecture, Readings, Role play | Int: Multiple time or repetitive | | | | | | Int: 6 months
Casebeer, 1999^131^ | Int: Audio Telephone conferences | Int: Case-based learning, Discussion group, Point of care | Int: Multiple time or repetitive | Patient health status as measured by SF-12 | Clinical outcome | No | No difference in physical health status or mental health status between intervention and control groups. | Combining a series of interactive case audio-conferences with chart reminders shows promise in increasing physicians' adherence-enhancing strategies. | Int: 9 months
| CC: NA | CC: NA | CC: NA
Gullion, 1988^132^ | Int: Print, Telephone conference | Int: Discussion group, Feedback, Readings | Int: Multiple time or repetitive | Change in patients' diastolic blood pressure (DBP), from pre- to post-intervention (up to 11 months post-phone call) | Clinical outcome | No | DBP improved for all groups (1.32 mmHg, p<0.0001), with no significant differences between control group and the intervention groups. | An education program combining an individualized feedback report of performance, a peer-reviewed syllabus, and an educational session in the form of a telephone conference call had no significant impact on patients' hypertension. | Int: 11 months
| Int: Print, Telephone conference | Int: Discussion group, Feedback, Readings | Int: Multiple time or repetitive | | | | | | Int: 11 months
| Int: Print, Telephone conference | Int: Discussion group, Feedback, Readings | Int: Multiple time or repetitive | | | | | | Int: 11 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Harris, 2005^75^ | Int: Live, Audio, Print, teleconference | Int: Case-based learning, Lecture, Readings | Int: Multiple time or repetitive | Overall mean fasting plasma glucose values | Clinical outcome | No | The overall mean fasting plasma glucose values were not significantly affected (control, 8.5 mmol/L, versus intervention, 8.4 mmol/L; p = .74). | CME delivered by teleconference was feasible, well attended, well received by participants, and improved some key diabetes management practices and outcomes, although primary goal of improving HbA1C was not achieved. | Int: 12 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Harris, 2005^75^ | Int: Live, Audio, Print, teleconference | Int: Case-based learning, Lecture, Readings | Int: Multiple time or repetitive | HbA1c levels | Clinical outcome | No | The intervention did not significantly affect the primary outcome measure (control, 0.076, versus intervention, 0.073; p = .29). The intervention did, however, significantly (p < .04) alter the distribution of patients (n = 369) by level of glycemic control as defined by 1998 Canadian diabetes guidelines and as taught in the TED CME. In the intervention group, fewer patients had inadequate glycemic control (HbA1c levels > 0.084) than in the control group (15.8% versus 23.9%). Significantly more patients in the intervention group were taking insulin (alone or in combination with oral agents), whereas significantly more patients in the control group were prescribed oral agents only. Significantly more patient records in the intervention group had documentation of BMI, eye exams, communication of a treatment plan, and used a flow sheet. | CME delivered by teleconference was feasible, well attended, well received by participants, and improved some key diabetes management practices and outcomes, although primary goal of improving HbA1C was not achieved. | Int: 12 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Cummings, 1989^112^ | Int: Live, Video, Print | Int: Demonstration, Discussion group, Lecture, Role play | Int: Multiple time or repetitive | Long-term smoking cessation rates of patients | Clinical outcome | No | There was no difference between intervention and control groups regarding long-term smoking cessation rates among patients at one year. | Intervention physicians discuss smoking at a greater rate than did control physicians. Intervention physicians spent more time discussing smoking with their patients. More smoking patients of the intervention physicians set quit dates and had more follow-up with their physicians. Rates of smoking cessation among patients at one year were no different between control and intervention physicians. | Int: 1 year
| CC: NA | CC: NA | CC: NA | | | | | | CC: 1 year
Cummings, 1989^113^ | Int: Live, Video, Print | Int: Case-based learning, Demonstration, Discussion group, Lecture, Role play | Int: Multiple time or repetitive | Patient smoking cessation rates at one year | Clinical outcome | No | Although patients in the intervention group received more counseling, their patients did not have a higher rate of smoking cessation at one year. | Intervention physicians discussed smoking cessation at a higher rate than did control physicians. They spent more time discussing smoking overall, and more of their patients set quit dates. Overall, smoking cessation rates of patients at one year did not differ between groups. | Int: 1 year
| CC: NA | CC: NA | CC: NA | | | | | | CC: 1 year
Kottke, 1989^114^ | Int: Live, Print | Int: Demonstration, Discussion group, Lecture, Readings | Int: One time | Smoking cessation rates at one year. | Clinical outcome | No | Smoking cessation rates were not significantly different among the three groups (workshop, materials-only, and control) | A brief training program and/or the distribution of education materials marginally increased smoking cessation behaviors among volunteer physicians but did not result in increased smoking cessation rates at one year. | Int: 1 year
| Int: Print | Int: Readings | Int: determined by participant | | | | | | Int: 1 year
| CC: NA | CC: NA | CC: NA | | | | | | CC: 1 year
Cummings, 1989^117^ | Int: Live, Video, Patient education materials | Int: Case-based learning, Demonstration, Role play, Self-reflection | Int: Multiple time or repetitive | Smoking cessation by patients, as measured by self-report and biochemical validation | Clinical outcome | No | No statistical differences in attempt to quit (39.7 vs. 36.6%), self-report of abstinence, or biochemically validated long-term (>=9 month) abstinence were similar between groups (3.2 vs. 2.5%, difference -1.7 to +3.1). | 3-hour continuing education program combined with supportive materials for offices changed the way physicians in private practice counseled about smoking, but had no statistically significant effects on patient outcomes. Some significant differences physicians and patients in intervention vs. control group related to drop-out, but adjustment for factors did not affect outcomes. | Int: 1 year
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Elliott, 1997^55^ | CC: NA | CC: NA | CC: NA | Attitude score of patients and caregivers | Clinical outcome | No | Attitude score declined in patients and caregivers in the intervention group but not statistically significant. | With the exception of attitudes of patients and caregivers, there was a trend toward improvement in pain ratings as well as provider attitudes and knowledge but the effect was minor and the overall results were not overwhelmingly convincing | CC: NA
| Int: Live, Print | Int: Case-based learning, Clinical experiences, Discussion group, Lecture, Readings | Int: Multiple time or repetitive | | | | | | Int: 15 months
Elliott, 1997^55^ | CC: NA | CC: NA | CC: NA | Pain scores of patients | Clinical outcome | No | Improved in the intervention group but not statistically significant. | With the exception of attitudes of patients and caregivers, there was a trend toward improvement in pain ratings as well as provider attitudes and knowledge but the effect was minor and the overall results were not overwhelmingly convincing. | CC: NA
| Int: Live, Print | Int: Case-based learning, Clinical experiences, Discussion group, Lecture, Readings | Int: Multiple time or repetitive | | | | | | Int: 15 months
Evans, 1986^56^ | Int: Print | Int: Readings, Chart cue materials offered, but not necessarily implemented | Int: Multiple time or repetitive | Average blood pressure change from baseline to post-intervention, as measured by home visit to patient | Clinical outcome | No | Blood pressure improved significantly in both intervention and control groups (SBP 12.2 and 13 mmHg lower, DBP 10.4 and 10.6 mmHg lower), but no difference between study and control groups. | "Our study demonstrates no influence of a mailed continuing medical education program on the practices of physicians or on the control of blood pressure of hypertensive patients referred from a community survey to these physicians after the program was begun. | Int: 21 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 21 months
Kim, 1999^137^ | Int: Live, Print | Int: Academic detailing, Feedback, Readings | Int: Multiple time or repetitive | Patient satisfaction | Clinical outcome | No | Satisfaction high at baseline with no significant changes, but comprehensive intervention patients felt quality of care improved. Patient satisfaction reporting preventative services offered reported higher satisfaction. | A physician-targeted approach of education, peer-comparison feedback, and academic detailing has modest effects on patient satisfaction and possibly on the offering of selected preventative care services. The lack of agreement between patient reports and medical records review raises concerns about current methods of ascertaining compliance with guidelines for preventative care. | Int: 2–2.5 years
| CC: Print | CC: Readings | CC: Multiple time or repetitive | | | | | | CC: 2–2.5 years
Clinical Outcomes Objectives With Mixed Results, Evaluation Duration Not Reported
Wells, 2000^151^ | Int: Live, Print | Int: Academic detailing, Discussion group, Feedback, Lecture, Point of care, Readings | Int: Multiple time or repetitive | Patient employment status, as measured by patient survey | Clinical outcome | Mixed | Among patients initially employed, 89.7% of intervention patients and 84.7% of control patients worked at 12 months (P = .05). Among those initially not working, 16.4% of intervention patients and 11.4% of control patients were working at 6 months (P>.10); by 12 months, 17% to 18% of intervention and control patients started working. | When these managed primary care practices implemented QI programs that improve opportunities for depression treatment without mandating it, quality of care, mental health outcomes, and retention of employment of depressed patients improved over a year, while medical visits did not increase overall. | Int: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Wells, 2000^151^ | Int: Live, Print | Int: Academic detailing, Discussion group, Feedback, Lecture, Point of care, Readings | Int: Multiple time or repetitive | Health-related quality of life, as measured by patient survey (SF-12) | Clinical outcome | Mixed | Intervention patients improved more on mental HRQOL by 1 to 2 points at each time point, but not global physical health or physical limitations. | When these managed primary care practices implemented QI programs that improve opportunities for depression treatment without mandating it, quality of care, mental health outcomes, and retention of employment of depressed patients improved over a year, while medical visits did not increase overall. | Int: NR
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Gerrity, 1999^32^ | Int: Live, Video, Audio, Print | Int: Clinical experiences, Discussion group, Feedback, Lecture, Readings, Role play | Int: Multiple time or repetitive | Patient satisfaction | Clinical outcome | Mixed | Patient satisfaction in the female case was higher for intervention physicians than control (p=.014), and higher in the male patient, but not at a significant level. | The Depression Education Program changed physicians' behavior and may be an important component in the efforts to improve the care of depressed patients. | Int: 2–6 weeks
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Clinical Outcomes Objectives With Mixed Results, Evaluation Duration Greater Than 30 Days
Lin, 1997^73^ | CC: NA | CC: NA | CC: NA | Depression outcome measures | Clinical outcome | Mixed | The main depression outcome measure (the IDS score) did not show any change as a result of the intervention (as expected it decreased with treatment but the amount of decrease was not higher as a result of the intervention). Another measure called the SCL-90 did show a significantly greater decrease of scores after the intervention but the overall result was mixed. | The results do not support the concept that this complex and aggressive intervention effected a sustained change in practice behaviors 6 months after the intervention. In fact, some positive changes were noted immediately after the intervention (i.e. prescribing patterns) but were lost 6 months after the intervention was over | CC: NA
| Int: Live, Video, Print | Int: Academic detailing, Feedback, Lecture, Readings, Role play | Int: Multiple time or repetitive | | | | | | Int: 6 months
Casebeer, 1999^131^ | Int: Audio Telephone conferences | Int: Case-based learning, Discussion group, Point of care | Int: Multiple time or repetitive | Patient knowledge and behavior on hypercholesterolemia, as measured by self-reported patient questionnaire and lipid levels | Clinical outcome | Mixed | Intervention group had significantly higher knowledge score (p=0.008) and self-reported consumption of dietary fats (p=0.002), but no significant difference in 8 other items. | Combining a series of interactive case audio-conferences with chart reminders shows promise in increasing physicians' adherence-enhancing strategies. | Int: 9 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Casebeer, 1999^131^ | Int: Audio Telephone conferences | Int: Case-based learning, Discussion group, Point of care | Int: Multiple time or repetitive | Patient lipid levels, as measured by laboratory testing | Clinical outcome | Mixed | Significantly lower serum cholesterol in men in intervention group 9 months after intervention. (p=.02) Specific changes, lipid levels, and data in women NR. | Combining a series of interactive case audio-conferences with chart reminders shows promise in increasing physicians' adherence-enhancing strategies. | Int: 9 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Clark, 1998^120^ | CC: NA | CC: NA | CC: NA | Impact of intervention on use of health care services by the patient | Clinical outcome | Mixed | IG group patients were stat sig. less likely to have office visits. There was no impact on ED visits and hospitalizations (except in a subgroup analysis of low-income patients where the IG had fewer). | The intervention had a positive impact on both physician and parent reported behaviors, and patient outcomes were also positively impacted by the intervention. In addition, the impact appeared to be more than just that resulting from the increased use of anti-inflammatory medication and the change in practice behavior and the disease management model seems to be important as well. | CC: 22 months
| Int: Live, Video | Int: Case-based learning, Clinical experiences, Lecture | Int: Multiple time or repetitive | | | | | | Int: 22 months
Messina, 2002^156^ | Int: Live, Audio, Print | Int: Demonstration, Readings, Standardized patient, telephone counseling | Int: Multiple time or repetitive | Patient mammography use. | Clinical outcome | Mixed | Baseline ever users of mammography showed an increase in use among those who received BSTC compared to control pts (p=0.041). However, among never users, CME, and not BSTC, is more important in achieving regular use of mammography (but not to a statistically significant degree- lack of power) | “...findings suggest that women who have bad prior mammography but do not screen regularly may require different approaches to promote screening than women who have never had a mammogram. BSTC is still potentially useful as a motivator to obtain subsequent mammograms but does not appear to be adequate for initiating screening in our sample of women who never had a mammogram.” | Int: 3 years
| Int: Live, Print | Int: Demonstration, Readings, Standardized patient | Int: Multiple time or repetitive | | | | | | Int: 3 years
| CC: Live, Audio | CC: Readings, telephone counseling | CC: Multiple time or repetitive | | | | | | CC: 3 years
| CC: NA | CC: NA | CC: NA | | | | | | CC: 3 years
Unclear if Clinical Outcomes Objectives Met, Evaluation Duration Greater Than 30 Days
Rodney, 1986^77^ | Int: Live, Video | Int: Demonstration, Lecture, Simulation (other than standardized patient or role-play) | Int: One time | Procedure outcomes from flexible sigmoidoscopy, as reported by physicians by phone or written survey | Clinical outcome | Unclear | 2 complications were reported among large group learners, and none in the small groups, but no test of significance mentioned. | Physicians who participate in courses in flexible sigmoidoscopy have a higher probability of office utilization of these skills than those who do not take courses. Minimal differences found between large and small group CME formats. | Int: 12–18 months
| Int: Live, Video | Int: Demonstration, Lecture, Simulation (other than standardized patient or role-play) | Int: One time | | | | | | Int: 12–18 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: NA
Clinical Outcomes Objectives With No Control Group, Evaluation Duration Greater Than 30 Days
Brown, 2004^135^ | Int: Live, Video, Print | Int: Case-based learning, Demonstration, Lecture, Problem-based learning or team-based learning, Readings | Int: Multiple time or repetitive | Admission rates, written asthma action plan, and days absent from school | Clinical outcome | No control group | The families of 36 children (13%) had an income of < $20,000, and they were treated by 23 physicians. Low-income children in the treatment group tended to have higher levels of use of controller medications, to receive a written asthma action plan, and to miss fewer days of school, although these differences were not statistically significant compared to low-income children in the control group. However, low-income treatment group children were significantly less likely to be admitted to an emergency department (annual rate, 0.208 vs 1.441, respectively) or to a hospital (annual rate, 0 vs 0.029, respectively) for asthma care compared to children in the control group. | “The physician's interactive seminar has been shown to enhance asthma care and outcomes. The impact of the program is not reserved merely for those patients with more resources. The greatest decline in emergency department use was in children from low-income families.” | Int: 22 months
| CC: NA | CC: NA | CC: NA | | | | | | CC: 22 months
Kutcher, 2002^65^ | Int: Live, Print | Int: Academic detailing, Discussion group, Lecture, Readings, | Int: One time | Patient satisfaction, compliance, treatment outcome and office visits. | Clinical outcome | No control group | Patients were satisfied in both groups, but no between group comparison was done, no differences were found in compliance or withdrawals. Patients treated by physicians in the enhanced group did make fewer office visits. Both patient groups improved with regard to self reported signs of depression (p<0.001) but the between group comparison showed no differences between groups. Patients treated by physicians in the enhanced group were less likely to be sent for adjunctive psychotherapy, (p <0.0001). | “A well-designed, directional, brief, simple, and low-cost educational program can increase family physicians' knowledge of depression, improve their diagnostic skills, and optimize their treatment of depression.” | Int: 6 months
| Int: Live, Print | Int: Discussion group, Lecture, Readings | Int: One time | | | | | | Int: 6 months

* A complex intervention, which involved both physician and patient education, was used.

AMI = acute myocardial infarction; BMI = body mass index; BSTC = barrier-specific telephone counseling; CES-D = Center for Epidemiologic Studies Depression; CME = continuing medical education; CI = confidence interval; DBP = diastolic blood pressure; ED = emergency department; EH = emotion handling; HRQOL = health-related quality of life; IDS = Inventory of Depressive Symptomatology; IG = intervention group; LOS = length of stay; NA = not applicable; NR = not reported; NSAID = non-steroidal anti-inflammatory drug; PCP = primary care provider; PD = problem defining; QI = quality improvement; SBP = systolic blood pressure; SCL-90 = Symptom Checklist-90; SD = standard deviation; SET = standard educational tools; SF-12 = Short Form-12; FQ = fluoroquinolone; TED = teleconferenced educational detailing; WARN = Wisconsin Antibiotic Resistance Network;

Table 13 Characteristics of systematic reviews evaluating the effectiveness of simulation in medical education

Author, year | Simulation methods | Health care professionals | Study designs | Comparisons | End date for search | Articles included, N | Relevant studies, N
Psychomotor Skills
Haque, 2006^26^ | Virtual reality | Medical students; Physicians-in-training (residents or fellows) | Randomized controlled trials; Prospective studies (Note: In order for studies to be included, they should have reported results with statistical data). | Simulation vs other medical education; Experienced operators vs novice operators in a simulated environment | 2004 | 16 | 7
Aucar, 2005^29^ | Partial task simulation; Computer simulation | Medical students; Physicians-in-training (residents or fellows); Fully trained physicians; Non-surgical personnel | Randomized controlled trials; Nonrandomized controlled trials; Prospective studies; review articles | Simulation vs other simulation; Simulation vs other medical education; Simulation vs no education | 2004 (not clearly reported, authors wrote that search was conducted until ‘present’) | 37 (16 review articles, 21 original articles) | 7
Gerson, 2004^30^ | Partial task simulation; Computer simulation; Virtual reality | Physicians-in-training (residents or fellows); Fully trained physicians; novice; clerical staff | Randomized controlled trials; Nonrandomized controlled trials; Prospective studies; Case-control studies | Simulation vs other simulation; Simulation vs other medical education; Simulation vs no education; Expert vs novice | January 2004 | 12 | 4
Sutherland, 2006^31^ | Full simulation; Partial task simulation; Computer simulation | Medical students; Physicians-in-training (residents or fellows); Fully trained physicians; other groups not specified | Randomized controlled trials | Simulation vs other simulation; Simulation vs other medical education; Simulation vs no education | April 2005 | 30 | 30
Gaffan, 2006^158^ | Partial task simulation; Computer simulation; Standardized patient | Medical students | Randomized controlled trials; Nonrandomized controlled trials; descriptive; cohort | Simulation vs other medical education; Simulation vs no education | August 2004 | 48 | 5
Ravert P, 2002^159^ | Full simulation; Partial task simulation; Computer simulation | Medical students; Physicians-in-training (residents or fellows); Nurses; Nursing students | Randomized controlled trials; Nonrandomized controlled trials; Prospective studies | Simulation vs other medical education | NR | 9 | 4
Communication Skills
Gaffan, 2006^158^ | Partial task simulation; Computer simulation; Standardized patient | Medical students | Randomized controlled trials; Nonrandomized controlled trials; descriptive; cohort | Simulation vs other medical education; Simulation vs no education | August 2004 | 48 | 5
Spangler, 2002^160^ | Standardized patient role play | Medical students | Randomized controlled trials; Prospective studies | Simulation vs other medical education | June 2002 | 13 studies met eligibility for inclusion; not all included simulation | 9
Cognitive Skills
Hmelo, 1990^28^ | Computer simulation, not clear | Medical students; Physicians-in-training (residents or fellows); other health professional students (e.g., dietary, allied health, pharmacy, nursing, occupational health, dental, respiratory health); medical/nursing staff | Not specified, but 78% had controls | Simulation vs other medical education; Simulation vs no education | NR | 65, but only 33 had data on effects of simulation | 33
Ravert P, 2002^159^ | Full simulation; Partial task simulation; Computer simulation | Medical students; Physicians-in-training (residents or fellows); Nurses; Nursing students | Randomized controlled trials; Nonrandomized controlled trials; Prospective studies | Simulation vs other medical education | NR | 9 | 4
Other
Issenberg, 2005^27^ | None, discussed features of high-fidelity simulation | Medical students; Physicians-in-training (residents or fellows); Fully trained physicians | Randomized controlled trials; Nonrandomized controlled trials; Prospective studies | None | June 2003 | 109 | 109

NR = not reported

Table 14 Evidence Table. Results of systematic reviews evaluating the effectiveness of simulation on medical education

Psychomotor Skills
Aucar, 2005^29^
Outcome | Effectiveness of simulation in improving performance of a single cohort of subjects. Comparison was made before and after simulation training. | Overall Conclusion: overall improvement after educational intervention
Objective | Psychomotor skills | Author's Main Conclusion: Surgical simulators can serve as an objective measure of technical skill level among surgeons. The presence of limited data and several inconsistencies remain that should temper the acceptance of current simulators as inherently valid for certification of surgeons. Additional studies are needed that correlate the observed clinical performance of capable and experience surgeons, using defined criteria, with their measured performance on simulators.
Results | Out of nine studies, eight found that simulation improved performance. Ninth study, which enrolled experienced surgeon only, found marked variability in the measurable skills.
Outcome | To evaluate the role of simulation in assessing the effectiveness of simulators in differentiating experienced from novice users.
Objective | Psychomotor skills
Results | Simulation is effective in differentiating between novice and expert users.
Outcome | To evaluate the performance on a simulator with performance on live animals or human surgical subjects.
Objective | Psychomotor skills
Results | Performance on simulation correlates well with performance on live animals or human subjects. Trainees trained on simulators may perform better on live animals or human subjects as compared to untrained trainees (one study).
Gaffan, 2006^158^
Outcome | Student satisfaction with learning. | Overall Conclusion: Overall improvement after educational intervention
Objective | Attitudes | Author's Main Conclusion: With respect to simulation: Use of standardized patients to teach breast examination improves students' performance in clinical assessment; the use of silicone models to teach breast examination improves students' sensitivity for detecting breast lumps; computer aided learning modules have a role, but are not superior to other types of learning.
Results | Student satisfaction with structured clinical instruction models was positive.
Outcome | Ability to detect breast lumps using standardized patients.
Objective | Psychomotor skills
Results | In two studies, teaching of breast examination with standardized patients had increased detection in intervention groups compared with normal teaching. p<.05 and p<.001.
Outcome | Ability to detect breast lumps using models
Objective | Psychomotor skills
Results | Lump detection higher for group trained with dynamic model, p<0.001. In two more studies, post-test improvement in lump detection, p<.05 and p<.01, in intervention groups trained with models. Third study showed intervention group had higher sensitivity in detecting breast lumps, p=.001, but lower specificity, p=.001.
Outcome | Knowledge of breast cancer detection.
Objective | Psychomotor skills
Results | One study showed equivalent knowledge test results in group taught by standardized patients and group taught by normal teaching.
Outcome | Giving bad news
Objective | Psychomotor skills
Results | Four studies looked at giving bad news education, three with SPs, one with role play and SPs, and one with role play alone. All showed improvement in competence in giving bad news.
Outcome | Student satisfaction with learning detection of testicular lumps.
Objective | Attitudes
Results | One study showed positive feedback from students in learning with mannikin Zack
Sutherland, 2006^31^
Outcome | Surgical trainees trained with physical or model training vs other forms of training, including no training. | Overall Conclusion: Overall improvement after educational intervention.
Objective | Psychomotor skills | Author's Main Conclusion: Computer simulation generally showed better results than no training at all but was not convincingly superior to standard training (such as surgical drills) or video simulation (particularly when assessed by operative performance). Video simulation did not show consistently better results than groups with no training at all, and there were not enough data to determine if video simulation was better than standard training or the use of models. Model simulation may have been better than standard training, and cadaver training may have been better than model training.
Results | Four studies found that model training may be better than no training and standard training, but overall there were mixed results.
Outcome | Surgical trainees trained on computer simulation versus video simulation.
Objective | Psychomotor skills
Results | Mixed results in seven studies; may have depended on types of tasks, with computer simulating producing better results for tasks such as incisions, but not for knot tying times.
Outcome | Surgical trainees trained on computer simulating vs no training.
Objective | Psychomotor skills
Results | Those trained on computer simulation performed better than those with no training in eight of nine studies.
Outcome | Surgical trainees trained on computer simulation vs physical trainer.
Objective | Psychomotor skills
Results | One study showed computer simulation training to be superior to live pig (p=.0005)
Outcome | Surgical trainees with two or more types of computer simulating; MIST-VR outcome.
Objective | Psychomotor skills
Results | One study showed more intensive training is more effective than easy level training; 2nd study showed inconsistent results.
Outcome | Surgical trainees trained with video simulation vs no training or other forms of training.
Objective | Psychomotor skills
Results | Six studies comparing video simulation with no training showed inconsistent results; five studies comparing video with other forms of training showed no differences.
Outcome | Surgical trainees trained on computer simulation vs standard training.
Objective | Psychomotor skills
Results | Four out of five studies showed statistical differences with improved results in computer simulation group. Authors concluded that computer simulation comparisons varied, potentially confounded by the different components of standard training, as well as by the different intensities of time allowed on the simulator in computer simulation groups.
Ravert P, 2002^159^
Outcome | Effect of simulation on skill or knowledge acquisition. | Overall Conclusion: Partial improvement or mixed results
Objective | Knowledge or cognitive skills (Psychomotor skills) | Author's Main Conclusion: It appears that the use of computer-based simulators could play a role in knowledge and skill acquisition. The potential of computer-based simulation as an education strategy is enormous, but more research to fully document its effectiveness is needed.
Results | Five out of nine studies included in this review included medical students or physicians-in-training. Two out of the five studies had a control or comparison group, and one study had a cross-control design. Overall, 75% of the nine studies showed positive effects of simulation on skill or knowledge acquisition as determined by effect size which was measured as d-index. The effect sizes ranged from 0.34 to 5.06.
Gerson, 2004^30^
Outcome | To evaluate the role of upper GI endoscopy simulator in differentiating between a novice and an expert in performing upper GI endoscopy.(Validation). | Overall Conclusion: Overall improvement after educational intervention
Objective | Psychomotor skills | Author's Main Conclusion:; 1 Flexible sigmoidoscopy simulators might be applied for clinical training of residents and fellows if improved patient comfort is the primary outcome. However, based upon the current studies, no benefit in clinical training has been demonstrated to date.; 2 Use of the colonoscopy training for residents and fellows early in the training process (performance of less than 30 procedures) has been shown to be beneficial, based upon data from a small clinical trial. Further prospective studies are needed to confirm these preliminary findings.; 3 Indications for ERCP and EUS simulator training cannot be made until validation and clinical trials are conducted.; 4 Because current state-of-the art computer-based simulators have been demonstrated to distinguish expert endoscopists from novices in upper endoscopy, sigmoidoscopy, and colonoscopy, this technology may someday be used as an objective method to judge competence in GI endoscopy.
Results | Authors found two studies and they showed that a simulator was able to distinguish a novice from an expert. One study also found that novice trained on the simulator reached the level of the experts after three weeks of simulator training.
Outcome | To evaluate the role of simulation in training colonoscopy by comparing novice GI fellows trained on simulators with traditionally trained novice GI fellows.
Objective | Psychomotor skills
Results | Simulator-trained novice fellows performed better than the novice fellows trained traditionally in all performance aspects except for time of insertion (p<.05) and that this advantage continued up to 30 colonoscopies.
Outcome | To determine optimal time for using simulation in the training of GI fellows.
Objective | Psychomotor skills
Results | Authors found one study which concluded that colonoscopy simulators are most effective early in the training of GI fellows.
Outcome | To evaluate the role of simulation in training ERCP by comparison of live pig model, Erlangen Endo-trainer model, and a computer simulation model. Each model was rated by novices and expert faculty for realism, utility in training, and ease of use.
Objective | Realism, usefulness in teaching basic and advanced ERCP skills.
Results | Authors found one study that reported Erlangen Endo-trainer model to be superior to other models.
Outcome | To evaluate the role of simulation in training flexible sigmoidoscopy by comparing simulator-trained trainees with trainees trained with standard methods or no training.
Objective | Psychomotor skills
Results | Authors found three studies. One study reported that simulator training is better than no training in teaching flexible sigmoidoscopy to family medicine residents as measured by insertion time (p=.03), directional errors (p<.01), and examination time (p=.01). Second study reported that bedside teaching was superior to simulator training in teaching flexible sigmoidoscopy to medical residents as measured by insertion time, negotiating rectosigmoid junction, reaching spleenic flexure, and performing reteroflexion. The third study found no procedural skills differences between the groups of 2nd-year residents trained on a simulator and those trained using standard methods.
Outcome | To evaluate the role of flexible sigmoidoscopy simulator in differentiating between a novice and an expert in performing sigmoidoscopy.
Objective | Psychomotor skills
Results | Authors found two studies and they showed that a flexible sigmoidoscopy simulator was able to distinguish a novice from an expert.
Outcome | To evaluate the role of simulation in assessing the effectiveness of colonoscopy simulators in differentiating novice from experts
Objective | Psychomotor skills
Results | Colonoscopy simulators can differentiate a novice from an expert as measured by procedure time, insertion time, and time in and out.
Haque, 2006^26^
Outcome | Effectiveness of virtual simulation in differentiating between experienced (those who have performed more than 50 such procedures) and novice (those who have performed less than 10 procedures) trainees based on the “error score” (the number of “wall-strikes” experienced by the trainee or the ratings provided by an external expert of the trainee's performance). | Overall Conclusion: No evaluation of improvement after educational intervention
Objective | Psychomotor skills | Author's Main Conclusion: Training on virtual reality simulators can lessen the time taken to complete a given surgical task as well as can help to discriminate between the experienced and the inexperienced trainees.
Meta-analysis | Yes
Significant Results | Yes
Results | Virtual reality simulators help to differentiate between a novice and an experienced trainee as evidenced by low error scores of the experienced trainees to complete a given surgical task in a virtual reality simulation environment. Standardized effect size = -1.325 (95%CI; -2.125, -0.525)[Random-effects model, p <0.0001 for homogeneity].
Outcome | Effectiveness of virtual simulation in differentiating between experienced (those who have performed more than 50 such procedures) and novice (those who have performed less than 10 procedures) trainees based on the “task completion time” (amount of time, in seconds or minutes, taken by the trainee to complete task)
Objective | Psychomotor skills
Meta-analysis | Yes
Significant Results | Yes
Results | Virtual reality simulators help to differentiate between a novice and an experienced trainee as evidenced by the decreased amount of time taken by experienced trainees to complete a given surgical task in a virtual reality simulation environment. Standardized effect size = -1.059 (95% CI; -1.331, -0.786)[fixed-effects model, p = 0.13 for homogeneity; authors report performing a random effects model with quite similar results.]
Outcome | Effectiveness of transference of skills from the simulation environment to the operating room with experienced surgeons or physicians, trained on simulations, operating on real patients or animal subjects. The control group was experienced surgeons or physicians trained using traditional methods. Both, simulation-trained and traditional method-trained, groups were compared using the “task completion time” (amount of time, in seconds or minutes, taken by the trainee to complete task).
Objective | Psychomotor skills
Meta-analysis | Yes
Significant Results | Yes
Results | The simulation-trained group took much less time than the traditionally trained group. Using the fixed effect model, a significant standardized effect size of -1.178 (95% CI; -1.706, -0.651) was obtained, but the inadequacy of analysis was indicated by lack of homogeneity (P <0.0001). Reanalysis using the random effects model yielded a statistically significant standardized effect size of -2.175(95% CI; -3.865, -0.485).
Outcome | Effectiveness of transference of skills from the simulation environment to the operating room with experienced surgeons or physicians, trained on simulations, operating on real patients or animal subjects. The control group was experienced surgeons or physicians trained using traditional methods. Both, simulation-trained and traditional method-trained, groups were compared using the “error score” (the number of “wall-strikes” experienced by the trainee or the ratings provided by an external expert of the trainee's performance).
Objective | Psychomotor skills
Meta-analysis | Yes
Significant Results | No
Results | The simulation-trained group had a smaller error score than the traditionally trained group. Using the fixed effect model, a significant standardized effect size of -0.974(95% CI; -1.457, -0.491) was obtained, but the inadequacy of analysis was indicated by lack of homogeneity (P <0.0001). Reanalysis using the random effects model yielded a statistically insignificant standardized effect size of -1.565(95% CI; -3.445, 0.314).
Communication Skills
Spangler, 2002^160^
Outcome | Student demonstration of effective tobacco cessation counseling. | Overall Conclusion: Overall improvement after educational intervention
Objective | Psychomotor skills | Author's Main Conclusion: Enhanced instructional methods (e.g., the use of patient centered counseling, standardized patient instructors, role playing, or a combination of these) are more effective for teaching tobacco intervention than are traditional didactic methods alone.
Results | Nine studies with active (role play or standardized patient) component to education: all but one showed significant improvement at posttest observation of skills; one did not show an improvement when SP group was compared with role playing group in follow-up SP assessment.
Outcome | Student confidence in tobacco cessation counseling skills
Objective | Attitudes
Results | Three studies demonstrated that students working with standardized patients expressed increased confidence in smoking cessation counseling. One RCT showed increased confidence in intervention students compared with controls.
Gaffan, 2006^158^
Outcome | Student satisfaction with learning. | Overall Conclusion: Overall improvement after educational intervention
Objective | Attitudes | Author's Main Conclusion: With respect to simulation: Use of standardized patients to teach breast examination improves students' performance in clinical assessment; the use of silicone models to teach breast examination improves students' sensitivity for detecting breast lumps; computer aided learning modules have a role, but are not superior to other types of learning.
Results | Student satisfaction with structured clinical instruction models was positive.
Outcome | Ability to detect breast lumps using standardized patients.
Objective | Psychomotor skills
Results | In two studies, teaching of breast examination with standardized patients had increased detection in intervention groups compared with normal teaching. p<.05 and p<.001.
Outcome | Ability to detect breast lumps using models
Objective | Psychomotor skills
Results | Lump detection higher for group trained with dynamic model, p<0.001. In two more studies, post-test improvement in lump detection, p<.05 and p<.01, in intervention groups trained with models. Third study showed intervention group had higher sensitivity in detecting breast lumps, p=.001, but lower specificity, p=.001.
Outcome | Knowledge of breast cancer detection.
Objective | Psychomotor skills
Results | One study showed equivalent knowledge test results in group taught by standardized patients and group taught by normal teaching.
Outcome | Giving bad news
Objective | Psychomotor skills
Results | Four studies looked at giving bad news education, three with SPs, one with role play and SPs, and one with role play alone. All showed improvement in competence in giving bad news.
Outcome | Student satisfaction with learning detection of testicular lumps.
Objective | Attitudes
Results | I One study showed positive feedback from students in learning with mannikin Zack
Cognitive Skills
Hmelo, 1990^28^
Outcome | Achievement | Overall Conclusion: need for future research
Objective | Unclear | Author's Main Conclusion: Whether or not computer-assisted instruction (CAI) is a useful modality, how it may best be used and what features promote learning and problem solving in the health care environment require further study. Ultimately, CAI may have a role in preparing a new generation of health practitioners, able to adapt to the changing situations that their professions demand.
Meta-analysis | Yes
Significant Results | Unclear
Results | The average effect size for achievement was 0.63.
Ravert P, 2002^159^
Outcome | Effect of simulation on skill or knowledge acquisition. | Overall Conclusion: Partial improvement or mixed results
Objective | Knowledge or cognitive skills (Psychomotor skills) | Author's Main Conclusion: It appears that the use of computer-based simulators could play a role in knowledge and skill acquisition. The potential of computer-based simulation as an education strategy is enormous, but more research to fully document its effectiveness is needed.
Results | Five out of nine studies included in this review included medical students or physicians-in-training. Two out of the five studies had a control or comparison group, and one study had a cross-control design. Overall, 75% of the nine studies showed positive effects of simulation on skill or knowledge acquisition as determined by effect size which was measured as d-index. The effect sizes ranged from 0.34 to 5.06.
Other
Issenberg, 2005^27^
Outcome | To evaluate the features and uses of high-fidelity simulators that lead to effective learning. | Overall Conclusion: Unclear
Objective | Effective learning | Author's Main Conclusion: While research in this field needs improvement in terms of rigor and quality, high-fidelity medical simulations are educationally effective and simulation-based education complements medical education in patient care settings.
Results | The important features of high-fidelity simulator that lead to effective learning are following:; 1 feedback is provided during learning experience; 2 Learners engage in repetitive practice; 3 Simulator is integrated in overall curriculum; 4 Learners practice with increasing levels of difficulty; 5 Adaptable to multiple learning strategies; 6 Clinical variation in a simulated environment can increase the number and variety of patients a learner encounters; 7 Controlled Environment in which learners make and detect mistakes without consequences; 8 Individualized and standardized learning; 9 Outcomes are clearly defined; 10 Face validity-realism of simulator

SP = standardized patient; RCT = randomized controlled trial; MIST-VR = Minimally Invasive Surgical Trainer Virtual Reality; ERCD = endoscopic retrograde pancreatography; EUS = endoscopic ultrasound; CAI = computer assisted instruction

Table 15 Evidence Table. Effects of audience characteristics on the effectiveness of continuing medical education

Author, year | Audience characteristic | Educational technique | Outcome | Results | Other characteristics analyzed | Primary goal audience characteristics
Juzych, 2005^92^ | Years in practice | Live case studies and printed material | Antibiotic prescribing rates | No effect | None | No
Kiang, 2005^33^ | Years in practice | Multiple interventions but specifics for groups not identified | Clinician knowledge and beliefs regarding antibiotic prescribing for upper respiratory infections | Clinicians in practice for >10 years improved in their beliefs about antibiotic prescribing but not in their knowledge compared to physicians with ≤ 10 years practice experience | None | No
Leopold, 2005^80^ | Years in practice | Printed guide or hands-on instruction or video instruction | Clinician confidence in performing knee joint injection and objective evaluation of joint injection technique | No effect | Age, number of injections performed in last year, gender, physician vs. non-physician | No
Beaulieu, 2002^140^ | Years in practice | 90-minute workshop using case discussion, role play, and educational handouts | Performance of physicians in including recommended screening items and excluding non-recommended screening items during periodic health exam | Physicians with less than 11 years of experience ordered fewer unnecessary tests order and fewer other tests ordered, but results not stratified by intervention | None | No
Gerstein, 1999^53^ | Years in practice | Seven-hour small group workshop for family physicians | Sub-scores on participant questionnaire about diabetes knowledge, attitude, practice behavior | Greater number of years in practice predicted an improvement in self-reported practice behavior but no improvement in attitude or diabetes knowledge | Gender, family practice certification, solo or group practice, full or part-time, practice size | No
Grady, 1997^79^ | Years in practice | Educational presentation with/without cue enhancement with/without feedback rewards | Cueing had a positive impact on mammography rates above education alone, but feedback and rewards had no added benefit | No effect | Age, gender, practice setting, board certification, specialty, foreign medical graduate vs. US graduate, group size, AMA membership, residency vs no residency | No
Leopold, 2005^80^ | Age | Printed guide or hands-on instruction or video instruction | Clinician confidence in performing knee joint injection and objective evaluation of joint injection technique | No effect | Years in practice, number of injections performed in last year, gender, physician vs. non-physician | No
Davis, 2004^101^ | Age | Live interactive case-based teleconferences | Change in prescribing patterns of asthma controller medications | Non-significant trend towards older physicians being less likely to prescribe controller medications | Unclear (analysis of factors mentioned but not described) | No
Harris, 2002^39^ | Age | Interactive, online, case-based program on domestic violence | Confidence in managing domestic violence patients | No effect, although data not shown | Gender, previous domestic violence training | No
Mazmanian, 2001^161^ | Age | Commitment-to-change statement with or without a signature by the CME course participant | Whether or not physicians changed their behaviors, depending on if they had a commitment to change, and also depending on whether or not they signed a commitment to change form | No effect | Gender | No
Grady, 1997^79^ | Age | Educational presentation with/without cue enhancement with/without feedback rewards | Cueing had a positive impact on mammography rates above education alone, but feedback and rewards had no added benefit | Intervention more effective in older physicians in bivariate but did not hold in multivariate analysis | Age, gender, practice setting, board certification, specialty, foreign medical graduate vs. US graduate, group size, AMA membership, residency vs no residency | No
Soumerai, 1987^105^ | Age | Printed educational materials and visits by clinical pharmacists | Intensity of prescribing target drugs. | No effect | Practice setting, specialty, professional boards, intensity of target drug use, Medicaid practice size, nursing home practice size | Yes
Leopold, 2005^80^ | Gender | Printed guide or hands-on instruction or video instruction | Clinician confidence in performing knee joint injection and objective evaluation of joint injection technique | Females confidence and objective performance improved more than males | Years in practice, number of injections performed in last year, age, physician vs. non-physician | No
Harris, 2002^39^ | Gender | Interactive, online, case-based program on domestic violence | Confidence in managing domestic violence patients | No effect, although data not shown | Age, previous domestic violence training | No
Mazmanian, 2001^161^ | Gender | Commitment-to-change statement with or without a signature by the CME course participant | Whether or not physicians changed their behaviors, depending on if they had a commitment to change, and also depending on whether or not they signed a commitment to change form. | No effect | Age | No
Gerstein, 1999^53^ | Gender | Seven-hour small group workshop for family physicians | Sub-scores on participant questionnaire about diabetes knowledge, attitude, practice behavior | No effect | Years in practice, family practice certification, solo or group practice, full or part-time, practice size | No
Grady, 1997^79^ | Gender | Educational presentation with/without cue enhancement with/without feedback rewards | Cueing had a positive impact on mammography rates above education alone, but feedback and rewards had no added benefit | No effect | Age, gender, practice setting, board certification, specialty, foreign medical graduate vs. US graduate, group size, AMA membership, residency vs no residency | No
Gerstein, 1999^53^ | Board certification (family practice) | Seven-hour small group workshop for family physicians | Sub-scores on participant questionnaire about diabetes knowledge, attitude, practice behavior | No effect | Years in practice, gender, solo or group practice, full or part-time, practice size | No
Grady, 1997^79^ | Board certification (family practice or IM) | Educational presentation with/without cue enhancement with/without feedback rewards | Cueing had a positive impact on mammography rates above education alone, but feedback and rewards had no added benefit | Greater effect on non board certified in bivariate model but not significant in multivariate | Age, gender, practice setting, board certification, specialty, foreign medical graduate vs. US graduate, group size, AMA membership, residency vs no residency | No
Soumerai, 1987^105^ | Board certification | Printed educational materials and visits by clinical pharmacists | Intensity of prescribing target drugs | No effect | Age, practice setting, specialty, professional boards, intensity of target drug use, Medicaid practice size, nursing home practice size | Yes
Grady, 1997^79^ | Race | Educational presentation with/without cue enhancement with/without feedback rewards | Cueing had a positive impact on mammography rates above education alone, but feedback and rewards had no added benefit | Intervention more effective in nonwhites in multivariate analysis | Age, gender, practice setting, board certification, specialty, foreign medical graduate vs. US graduate, group size, AMA membership, residency vs no residency | No
Grady, 1997^79^ | Practice setting: solo vs. other | Educational presentation with/without cue enhancement with/without feedback rewards | Cueing had a positive impact on mammography rates above education alone, but feedback and rewards had no added benefit | Intervention more effective in solo practitioners in multivariate analysis | Age, gender, practice setting, board certification, specialty, foreign medical graduate vs. US graduate, group size, AMA membership, residency vs no residency | No
Soumerai, 1987^105^ | Practice setting: rural vs. non-rural | Printed educational materials and visits by clinical pharmacists | Intensity of prescribing target drugs. | No effect | Age, practice setting, board certification, professional boards, intensity of target drug use, Medicaid practice size, nursing home practice size | Yes
Grady, 1997^79^ | Specialty (FP vs. IM) | Educational presentation with/without cue enhancement with/without feedback rewards | Cueing had a positive impact on mammography rates above education alone, but feedback and rewards had no added benefit | No effect | Age, gender, practice setting, board certification, specialty, foreign medical graduate vs. US graduate, group size, AMA membership, residency vs no residency | No
Lewis, 1993^70^ | Specialty | Day-long program on HIV using videotape, group discussion, small group workshops, and lecture | Increased frequency of sexual history questions asked | Internists, but not FPs or Ob/Gyns, were affected by the intervention. | None | No
Lane, 1991^69^ | Specialty | Multiple CME interventions AND low-cost mammography | Compliance with mammography screening guidelines | Ob/Gyns had the highest base-line screening levels, but still showed an increase in screening recommendations after the intervention. FP's improved significantly more than OB/Gyns. | Not specified | No
Des Marchais, 1990^61^ | Specialty | 2 training sessions on interpersonal skills | Pre- and post- average deviation score: participant's scoring of interpersonal interactions in videotape, compared with median group score | Psychiatrists had less deviation from median of group both pre- and post-, compared with family physicians | None | No
Soumerai, 1987^105^ | Specialty (IM vs. FP) | Printed educational materials and visits by clinical pharmacists | Intensity of prescribing target drugs. | No effect | Age, practice setting, board certification, professional boards, intensity of target drug use, Medicaid practice size, nursing home practice size | Yes
Grady, 1997^79^ | U.S. vs. foreign medical graduation | Educational presentation with/without cue enhancement with/without feedback rewards | Cueing had a positive impact on mammography rates above education alone, but feedback and rewards had no added benefit | No effect | Age, gender, practice setting, board certification, specialty, foreign medical graduate vs. US graduate, group size, AMA membership, residency vs no residency | No
Grady, 1997^79^ | Residency trained vs. no residency | Educational presentation with/without cue enhancement with/without feedback rewards | Cueing had a positive impact on mammography rates above education alone, but feedback and rewards had no added benefit | Intervention more effective in non residency trained in bivariate analysis but not in multivariate | Age, gender, practice setting, board certification, specialty, foreign medical graduate vs. US graduate, group size, AMA membership, residency vs no residency | No

AMA = American Medical Association; FP = family practitioner; Ob/Gyn = obstetrician/gynecologist; IM = internal medicine; US = United States; CME = continuing medical education

Table 16 Validity and/or reliability of tools to measure the effectiveness of continuing medical education

Author, year | Evaluation method | Pilot or cognitive testing | Method previously used (If “yes,” did method change) | Type of validity measured (comparison method) | Statistic for validity measure | Statistic measured for current or previous study | Type of reliability measured | Statistic for reliability measure | Statistic measured for current or previous study
Knowledge / Cognitive Skills
Fordis, 2005^42^ | Knowledge test about cholesterol / CAD risk and management, using multiple-choice questions and case vignettes with fixed-choice responses. | Yes | No | Face / content (Not reported) | NA | Current study | Internal consistency (inter-item) reliability | Cronbach's alpha: 0.79 averaged across pre- and post-testing | Current study
Macrae, 2004^85^ | Locally developed test of critical appraisal skills pilot tested on group of residents with internal consistency (in pilot and current study) and inter-rater reliability (pilot) as described below. Small modification of evaluation- decreasing number of articles used from 3 (in pilot) to 2 (in current), but claimed that this change has “minimal impact” on alpha reliability (dropped to 0.74) or “the evidence of validity” which wasn't otherwise quantified. | Yes | Yes (questions changed) | Face, content, and construct validity (experts and comparisons not reported) | | | Internal consistency (inter-item) reliability | Cronbach's alpha: 0.74 | Current study
Andersen, 1990^36^ | Diagnostic Knowledge Inventory, a measure of psychiatric knowledge based on DSM-III / DSM-IIIR criteria using 18 paragraph-length case vignettes about affective and anxiety disorders (discussed in intervention) and other disorders not discussed. Item-pool of 72 vignettes reviewed by team of experts and reduced through item-analysis in trained and untrained sample. Response options yes/no, 24-choice diagnoses, 7-point Likert for treatment options. Pre- and post-test versions with randomized vignette order. | No | Yes (no changes) | Face / content (Team of experts not specified) | KR 20 = 0.89 | Prior study | Internal consistency | Split-half and item-to-total KR20: 0.82–0.90 | Prior study
| | | | External construct (known group) | 55% difference in score between experts & non-experts; p<0.0001 for “diagnosis” cases | Prior study | Equivalence reliability | R=0.92, p<0.0001 | Prior study
Doucet, 1998^40^ | The Key Features Problem (KFP) was a 28-item mailed exam developed from guidelines by investigators to test on topics related to headache. 38-item pilot test was given to intervention and control groups for item-analysis. | Yes | No | Face / content (Experts/ sources: Two neurologists with interest in headache treatment ) | NA | Current study | Internal consistency (inter-item) reliability | Kuder-Richardson method: 0.71 (pilot sample only) | Current study
White, 1985^48^ | Knowledge test for in-hospital treatment of acute myocardial infarction, combining multiple-choice action items and true/false concept items corresponding to course objectives. Pilot tested on 15 physicians. Different versions used same items with change in order. | Yes | No | Face / content (Experts/ sources: 4 cardiovascular faculty and 2 family practice faculty ) | NA | Current study | Internal consistency (inter-item) reliability | Cronbach's alpha: 0.57–0.82 | Current study
Chung, 2004^54^ | 34-item multiple-choice questionnaire to assess bioterrorism diagnosis and management, using case scenarios. After review by expert panel, test was given to pilot group of 3 physicians in one exam period. Final test delivered by web. | Yes | No | Face / content (Experts/ sources: Physicians in EM, Ped EM, Peds, ID, medical toxicology, and medical informatics | NA | | Equivalence reliability | Average absolute difference of 8% | Current study
Gifford, 1999^142^ | Questionnaire / test using three clinical scenarios about dementia diagnosis and management, with open-ended responses about diagnosis, closed-ended choice of 12 diagnostic tests, additional write-in diagnostic tests, and additional write-in options. Test was developed by study neurologists, reviewed by advisory panel, and piloted in 8 neurologists. Mailed 8-page test was scored by 3 physician investigators | Yes | No | Face / content (Experts/ sources: AAN advisory panel) | NA | Current study
| | | | Concurrent Criterion (Chart review on subset of 22 physicians' charts) | Percent agreement: 95–99% for EEG, Apo E test, and referral to Safe Return Program; 47–77% for referral to Alzheimer's Association and diagnosis of and prescription for depression; 27–49% for neuro-imaging use | Current study
Chan, 1999^21^ | Multiple choice test assessing physician knowledge of geriatric psychiatry, administered by e-mail. | No | Yes (no changes) | Face / content (Experts/ sources: geriatrician, psychiatrist, and family physician) | NA | Current study
Gerrity, 1999^32^ | 54-item knowledge test about depression diagnosis and management. Pilot testing by facilitators and investigators, with retention of items if all 7 agreed on answer. | Yes | Yes (changed, but unclear how; test based on objecttives and derived from other test) | Face / content (Experts/ sources: literature review and workshop contents) | NA | Current study
Maxwell, 1984^57^ | 30-item multiple-choice test for evaluating knowledge gains at medical evaluation committee meetings. Senior resident and experts in relevant fields reviewed test, then pretested in resident physicians. | Yes | No | Face / content (Experts/ sources: NR) | NA | Current study
Premi, 1993^38^ | Knowledge test about the diagnosis and management of chest pain. 94 questions covering 5 specified domains. Reviewed by 8 residents for interpretability, reading level, ambiguity, double-barreled questions, jargon, value-laden terms, positive-negative wording, and length. Two versions created with software for randomized sampling and balancing. | Yes | No | Face / content (Experts/ sources: Consultants and practicing physicians) | NA | Current study
Gifford, 1996^46^ | Survey instrument to assess subjects' decision making and adherence to 16 practice recommendations on disease detection, diagnostic test use, and treatments for neurology topics. Developed by 2 investigators from guidelines and course content, using 7 clinical scenarios. Response options included write-in diagnoses, 12-choice test options, write-in management, and other open-ended questions. Pilot tested in 27 neurologists. | Yes | No | Face / content (Experts/ sources: seven experts designed course & reviewed content of the scenarios) | NA | Current study
| | | | External (known group) validity (Comparison: Readers within the intervention group were more likely to report adherence to practice recommendations) | Readers were 1.7–6.3 × more likely to report adherence | Current study
Stewart, 2005^43^ | Physician knowledge test, measured by questionnaire, of preventive / screening practices related to perimenopausal patient (21 items) and type 2 diabetes (22 items). | No | Yes (unclear if changed) | External construct (known group) | Statistic not reported | Current study
Slotnick, 1993^17^ | 24-item knowledge test about drug prescribing information for two drugs, Bumex (older drug) and Mazicon (newer drug). Response options included multiple-choice and true/false. | No | No | | | | Equivalence reliability | Split-half correlations and Spearman Brown prophecy calculations conducted but not reported | Current study
Hergenroeder, 2002^60^ | Knowledge test about ankle and knee examination | No | Yes (unclear if changes) | | | | Reliability: not specified | Statistic not reported | Prior study
Attitudes (and/or Knowledge)
Meredith, 2000^51^ | Self-administered, mailed physician questionnaire on depression treatment. Questionnaires included batteries of questions that have been previously evaluated for reliability & validity & batteries that were specifically developed for their study. Included items of depression knowledge (12-item scale) measuring endorsement of AHRQ guidelines. Response options: 5-point Likert scale from very false to very true, 3 reversed items. | No | Yes (No changes made) | Face / content (Experts/ sources: Panel of clinicians determined “nonambiguous” indicators of knowledge) | NA | Current study
Mann, 1997^52^ | 60-item physician questionnaire about knowledge and attitudes towards cholesterol-lowering practices. Response options included true/false and Likert. Experts agreed on >90% of questions and rest deleted. Piloted by FPs for internal consistency. | No | No | Face / content (3 experts not specified) | NA | Current study | Test-retest reliability | Correlation coefficient: knowledge r= 0.54–0.75; attitude/ practice component r=0.54–0.69 | Current study
| | | | | | | Internal consistency | KR=0.60 | Previous study
Mann, 1997^52^ | Physicians' perceptions of self-efficacy in counseling on cholesterol-lowering, hypertension, and smoking management practices, using 14-items and Likert scale. | No | No | | | | Test-retest reliability | Correlation coefficient: pre & posttest 1 r=0.79, pre & posttest 2 r=0.78, posttest 1&2 r=0.68 | Current study
Chodosh, 2006^62^ | Short scale for providers' perceptions of quality of care for dementia patients, comprising Likert scales and administered through mailed survey 9 months after intervention initiated. | Yes | No | | | | Internal consistency (inter-item) reliability | Cronbach's alpha: 0.75 | Current study
Lockyer, 2002^64^ | Written survey for knowledge and comfort in dementia management. 5-point scale for involvement-level in patient management; true/false and multiple-choice knowledge items for total score of 14; 3-point comfort score from 13 items. | No | No | | | | Internal consistency (inter-item) reliability | Cronbach's alpha: 0.56 for cognitive (pre- and post-), 0.88 & 0.93 (pre- and post-) for comfort | Current study
Elliott, 1997^55^ | Survey of physician and nurse knowledge and attitudes towards cancer pain management: 15 knowledge items on 5-point scale and 9 attitude items on 11-point scale | No | Yes (modified: unclear how) | | | | Internal consistency (inter-item) reliability | Cronbach's alpha: knowledge 0.68 for physicians and 0.67 for nurses; attitude 0.78 for physicians and 0.77 for nurses (with 2 items omitted) | Current study
White, 2004^63^ | Case-based 25 item, multiple-choice questionnaire of scenarios faced by community physicians treating asthma patients, to measure knowledge, skills, attitudes (confidence) towards asthma management. Visual analog scale used to assess confidence about answers. | Unclear | Yes (unclear if changed) | | | | Internal consistency (inter-item) reliability | Cronbach's alpha: 0.71 – 0.95, increasing with each administration | Current study
Skills (communication, psychomotor, or procedural)
Hergenroeder, 2002^60^ | Clinical Skills Assessment Examination (CSAE) using standardized patient to evaluate performance of ankle / knee exam by checklist: Interrater reliability of baseline rater evaluated in previous study of residents' performance using the same CSAE as that used in current study. SP (certified athletic trainer) used published checklist to rate as observer. | No | Yes (unclear if changes) | | | | Inter-rater reliability | Ankle and knee Cronbach alpha = 0.99 and 0.90, ankle and knee respectively | Prior study
Skills (communication, psychomotor, or procedural) Assessed in the Practice Setting (Practice Behaviors)
Greenberg, 1985^25^ | Standardized patients' assessment of the appropriateness of medical plan given by the learner for managing common pediatric problems. 6 sets of SP mothers/children with case histories on 4 topics; SP mother completed checklist after visit; senior author rated records after visits for validation. | No | No | Concurrent Criterion (Senior author's evaluation of medical records) | Correlation coefficient: 0.60 p<0.001 | Current study
Gerrity, 1999^32^ | Kaplan's 3-item Participatory Decision-Making scale, as completed by standardized patient after visit. | No | Yes (adapted, unclear how) | | | | Internal consistency (inter-item) reliability | Cronbach's alpha: 0.91 | Current study
Roter, 1995^84^ | Simulated patient visits about globus hystericus associated with unresolved grief were audiotaped and then scored by blinded coders for clinical proficiency. 97 clinical and psychologic items; 3 male physicians at Hopkins trained as blinded SPs; 10 categories and overall summed score as well as subscales. | No | No | | | | Internal consistency (inter-item) reliability | Cronbach alpha: Range of 0.76 to 0.81 for scales with four or more items; Range of 0.20 to 0.62 for scales with 2 or 3 items; Reliability for the overall score was 0.62. | Current study
Roter, 1995^84^ | Proficiency in the management of emotional distress by physicians audiotaped in a few real patient visits. The audiotapes were analyzed to determine how often the physicians used each skill that was mentioned in the CME activities. This evaluates the reliability of blinded coders based on 20 tapes. | No | No | | | | Inter-rater reliability | Correlation coefficient: 0.69 for emotion-handling skills; 0.80 for problem-defining skills | Current study
Beaulieu, 2002^140^ | Standardized patient visits for the periodic health exam (male and female scenario), 2 scenarios (man / woman). | No | Yes (questions, response options changed) | | | | Inter-rater reliability for coding | Kappa: K=0.66 female (90.5%); K=0.68 male scenario (90.1%) | Current study
| | | | | | | Degree of conformity of SP with scenario | 93.5% female; 84.8% male | Current study
Carney, 1995^88^ | Physicians' cancer-control clinical skills as measured through standardized patients after encounters. Reliability was tested for standardized-patient accuracy in case replication and in recall of study variables - monitored by audiotaping of encounters through hidden recorders. Pilot tested in 3 practice sessions, videotaped; only SPs with >90% recall accuracy and maintenance of scenarios retained; 9 SPs used | No | No | | | | Inter-rater reliability | Kappa: 0.93 indexed (range 0.87–1.0) | Current study
Levinson, 1993^138^ | RIAS content analysis of audiotaped patient encounters (measurement of communication skills behaviors); also 6-point scale for Global Affect Ratings for physicians and patients. Interrater reliability tested for 34 tapes, with random 2nd coder to check for coder decay and drift; interrater reliability for 17 components (others not frequent enough to do analysis). | Unclear | Yes (no changes) | | | | Inter-rater reliability | Pearson Correlation coefficient: averaged 0.80, range 0.55–0.94; Percent Agreement 0.33–1.00 for global affect ratings scales | Current study
Gerrity, 1999^32^ | Standardized patients to assess physician communication on depression, completed form after visit. | No | Yes (no changes) | | | | Inter-rater reliability | Statistic not reported | Current study
Gerrity, 1999^32^ | ABIM Patient Satisfaction Scale, 9-item, 5-point Likert scales, completed by standardized patients after visit | No | Yes (shorter version compared with citation) | Validity: not specified | | Previous study | Reliability: not specified | | Previous study
Stewart, 2005^43^ | Physician behavior in prevention and diabetes management, as assessed by standardized patient and checklists | No | Yes (unclear if changes made) | Validity: not specified
Self-reported Practice Behaviors with Knowledge and/or Attitudes
Gerstein, 1999^53^ | Survey about diabetes care knowledge, attitudes, and practice behaviors, as self-reported by primary care clinicians. 120 true/false items drafted / modified by endocrinologists, administered in two 58-question halves. 18 FPs tested in crossover design to test for test-retest and equivalence. Translated to and from French translation. Attitude scales used a 5-point Likert scale. | No | Yes (unclear if changes made) | Face / content (Experts/ sources: literature review and workshop contents) | NA | Current study | Test-retest reliability | Correlation coefficient: Intraclass correlation coefficients 0.8–0.87 | Prior study
| | | | | | | Equivalence reliability | Not given | Prior study
| | | | External construct (known group) (Comparison: Administration to medical students, residents, family physicians, and diabetes specialists (endocrinologists)) | ANOVA p=0.02 for attitude, p=0.0001 knowledge, p=0.012 practice | Prior study | Internal consistency (inter-item) reliability | Cronbach's alpha: 0.64 attitude, 0.13 knowledge, 0.63 practice | Prior study
McBride, 2000^144^ | Physician and staff questionnaires about use of prevention care documentation tools and services | No | No | Concurrent Criterion (Comparison: physician and staff phone interviews for 22%) | Statistic not reported | Current study
Schroy, 1999^82^ | Pre- and post-provider survey (mail or phone) to assess provider attitudes / practices in colorectal cancer screening. Based on ACS 1989 survey: Piloted to full-time providers within site. Yes/no and Likert responses. Actual utilization through appt logs / referrals. | Yes | Yes (unclear) | Concurrent validity | Kappa: 0.67 between self-report and utilization (referrals) for sigmoidoscopy | Current study
Clark, 2000^78^ | Physician self-report of clinical behaviors related to asthma management | No | Yes (no changes) | Predictive Criterion (Comparison: parent description of physician behavior ) | Statistic not reported | Prior study
Terry, 1981^49^ | Self-assessment questionnaires about knowledge, attitudes, and clinical practice behaviors related to COPD. 44-multiple-choice questions constructed using “standard test development procedures”; 25 items on subsequent tests, chosen based on reliability coefficients | No | No | | | | Internal consistency (inter-item) reliability | Cronbach's alpha: 0.80 on baseline test | Current study
Lane, 2001^45^ | Physician barriers to screening for breast cancer (CME need) based on skills, knowledge, and resources on a pre-intervention survey, with physicians categorized as high or low need for CME. Cronbach's alphas were calculated to determine inter-item reliability of the subscales of the test of CME intervention need. | No | Yes (no changes) | | | | Internal consistency (inter-item) reliability | Cronbach's alpha: 0.65 (overall), 0.77 for non-adherence, individual subscales ranged 0.44 for breast exam to 0.78 for counseling need | Current study
Brown, 1999^72^ | Learner (clinician) questionnaire about dealing with patients and routine communication style (skills, attitudes, and behaviors in communication) | No | Yes (unclear if changes made) | Validity: not specified | | Previous study
Practice Behaviors
Sibley, 1982^136^ | Abstraction of medical chart data to assess quality of documentation of clinical care processes for common medical conditions. Nurse abstractors trained and blinded; outcome was proportion of episodes of care classified as superior or adequate. | No | No | Face / content (Experts/ sources: Peer group of experienced clinicians and consultants) | NA | Current study | Intra-rater reliability | Kappa: >0.8 | Current study
| | | | | | | Inter-rater reliability | Kappa: >0.8
Brown, 1999^72^ | Art of Medicine Survey, a patient questionnaire about clinician's communication behavior and patient's reaction to it. Being administered by contractor to HMO, but no published reference to development or use of questionnaire. Mailed survey, 8 items; survey shown to be correlated with observed and experimentally manipulated differences in communication performance | No | Yes (no changes) | Concurrent Criterion (Comparison: Satisfaction) | Spearman Correlation coefficient: 0.92 | Current study | Internal consistency (inter-item) reliability | Cronbach's alpha: 0.97 | Current study
| | | | | | | | Correlation coefficient: 0.69–0.84 for 7 communications questions
Ozer, 2005^104^ | Adolescent Report of the Visit: an independent survey of provider screening behavior involving interviews by staff with patients / families after well visits. Distributed by research/clinic staff after MD visit, completed anonymously, yes/no responses. Included 45 items physician behavior; described as “valid indicator of delivery of services” with “construct validity.” | Unclear | Yes (length changed) | Construct validity | Statistic not reported | Prior study
Schectman, 1996^16^ | Claims based prescribing data as a measure of practice behavior | No | No | Concurrent Criterion (Comparison: Chart audit data) | 100% reliability for prescribing drug info, 92% for prescribing MD - % agreement? | Current study
Socolar, 1998^134^ | Chart audit of quality of physician documentation in evaluation for sexual abuse: rater scores of individual history and physical exam items documented. Up to 5 records from each MD assessed by two blinded reviewers; 3 reviewers total; 16 items assesed in each; if disagreed on 2 items or more by >=2 Likert scale, 3rd reviewer | No | Unclear | | | | Inter-rater reliability | Kappa: 0.75 (subsample of 30 charts once and all charts during second period) | Current study
| | | | | | | Test-retest reliability | Kappa: 0.96 (subsample of 60 charts done at two time periods) | Current study
Margolis, 2004^118^ | Blinded chart review data abstraction to assess preventive services for children - interrater reliability assessed on random 20% of charts | No | Yes (unclear if changes made) | | | | Inter-rater reliability | Kappa: above 0.85 for each preventive service | Current study
Fordis, 2005^42^ | Chart review to assess appropriate lipid screening and treatment in high-risk patients. Generalized Kappa averaged across dichotomously scored outcomes of primary interest (lipid screening and drug treatment); other outcomes for percent agreement. | No | Unclear | | | | Inter-rater reliability | Percentage agreement: 94.7% Kappa: 0.83 | Current study
| | | | | | | | <0.4% error rate on 10% sample
Schectman, 2003^108^ | Chart audit assessment of guideline-consistent behavior for low back pain management: independent patient record review (100 records, oversampled for utilization events) by clinician investigators blinded to prior audit findings | No | No | | | | Inter-rater reliability | Kappa: 0.55; Disagreements almost all due to 1 criterion; without item, residual misclassification <2% of events, mostly due to chart abstraction or data entry | Current study
Jennett, 1988^76^ | Chart abstraction for practice behaviors related to 3 cardiovascular and 3 cancer topics. 2 part-time data abstractors reviewed records selected by appointment / billing records; intraconsistency checks for both abstractors 1 year following training period with still high level of consistency | Yes | Unclear | | | | Inter-rater reliability | Statistic unclear: >0.95 | Current study
McBride, 2000^144^ | Chart review for use of cardiovascular risk tools and documentation of cardiovascular risk factor assessment and management; blinded abstracters at baseline, but not at 12 or 18 months; 100% of charts reviewed at baseline; at 12 / 18 months, random 2nd reviews on 10% | No | No | | | | Inter-rater reliability | Half of second reviews showed no data differences, and error rate on others was 1.3% | Current study
White, 1985^48^ | Medical record audit for appropriate in hospital management of acute myocardial infarction. 1 trained abstractor on project staff; not aware of desired medical practices for most objectives; Iowa Foundation for Medical Care helped develop audit; 1 audit per objective; exclusion criteria specified for cases; rated on 3-point scale; field tested; re-audit time not specified | Yes | No | | | | Intra-rater reliability | Percentage agreement: 84% | Current study
Rost, 2001^22^ | Services Assessment of Children and Adolescents: Patient self-report telephone interview about pharmacotherapy; concordance of physician depression treatment behavior with AHCPR guidelines was measured. | No | Yes (added questions) | | | | Test-retest reliability | Statistic not reported | Prior study
Moran, 1996^121^ | College of Family Physicians of Canada Practice Assessment Program (PASS). Clinical patient care, charting, prevention, and drug use as measured by PASS scores in database; physician questionnaire, patient questionnaire, chart review based on consensus criteria. | Yes | Yes (unclear if changes made) | Validity: not specified | | Prior study | Reliability: not specified | | Prior study
Clinical Outcomes
Maiman, 1988^47^ | Assessment of medication compliance by mothers' self-reports, as compared with home visit liquid/pill assessment: number of missed doses, measured during home visit 8 days after visit with MD. 20-minute structured interview with mothers | No | Unclear | Concurrent Criterion: (Comparison: mother self-report of missed doses in home interview vs. liquid / pill check vs. physician report | Correlation coefficient: Liquid/pill vs. self-report of missed doses 0.241; liquid/pill vs. self-report 0.367; compared with pediatricians report p<=0.05 | Current study
Kim, 1999^137^ | Patient survey about physician provision of preventive services, validated by medical record review. Surveyed by mail or f/u telephone; Usually medical records did not support pt recall of offered services | No | No | Concurrent Criterion: (Comparison: medical record review ) | Percentage agreement: Disagreements 20–40% of time | Current study
Roter, 1995^84^ | General Health Questionnaire, 28-item, to detect psychiatric distress in patients. “Self-administered screening test to detect psychiatric distress in community and nonpsychiatric medical settings.” Cut-off for scores not specified. | No | Yes (unclear if changes made) | | | | Internal consistency (inter-item) reliability | Cronbach's alpha: 0.92 | Current study
Elliott, 1997^55^ | Brief Pain Inventory: measure of cancer patients pain over last 7 days using 4-items and 11-point Likert scale | No | Yes (unclear) | | | | Internal consistency (inter-item) reliability | Cronbach's alpha: 0.83 | Current study
Elliott, 1997^55^ | Survey of patient and family knowledge (5-point scale) and attitudes (11-point scale) towards cancer pain management, modified from provider questionnaires - items for knowledge did not have adequate internal consistency (statistic not reported). | Yes | Yes (modified: unclear how) | | | | Internal consistency (inter-item) reliability | Cronbach 0.80 for pt attitude, 0.83 for family (total scale only - lower on subscales); knowledge scores without adequate internal consistency. | Current study
Gullion, 1988^132^ | Medical record abstraction to assess provider behavior and clinical outcomes regarding appropriate medication and behavioral management of hypertension | Yes | No | | | | Inter-rater reliability | Percentage agreement: 89–92% among 4 abstractors, baseline and re-assessment respectively | Current study
Kim, 1999^137^ | Chart review for preventive care services provided | No | No | | | | Inter-rater reliability | Percentage agreement: 100
Norris, 2000^81^ | Patient questionnaires regarding physical activity and health status: SF-36, Washburn's Physical Activity Scale for the Elderly (PASE), Paffenbarger's physical activity index; administered in-person at baseline and 6 months. | No | Yes (modified PASE subscales, unclear how) | Validity: not specified | | Previous study | Reliability: not specified | | Previous study

NA = not applicable; NR = not reported; EM = emergency medicine; Ped = pediatrics; ID = infectious disease; AAN = American Academy of Neurology; MCQ = multiple choice questionnaire; AHRQ = Agency for Healthcare Research and Policy; AHCPR = Agency for Health Care Policy and Research (now AHRQ); SP = standardized patient; CME = continuing medical education; RIAS = Roter Interactional Analysis System; KR = Kuder-Richardson; ANOVA = analysis of variance; COPD = chronic obstructive pulmonary diseases; HMO = health maintenance organization; ABIM = American Board of Internal Medicine; EEG = electroencephalography