# Appendix E: Data Abstraction Forms

To see the Data Abstraction Forms, please select the link below. This link will take you to a PDF version of the forms.

Data Abstraction Forms