# Appendix D: List of Excluded Articles

## References

Abidi F, Lee-Gorman M. Learning from experience: developments in forensic investigation from case histories. Sci Justice. 2005;45(1):45-51. Not US or Canada, Does not apply. [pmid: 15739692].
Adelson R, Hepburn K, Reed R, et al. Effective dissemination of the AHCPR guideline: prevention and early management of pressure ulcers. Abstract Book/Association for Health Services Research. 97;14:167-8. Abstract.
Ahluwalia NS, Das A, Verity R. Radical curriculum design: an experiment in learner empowerment. Med Educ. 2005;39(5):509-10. Not US or Canada. [pmid: 15842689].
AIDS education in general practice. N Z Med J 88;101(859):835–6 No evaluation, Does not apply
A-Latif A. Continuing medical education: merits of a surgical journal club. Med Teach. 90;12(2):219-21. Not US or Canada. [pmid: 2079897].
Alexander B, Nasrallah HA, Perry PJ. The impact of psychopharmacology education on prescribing practices. HOSP COMMUNITY PSYCHIATRY. 83;34(12):1150-1153. <15 trained physicians, No comparison. [pmid: 6642462].
Aloisio G, Barone L, Bergamasco M et al. Computer-based simulator for catheter insertion training. Stud Health Technol Inform 2004;984–6 No original data, No training, Not US or Canada
Alroy G, Ber R, Kramer D. An evaluation of the short-term effects of an interpersonal skills course. MED EDUC. 84;18(2):85-89. Not US or Canada. [pmid: 6700452].
Amatayakul M. Self-assessment for continuing education. Council on Certification of the American Health Information Management Association. J AHIMA 92;63(2):83–4, 109–11 No original data, No evaluation
Amiel GE, Ungar L, Alperin M, et al. Ability of primary care physician's to break bad news: a performance based assessment of an educational intervention. Patient Educ Couns. 2006;60(1):10-5. Not US or Canada. [pmid: 16122897].
Amin Z, Hoon Eng K, Chay Hoon T. A novel approach to faculty development programme evaluation. Med Educ. 2004;38(11):1187-8. <15 trained physicians, Not US or Canada. [pmid: 15507020].
Amos E, White MJ. Problem-based learning. Nurse Educ. 98;23(2):11-4. <15 trained physicians. [pmid: 9582794].
Anders K T. Click and learn. Continuing education on the Web. Contemp Longterm Care 2000;23(11):suppl 12–4 No original data, No evaluation
Andrews JO, Tingen MS, Waller JL, et al. Provider feedback improves adherence with AHCPR Smoking Cessation Guideline. Prev Med. 2001;33(5):415-21. <15 trained physicians. [pmid: 11676582].
Athanasiadis L, Papaharitou S, Salpiggidis G, et al. Educating physicians to treat erectile dysfunction patients: development and evaluation of a course on communication and management strategies. J Sex Med. 2006;3(1):47-55. Not US or Canada, No comparison. [pmid: 16409217].
Avorn J, Soumerai SB, Everitt DE, et al. A randomized trial of a program to reduce the use of psychoactive drugs in nursing homes. N Engl J Med. 92;327(3):168-73. <15 trained physicians. [pmid: 1608408].
Awad SS, Fagan SP, Bellows C, et al. Bridging the communication gap in the operating room with medical team training. Am J Surg. 2005;190(5):770-4. Does not apply, No comparison. [pmid: 16226956].
Ayoub MM, Clark JA. Reduction of fresh frozen plasma use with a simple education program. Am Surg. 89;55(9):563-5. No comparison. [pmid: 2774365].
Backhaus J, Junghanns K, Mueller-Popkes K, et al. Short-term training increases diagnostic and treatment rate for insomnia in general practice. Eur Arch Psychiatry Clin Neurosci. 2002;252(3):99-104. Not US or Canada. [pmid: 12192465].
Baldwin CD, Gephart D, Maulitz R. Collaborative planning of a Web-based learning resource for primary care education. Acad Med. 2001;76(5):549-50. <15 trained physicians. [pmid: 11346599].
Barsuk D, Ziv A, Lin G et al. Using advanced simulation for recognition and correction of gaps in airway and breathing management skills in prehospital trauma care. Anesth Analg 2005;100(3):803–9, table of contents <15 trained physicians, Not US or Canada
Barta PJ, Phillips WD, Davidson R. Physician education on five complications of diabetes mellitus. N J Med. 94;91(4):269-70. No comparison. [pmid: 8202276].
Bashook P, Meyer TC, Richards RK, et al. Symposium: Self-directed learning and physicians' practice changes: concepts, research and implications for CME. Proc Annu Conf Res Med Educ. 86;25:329-38. No original data.
Belda TE, Gajic O, Rabatin JT, et al. Practice variability in management of acute respiratory distress syndrome: bringing evidence and clinician education to the bedside using a web-based teaching tool. Respir Care. 2004;49(9):1015-21. No comparison. [pmid: 15329172].
Ben-Arye E, Frenkel M, Hermoni D. An approach to teaching primary care physicians how to integrate complementary medicine into their daily practices: a pilot study. J Altern Complement Med. 2006;12(1):79-83. <15 trained physicians, Not US or Canada, No comparison. [pmid: 16494572].
Ben-Arye E, Frenkel M. An approach to teaching physicians about complementary medicine in the treatment of cancer. Integr Cancer Ther. 2004;3(3):208-13. Not US or Canada. [pmid: 15312262].
Benjamin EM, Schneider MS, Hinchey KT. Implementing practice guidelines for diabetes care using problem-based learning. A prospective controlled trial using firm systems. Diabetes Care. 99;22(10):1672-8. <15 trained physicians, PI or QI, Other.
Bennett P. The process of postgraduate education in general practice. Practitioner. 87;231(1436):1298-302. No original data, No evaluation. [pmid: 3505024].
Beno L, Hinchman J, Kibbe D, et al. Design and implementation of training to improve management of pediatric overweight. J Contin Educ Health Prof. 2005;25(4):248-58. No comparison. [pmid: 16365897].
Berkenstadt H, Ziv A, Barsuk D et al. The use of advanced simulation in the training of anesthesiologists to treat chemical warfare casualties. Anesth Analg 2003;96(6):1739–42, table of contents Not US or Canada
Berkowitz K J, Anderson L A, Panayioto R M et al. Mini-residency on diabetes care for healthcare providers: enhanced knowledge and attitudes with unexpected challenges to assessing behavior change.. Diabetes Educ 98;24(2):143–144, 149 <15 trained physicians, No comparison
Berntson A, Goldner E, Leverette J, et al. Psychiatric training in rural and remote areas: increasing skills and building partnerships. Can J Psychiatry. 2005;50(9):1-8. No original data, No original data. [pmid: 16262109].
Birnbaum ML, Robinson NE, Kuska BM, et al. Effect of advanced cardiac life-support training in rural, community hospitals. Crit Care Med. 94;22(5):741-9. No comparison. [pmid: 8181281].
Bjornson DC, Rector TS, Daniels CE, et al. Impact of a drug-use review program intervention on prescribing after publication of a randomized clinical trial [see comment]. American journal of hospital pharmacy. 90;47(7):1541. Other. [pmid: 2368745].
Black F. “You show me yours and I'll show you mine”. A new CME option—learning from your own consultations. Aust Fam Physician. 94;23(9):1788-90. No original data, Not US or Canada. [pmid: 7980180].
Blackstien-Hirsch P, Anderson G, Cicutto L, et al. Implementing continuing education strategies for family physicians to enhance asthma patients' quality of life. J Asthma. 2000;37(3):247-57. No comparison. [pmid: 10831149].
Blum RH, Raemer DB, Carroll JS, et al. Crisis resource management training for an anaesthesia faculty: a new approach to continuing education. Med Educ. 2004;38(1):45-55. No comparison. [pmid: 14962026].
Boland MR, Hornblow AR, Gibbs JM, et al. The learning process in medical education. NEW ZEALAND MED J. 85;98(788):861-863. No original data. [pmid: 3864041].
Booth MB. Teaching and learning in a neonatal intensive care unit. Arch Dis Child. 98;78(3):275-7. No original data, Not US or Canada. [pmid: 9613365].
Bordley WC, Travers D, Scanlon P, et al. Office preparedness for pediatric emergencies: a randomized, controlled trial of an office-based training program. Pediatrics. 2003;112(2):291-5. PI or QI. [pmid: 12897276].
Borgiel AE, Williams JI, Davis DA, et al. Evaluating the effectiveness of 2 educational interventions in family practice. CMAJ. 99;161(8):965-70. PI or QI. [pmid: 10551192].
Botelho RJ, McDaniel SH, Jones JE. Using a family systems approach in a balint-style group: an innovative course for continuing medical education. Fam Med. 90;22(4):293-5. <15 trained physicians, No comparison. [pmid: 2384204].
Boudreau D, Tamblyn R, Dufresne L. Evaluation of consultative skills in respiratory medicine using a structured medical consultation. Am J Respir Crit Care Med. 94;150(5 Pt 1):1298-304. <15 trained physicians, Does not apply. [pmid: 7952556].
Bratton SL, Cabana MD, Brown RW, et al. Asthma educational seminar targeting Medicaid providers. Respir Care. 2006;51(1):49-55. No comparison. [pmid: 16381618].
Bravata D M, Huot S J, Abernathy H S et al. The development and implementation of a curriculum to improve clinicians' self-directed learning skills: a pilot project. BMC Med Educ 2003;37 <15 trained physicians
Brezis M, Cohen R. Interactive learning with voting technology. Med Educ. 2004;38(5):574-5. No original data, <15 trained physicians. [pmid: 15107127].
Brown RL. Evaluation of a continuing medical education program for primary care physicians on the management of alcoholism. J Med Educ. 88;63(6):482-4. No comparison. [pmid: 3286871].
Brown RM. What do phonemes have to do with learning medicine?. Acad Med. 2005;80(5):455. No original data. [pmid: 15851456].
Brown RM. What do phonemes have to do with learning medicine?. Acad Med. 2005;80(5):455. Does not apply. [pmid: 15851456].
Browning P, Foss G. Evaluation of rehabilitation continuing education. Annu Rev Rehabil 83;364–92 No original data
Burlingame GM, Earnshaw D, Hoag M, et al. A systematic program to enhance clinician group skills in an inpatient psychiatric hospital. Int J Group Psychother. 2002;52(4):555-587. No original data, <15 trained physicians. [pmid: 12375487].
Burr R, Johanson R. Continuing medical education: an opportunity for bringing about change in clinical practice. Br J Obstet Gynaecol. 98;105(9):940-5. No original data. [pmid: 9763043].
Byrne AJ, Sellen AJ, Jones JG, et al. Effect of videotape feedback on anaesthetists' performance while managing simulated anaesthetic crises: a multicentre study. Anaesthesia. 2002;57(2):176-9. Not US or Canada. [pmid: 11871957].
Byrnes JA, Kulick TA, Schwartz DG. Information-seeking behavior changes in community-based teaching practices. J Med Libr Assoc. 2004;92(3):334-40. No comparison. [pmid: 15243639]. [pmcid: 442175].
Cabana MD, Slish KK, Evans D et al. Randomized control trial of physician education to improve pediatric outcomes for asthma [Abstract]. American Thoracic Society 2005 International Conference; May 20–25; San Diego, California 2005;[D93][Poster: 626]Abstract
Cahan JI. Continuing medical education. An effective tool or a faulty fantasy?. Md Med. 2001;2(3):14-6. No original data, No evaluation. [pmid: 11525143].
Cameron C, Naylor CD. No impact from active dissemination of the Ottawa Ankle Rules: further evidence of the need for local implementation of practice guidelines. CMAJ. 99;160(8):1165-8. <15 trained physicians, Not US or Canada. [pmid: 10234347].
Campbell C, Parboosingh J, Gondocz T, et al. A study of the factors that influence physicians' commitments to change their practices using learning diaries. Acad Med. 99;74(10 Suppl):S34-6. No training, No comparison. [pmid: 10536587].
Campbell DD. Implementing and evaluating continuing professional education: elements of a strategy. Physiother Can. 83;35(5):253-6. No original data. [pmid: 10262975].
Campbell HS, Fletcher SW, Pilgrim CA, et al. Improving physicians' and nurses' clinical breast examination: a randomized controlled trial. Am J Prev Med. 91;7(1):1-8. <15 trained physicians. [pmid: 1867894].
Campbell NR, McAlister FA, Brant R, et al. Temporal trends in antihypertensive drug prescriptions in Canada before and after introduction of the Canadian Hypertension Education Program. J Hypertens. 2003;21(8):1591-7. No comparison. [pmid: 12872055].
Carbonell JL, Chez RA, Hassler RS. Florida physician and nurse education and practice related to domestic violence. Womens Health Issues. 95;5(4):203-7. No evaluation, No comparison. [pmid: 8574116].
Cardenas VM, Roces MC, Wattanasri S, et al. Improving global public health leadership through training in epidemiology and public health: the experience of TEPHINET. Training Programs in Epidemiology and Public Health Interventions Network. Am J Public Health. 2002;92(2):196-7. No original data, Does not apply. [pmid: 11818290]. [pmcid: 1447041].
Carlson B. A day spent learning how to satisfy patients. Manag Care. 97;6(9):57-60. No original data, Does not apply. [pmid: 10173826].
Carpenter JL, Battles JB, McIntire D, et al. Assessing the usefulness of using standardized patients in a clinical medicine course. Acad Med. 92;67(4):286. <15 trained physicians. [pmid: 1558610].
Casebeer LL, Strasser SM, Spettell CM, et al. Designing tailored Web-based instruction to improve practicing physicians' preventive practices. J Med Internet Res. 2003;5(3):e20. No original data, Does not apply, Other. [pmid: 14517111].
Casebeer L, Kristofco RE, Strasser S, et al. Standardizing evaluation of on-line continuing medical education: physician knowledge, attitudes, and reflection on practice. J Contin Educ Health Prof. 2004;24(2):68-75. No original data, No comparison. [pmid: 15279131].
Cauffman JG, Rasgon IM, Mayne JC. Relationship between quality of CME instruction and changes in physicians' patient-management plans. J MED EDUC. 85;60(6):486-488. No comparison. [pmid: 4009656].
Centor R, Casebeer L, Klapow J. Using a combined CME course to improve physicians' skills in eliciting patient adherence. Acad Med. 98;73(5):609-10. No comparison. [pmid: 9643932].
Cerne F. Learning to survive. Continuing education is helping health care managers thrive in today's managed care-driven environment. Hosp Health Netw 95;69(17):47–8, 50 No original data, Does not apply
Chen FM, Burstin H, Huntington J. The importance of clinical outcomes in medical education research. Med Educ. 2005;39(4):350-1. No original data. [pmid: 15813754].
Cherkin D, Deyo RA, Berg AO. Evaluation of a physician education intervention to improve primary care for low-back pain. II. Impact on patients. Spine. 91;16(10):1173-8. No comparison. [pmid: 1836677].
Chopra V, Gesink BJ, de Jong J, et al. Does training on an anaesthesia simulator lead to improvement in performance?. Br J Anaesth. 94;73(3):293-7. Not US or Canada. [pmid: 7946851].
Clark KM. Notes on continuing education: Self-Directed Learning Network. J Contin Educ Nurs. 86;17(3):101-3. No original data, No evaluation. [pmid: 3086399].
CME evaluation. Semin. Oncol. 2005;32(SUPPL. 2):S23 Does not apply
CME evaluation. Semin. Oncol. 2005;32(SUPPL. 2):S23 No original data
CME examination for volume 41Include entire volume with the exception of the CME articles. J Am Acad Dermatol 2000;42(6):33–6 No original data, No evaluation
CME examination. Am J Obstet Gynecol 98;179(6 Pt 2):114–8 No original data
CME examination. J. Am. Acad. Dermatol. 2005;53(2):210–212 No original data, No evaluation, Does not apply
CME examination: July 2005. Pediatr. Emerg. Care 2005;21(7):457 No original data, No evaluation, Does not apply
CME quiz & evaluation. Ca Cancer J. Clin. 2005;55(4):260–264 No original data, No evaluation, Does not apply
Cohen SJ, Stookey GK, Katz BP, et al. Encouraging primary care physicians to help smokers quit. A randomized, controlled trial. Ann Intern Med. 89;110(8):648-52. <15 trained physicians. [pmid: 2930095].
Cole TB, Glass RM. Learning associated with participation in journal-based continuing medical education. J Contin Educ Health Prof. 2004;24(4):205-12. No comparison. [pmid: 15709560].
Coleman EA, Stewart CB, Wilson S, et al. An evaluation of standardized patients in improving clinical breast examinations for military women. Cancer Nurs. 2004;27(6):474-82. <15 trained physicians, PI or QI. [pmid: 15640625].
Collins R, Hammond M. Self-directed learning to educate medical educators, Part 2: Why do we use self-directed learning?. Med Teach. 87;9(4):425-32. No original data., Not US or Canada. [pmid: 3505324].
Connolly Nancy K, Williams Mark E. Facilitating Change through CME in Geriatrics. Journal of Continuing Education in the Health Professions. 92;12(4):215-224. No comparison.
Continuing education: keeping pace with the changing scene. Council on Practice Continuing Education Committee. J Am Diet Assoc 88;88(10):1224–5 No original data, Does not apply
Continuing Medical Education examination: EBV the prototypical human tumor virus - Just how bad is it?. J. Allergy Clin. Immunol. 2005;116(2):262 No original data, Does not apply
Continuing Medical Education examination: Innate immune responses to infection. J. Allergy Clin. Immunol. 2005;116(2):250 No original data, Does not apply
Cook DA. Internet-based continuing medical education. JAMA. 2006;295(7):758. author reply 758–9 No original data. [pmid: 16478897].
Craig M, Nichols A, Price D. Education for general practitioners proposing to administer anaesthesia in rural general practice. Anaesth Intensive Care. 93;21(4):432-41. Not US or Canada. [pmid: 8214550].
Craychee GA. The psychosocial dimension of professional continuing education: behavioral intentions. Radiol Technol. 87;58(6):529-35. <15 trained physicians, Does not apply. [pmid: 3615845].
Crow WC. Using “pearls” to ensure that learners learn key information. Fam Med. 2004;36(9):619-21. No original data, <15 trained physicians, No training, No evaluation. [pmid: 15467935].
Cunningham AM, Edwards A, Jones KV, et al. Evaluation of a service development to increase detection of urinary tract infections in children. J Eval Clin Pract. 2005;11(1):73-6. Not US or Canada. [pmid: 15660540].
Curtis JR, Rubenfeld GD, Hudson LD. Training pulmonary and critical care physicians in outcomes research: should we take the challenge?. Am J Respir Crit Care Med. 98;157(4 Pt 1):1012-5. No original data. [pmid: 9563712].
Curtis JR, Rubenfeld GD, Hudson LD. Training pulmonary and critical care physicians in outcomes research: should we take the challenge?. Am J Respir Crit Care Med. 98;157(4 Pt 1):1012-5. Does not apply. [pmid: 9563712].
Curtis P, Carey TS, Evans P, et al. Training primary care physicians to give limited manual therapy for low back pain: patient outcomes. Spine. 2000;25(22):2954-60. discussion 2960–1 No comparison. [pmid: 11074684].
Da Costa M. Practice-based continuing medical education. Educ Gen Pract. 99;10(1):70-72. <15 trained physicians, No comparison.
D'Alessandro MP, Galvin JR, Erkonen WE, et al. The instructional effectiveness of a radiology multimedia textbook (HyperLung) versus a standard lecture. Invest Radiol. 93;28(7):643-8. <15 trained physicians. [pmid: 8344816].
Dankelman J, Wentink M, Grimbergen CA, et al. Does virtual reality training make sense in interventional radiology? Training skill-, rule- and knowledge-based behavior. Cardiovasc Intervent Radiol. 2004;27(5):417-421. No original data, Not US or Canada. [pmid: 15383842].
Dark GG. Learning on the Internet. Br J Hosp Med. 97;58(11):572-4. No original data. [pmid: 10193473].
Dauphinee WD. Role of examinations of the Medical Council of Canada in improving medical standards. CAN MED ASSOC J. 81;124(11):1425-1427. No original data. [pmid: 7237322].
David TJ, Dolmans DH, Patel L, et al. Problem-based learning as an alternative to lecture-based continuing medical education. J R Soc Med. 98;91(12):626-30. No original data, Does not apply. [pmid: 10730109].
Davis D, O'Brien MAT, Freemantle N, et al. Review: Interactive, but not didactic, continuing medical education is effective in changing physician performance. Evid.-Based Med. 2000;5(2):64. No original data.
Davis D. Evaluating continuing medical education: common sense and science. CMAJ. 86;134(5):485-6. No original data. [pmid: 3948061].
Davis MH, Karunathilake I. The place of the oral examination in today's assessment systems. Med Teach. 2005;27(4):294-7. No original data. [pmid: 16024410].
Dayal R, Faries PL, Lin SC, et al. Computer simulation as a component of catheter-based training. J Vasc Surg. 2004;40(6):1112-7. <15 trained physicians. [pmid: 15622364].
de Burgh S, Mant A, Mattick RP, et al. A controlled trial of educational visiting to improve benzodiazepine prescribing in general practice. Aust J Public Health. 95;19(2):142-8. Not US or Canada. [pmid: 7786939].
De Muylder R, Tonglet R, Nackers F, et al. Randomised evaluation of a specific training of general practitioners in cardiovascular prevention. Acta Cardiol. 2005;60(2):199-205. Not US or Canada. [pmid: 15887477].
Deeb LC, Pettijohn FP, Shirah JK, et al. Interventions among primary-care practitioners to improve care for preventable complications of diabetes. Diabetes Care. 88;11(3):275-80. <15 trained physicians, PI or QI. [pmid: 3416683].
Delmont G. Using electronic portfolios to document learning. Athl Ther Today. 2003;8(4):22-23. No evaluation, Does not apply.
Delvaux N, Razavi D. Psychological training for health-care professionals in oncology. A way to improve communication skills. Ann N Y Acad Sci. 97;809:336-49. No original data. [pmid: 9103585].
Devitt P, Worthley S, Palmer E, et al. Evaluation of a computer based package on electrocardiography. Aust N Z J Med. 98;28(4):432-5. Not US or Canada. [pmid: 9777109].
Diarrhoeal Diseases Control Programme. Supervisory skills training course. Wkly Epidemiol Rec 90;65(42):326–7 No original data, <15 trained physicians, No evaluation, Not US or Canada, Does not apply
Dibbern DA, Wold E. Workshop-based learning: a model for teaching ethics. JAMA. 95;274(9):770-1. No original data, Does not apply. [pmid: 7650833].
DiMatteo MR. Evidence-based strategies to foster adherence and improve patient outcomes. JAAPA. 2004;17(11):18-21. No original data. [pmid: 15575518].
Din-Dzietham R, Porterfield DS, Cohen SJ, et al. Quality care improvement program in a community-based participatory research project: example of Project DIRECT. J Natl Med Assoc. 2004;96(10):1310-21. No comparison. [pmid: 15540882]. [pmcid: 2568538].
DM program cuts back pain costs by educating, supporting primary care physicians. Healthc Demand Dis Manag 99;5(10):149–53 Abstract, No evaluation, PI or QI
Dolan NC, Ng JS, Martin GJ, et al. Effectiveness of a skin cancer control educational intervention for internal medicine housestaff and attending physicians. J Gen Intern Med. 97;12(9):531-6. <15 trained physicians. [pmid: 9294786].
Dornan T, David T. Adult learning and continuing education. Diabet Med. 2000;17(1):78-80. No original data, Does not apply. [pmid: 10691165].
Dornbusch D, Allegra C, Willey J, et al. How Do U.S. Medical Oncologists Learn and Apply New Clinical Trials Information from Press Releases in Nonmedical Media? A Case Study Based on ECOG 4599. Oncologist. 2006;11(1):31-8. No training, No comparison. [pmid: 16401711].
D'Orsi CJ, Karellas A, Costanza ME, et al. Preliminary report of an intervention to improve mammography skills of radiologists. Prog Clin Biol Res. 89;293:151-7. No comparison. [pmid: 2726930].
Dougherty M. Going the distance. Balancing work and education in a distance learning program. J AHIMA. 2005;76(6):38-42. No human data, <15 trained physicians, Does not apply. [pmid: 15986560].
Dowell J, Pagliari C, McAleer S. Development and evaluation of a concordance training course for medical practitioners. Med Teach. 2004;26(4):384-6. <15 trained physicians, Not US or Canada, No comparison. [pmid: 15203857].
Du Pen AR, Du Pen S, Hansberry J, et al. An educational implementation of a cancer pain algorithm for ambulatory care. Pain Manag Nurs. 2000;1(4):116-28. <15 trained physicians. [pmid: 11709865].
Duggan CM. Designing effective training. J AHIMA. 2005;76(6):28-32. quiz 33–4 Does not apply. [pmid: 15986558].
Dumay AC, Jense GJ. Endoscopic surgery simulation in a virtual environment. Comput Biol Med. 95;25(2):139-48. No original data, Not US or Canada. [pmid: 7554832].
Duncan AK, Multari A, Li J. Curriculum in physician-patient communication skills for new faculty. Acad Med. 2002;77(5):462. No original data, Does not apply. [pmid: 12010721].
Dutta PK. Continuing medical education of general practitioners on MCH care through distance learning. Indian J Public Health. 96;40(3):68-70. Not US or Canada. [pmid: 9119425].
Dykes PC, Acevedo K, Boldrighini J, et al. Clinical practice guideline adherence before and after implementation of the HEARTFELT (HEART Failure Effectiveness & Leadership Team) intervention. J Cardiovasc Nurs. 2005;20(5):306-14. <15 trained physicians. [pmid: 16141775].
Eisenberg J. Changing provider behavior: is it possible?. Clin Perform Qual Health Care. 96;4(4):204-5. No original data, Does not apply. [pmid: 10162155].
El Ansari W, Pearson D, Davis T. Satisfaction with interprofessional education? Influences of learners' demographic and academic characteristics. J Interprof Care. 2002;16(2):174-175. <15 trained physicians, Not US or Canada.
Elkin PL, Gorman PN. Continuing medical education and patient safety: an agenda for lifelong learning. J Am Med Inform Assoc. 2002;9(6 Suppl):S128-32. No original data, No evaluation. [pmid: 12386200]. [pmcid: 419436].
Emlet CA, da Silva P. Medications, behavior and the elderly: a continuing education program for board and care facility operators. Gerontol Geriatr Educ. 86;6(4):41-51. <15 trained physicians, No comparison. [pmid: 3653711].
Evans AW, McKenna C, Oliver M. Self-assessment in medical practice. J R Soc Med. 2002;95(10):511-513. No original data. [pmid: 12356978]. [pmcid: 1279183].
Evans PR. CME in general practice. Postgrad Med J. 96;72(Suppl 1):S27-9. No training, Not US or Canada. [pmid: 8849515].
Ewart CK, Li VC, Coates TJ. Increasing physicians' antismoking influence by applying an inexpensive feedback technique. J Med Educ. 83;58(6):468-73. <15 trained physicians, No comparison. [pmid: 6854609].
Fallowfield L, Jenkins V, Farewell V, et al. Enduring impact of communication skills training: results of a 12-month follow-up. Br J Cancer. 2003;89(8):1445-9. Not US or Canada. [pmid: 14562015].
Farris KB, Kirking DM, Shimp LA, et al. Design and results of a group counter-detailing DUR educational program. Pharm Res. 96;13(10):1445-52. <15 trained physicians. [pmid: 8899833].
Fasel J, Sieber R, Rohr HP. Laservision-disk and computer-assisted medical learning. J Audiov Media Med. 86;9(1):15-6. No evaluation, Does not apply. [pmid: 2422243].
Featherstone HJ, LoGerfo JP, Barnes RH. Performance-based continuing medical education. Prophylactic cephalosporin use in hysterectomy patients. QUAL REV BULL. 83;9(6):169-174. <15 trained physicians.
Feighny KM, Monaco M, Arnold L. Empathy training to improve physician-patient communication skills. Acad Med. 95;70(5):435-6. <15 trained physicians. [pmid: 7748400].
Fiallo VM, O'Connor FX, Reed WP. Preceptored introduction of laparoscopic techniques for cholecystectomy into a large university-affiliated medical center. Surg Endosc. 94;8(9):1063-6. <15 trained physicians, No comparisonv. [pmid: 7992176].
Fincher RM, Abdulla AM, Sridharan MR, et al. A prospective educational trial comparing efficacy of computer-assisted learning and weekly seminars in teaching EKG interpretation. Proc Annu Conf Res Med Educ. 86;25(-):3-7. <15 trained physicians.
Finestone A J, Lanzilotti S S, Marks A D et al. An assessment of practice-based CME. Pa Med 87;90(6):45–6, 48 No comparison
Fishbein RH. Professionalism and “the master clinician”—an early learning experience. J Eval Clin Pract. 2000;6(3):241-3. No original data, Does not apply. [pmid: 11083034].
Folberg R, Dickinson LK, Christiansen RA, et al. Interactive videodisc and compact disc-interactive for ophthalmic basic science and continuing medical education. Ophthalmology. 93;100(6):842-50. No original data, No evaluation. [pmid: 8510895].
Fox RD, Bennett NL. Continuing medical education. Learning and change: Implications for continuing medical education. Br Med J. 98;316(7129):466-468. No original data. [pmid: 9492684].
Fox S, Tsou CV, Klos DS. Increasing mammography screening: An application of general principles of CME methodology. J PSYCHOSOM OBSTET GYNECOL. 85;4(2):95-104. <15 trained physicians.
Frenkel M, Ben-Arye E, Hermoni D. An approach to educating family practice residents and family physicians about complementary and alternative medicine. Complement Ther Med. 2004;12(23):118-25. Not US or Canada, No comparison. [pmid: 15561521].
Friedenberg RM. Medical education and practice in a new environment. Radiology. 97;202(3):33A-36A. No original data, Does not apply.
Friedmann P, Selbovitz LG. Continuous quality improvement and physician training. Qual Manag Health Care. 92;1(1):13-9. No original data, No evaluation, Does not apply. [pmid: 10131642].
Friss L, Lass S. An evaluation approach for continuing education programs in the health professions. Mobius. 82;2(1):5-13. No original data, No comparison. [pmid: 10257610].
Fustukian S, Macdonald J. Health action is: continuing education for PHC. HealthAction 94;(8):2 Other
Gainford M C, McCready D, Cohen Z et al. The latest is the greatest? Results of a structured lecture about aromatase inhibitor use for breast cancer. Breast Cancer Res Treat 2005;1–4 No comparison
Gallagher AG, McClure N, McGuigan J, et al. Virtual reality training in laparoscopic surgery: a preliminary assessment of minimally invasive surgical trainer virtual reality (MIST VR). Endoscopy. 99;31(4):310-3. Not US or Canada. [pmid: 10376458].
Gallagher RE, Smith DU. Formulation of teaching/learning objectives useful for the development and assessment of lessons, courses, and programs. J Cancer Educ. 89;4(4):231-4. No original data, No evaluation. [pmid: 2641341].
Gask L, Dowrick C, Dixon C, et al. A pragmatic cluster randomized controlled trial of an educational intervention for GPs in the assessment and management of depression. Psychol Med. 2004;34(1):63-72. Not US or Canada, Not US or Canada. [pmid: 14971627].
Gautam V, Heyworth J. A method to measure the value of formal training in trauma management: comparison between ATLS and induction courses. Injury. 95;26(4):253-5. Not US or Canada. [pmid: 7649626].
Gemson DH, Ashford AR, Dickey LL, et al. Putting prevention into practice. Impact of a multifaceted physician education program on preventive services in the inner city. Arch Intern Med. 95;155(20):2210-6. <15 trained physicians. [pmid: 7487243].
Gilbert J H. Interprofessional education for collaborative, patient-centred practice.. Can J Nurs Leadersh 2005;18(2):32–36, 38 No original data, Does not apply
Giovino GA, Cummings KM, Koenigsberg MR, et al. An evaluation of a physician training program on patient smoking cessation. Prog Clin Biol Res. 90;339:27-48. <15 trained physicians. [pmid: 2392425].
Girgis A, Sanson-Fisher RW, Howe C, et al. A skin cancer training programme: evaluation of a postgraduate training for family doctors. Med Educ. 95;29(5):364-71. Not US or Canada. [pmid: 8699975].
Glassman PA, Luck J, O'Gara EM, et al. Using standardized patients to measure quality: evidence from the literature and a prospective study. Jt Comm J Qual Improv. 2000;26(11):644-53. No evaluation. [pmid: 11098427].
Glazier RH, Badley EM, Lineker SC, et al. Getting a Grip on Arthritis: an educational intervention for the diagnosis and treatment of arthritis in primary care. J Rheumatol. 2005;32(1):137-42. <15 trained physicians. [pmid: 15630739].
Godfrey J, Dennick R, Welsh C. Training the trainers: do teaching courses develop teaching skills?. Med Educ. 2004;38(8):844-7. Not US or Canada. [pmid: 15271044].
Goettner P. Effective e-learning for healthcare.. Health Manag Technol 2000;21(12):64, 63 No original data
Goldberg HI, Wagner EH, Fihn SD, et al. A randomized controlled trial of CQI teams and academic detailing: can they alter compliance with guidelines?. Jt Comm J Qual Improv. 98;24(3):130-42. PI or QI. [pmid: 9568553].
Gomel MK, Wutzke SE, Hardcastle DM, et al. Cost-effectiveness of strategies to market and train primary health care physicians in brief intervention techniques for hazardous alcohol use. Soc Sci Med. 98;47(2):203-11. Not US or Canada. [pmid: 9720639].
Gonzalez-Willis A, Rafi I, Boekeloo B, et al. Using simulated patients to train physicians in sexual risk assessment and risk reduction. Acad Med. 90;65(9 Suppl):S7-8. No comparison. [pmid: 2400511].
Gopalakrishnan G, Devarajan V. StapSim: a virtual reality-based stapling simulator for laparoscopic hemiorrhaphy. Stud Health Technol Inform. 2004;98:111-3. No training, Does not apply. [pmid: 15544253].
Gordon MS, Ewy GA, Felner JM, et al. A cardiology patient simulator for continuing education of family physicians. J Fam Pract. 81;13(3):353-6. No comparison. [pmid: 7276845].
Gordon SM, Troncale J. Evaluation of the effectiveness of an addiction treatment training program for physicians. Am Clin Lab. 2002;21(5):22-4. <15 trained physicians. [pmid: 12122780].
Gore MJ. Outcomes assessment: Latest way to gauge the value of CLS education. CLIN LAB SCI. 91;4(2):70-73. No original data.
Gormley GJ, Steele WK, Stevenson M, et al. A randomised study of two training programmes for general practitioners in the techniques of shoulder injection. Ann Rheum Dis. 2003;62(10):1006-9. Not US or Canada. [pmid: 12972483]. [pmcid: 1754313].
Goulet F, Jacques A, Gagnon R. An innovative approach to remedial continuing medical education, 1992-2002. Acad Med. 2005;80(6):533-40. Does not apply, No comparison. [pmid: 15917355].
Greco M, Buckley J, Francis W. Triads: An effective method for learning the art of listening. EDUC GEN PRACT. 97;8(4):329-337. Not US or Canada.
Greenberg LW, Jewett LS. The impact of two educational techniques on physician knowledge, performance and patient care. Mobius. 84;4(4):51-4. Other. [pmid: 10269872].
Greene RA, Beckman H, Chamberlain J, et al. Increasing adherence to a community-based guideline for acute sinusitis through education, physician profiling, and financial incentives. Am J Manag Care. 2004;10(10):670-8. No comparison. [pmid: 15521158].
Griffin GA, Barry SM. Muscle and joint pain: design and evaluation of courses for general practitioners. J R Coll Gen Pract. 81;31(232):661-8. Not US or Canada. [pmid: 6977027].
Grogan EL, Stiles RA, France DJ, et al. The impact of aviation-based teamwork training on the attitudes of health-care professionals. J Am Coll Surg. 2004;199(6):843-8. No comparison. [pmid: 15555963].
Groveman HD, Ganiats TG, Klauber MR, et al. Computer-assisted assessment of family physicians' knowledge about cancer screening guidelines. West J Med. 85;143(4):541-4. No comparison. [pmid: 3911588].
Groveman HD, Sanowski RA, Klauber MR. Training primary care physicians in flexible sigmoidoscopy—performance evaluation of 17,167 procedures. West J Med. 88;148(2):221-4. No comparison. [pmid: 3348037].
Grunwald T, Clark D, Fisher SS, et al. Using cognitive task analysis to facilitate collaboration in development of simulator to accelerate surgical training. Stud Health Technol Inform. 2004;98:114-20. No training, No evaluation. [pmid: 15544254].
Guenther SM, Laube DW, Matthes S. Effectiveness of the gynecology teaching associate in teaching pelvic examination skills. J MED EDUC. 83;58(1):67-69. <15 trained physicians. [pmid: 6848762].
Gullion DS, Adamson TE, Watts MS. The effect of an individualized practice-based CME program on physician performance and patient outcomes. West J Med. 83;138(4):582-8. No comparison. [pmid: 6868584].
Gullion DS, Adamson TE. A practice-based CME program in hypertension using a medication and behavioral treatment approach. Proc Annu Conf Res Med Educ. 85;24:207-12. No comparison.
Gurwitz JH, Noonan JP, Soumerai SB. Reducing the use of H2-receptor antagonists in the long-term-care setting [see comment]. Journal of the American Geriatrics Society. 92;40(4):359. No comparison. [pmid: 1348256].
Hall P, Hupe D, Scott J. Palliative care education for community-based family physicians: the development of a program, the evaluation, and its consequences. J Palliat Care. 98;14(3):69-74. No comparison. [pmid: 9770925].
Halm EA, Horowitz C, Silver A, et al. Limited impact of a multicenter intervention to improve the quality and efficiency of pneumonia care. Chest. 2004;126(1):100-7. <15 trained physicians, No comparison, PI or QI. [pmid: 15249449].
Hamstra SJ, Dubrowski A. Effective training and assessment of surgical skills, and the correlates of performance. Surg Innov. 2005;12(1):71-7. No original data, <15 trained physicians. [pmid: 15846449].
Handler S. Does continuing medical education affect medical care. A study of improved transfusion practices. Minn Med. 83;66(3):167-80. Does not apply, Other. [pmid: 6855731].
Handmaker NS, Hester RK, Delaney HD. Videotaped training in alcohol counseling for obstetric care practitioners: A randomized controlled trial. Obstet Gynecol. 99;93(2):213-218. <15 trained physicians. [pmid: 9932558].
Hardern RD. Teaching and learning evidence based medicine skills in accident and emergency medicine. J Accid Emerg Med. 99;16(2):126-129. No original data. [pmid: 10191449].
Harewood GC, Yusuf TE, Clain JE, et al. Assessment of the impact of an educational course on knowledge of appropriate EUS indications. Gastrointest Endosc. 2005;61(4):554-9. No comparison. [pmid: 15812408].
Harper G, Norris D, Woo B. Physician education in a diverse society: listening to and learning from new voices. Pharos Alpha Omega Alpha Honor Med Soc. 95;58(2):39-42. No original data, No training. [pmid: 7784489].
Harris GD. Professionalism: part II — teaching and assessing the learner's professionalism. Fam Med. 2004;36(6):390-2. No original data, No training, Does not apply. [pmid: 15181546].
Harris IB, Wempner J. Continuing medical education reconceived: evaluation of a sabbatical program for physicians. Acad Med. 96;71(10 Suppl):S46-8. No comparison. [pmid: 8940932].
Harrison RV, Gallay LS, McKay NE, et al. The association between community physician's attendance at a medical center's CME courses and their patient referrals to the medical center. J Contin Educ Health Prof. 90;10(4):315-20. Does not apply. [pmid: 10109570].
Haynes R B, Johnston M E, McKibbon K A et al. A program to enhance clinical use of MEDLINE. A randomized controlled trial. Online J Curr Clin Trials 93;Doc No 56[4005 words; 39 paragraphs]<15 trained physicians
Heins HC, Miller JM, Childs D, et al. Perinatal educational programs and perinatal outcomes. J S C Med Assoc. 84;80(9):431-5. <15 trained physicians. [pmid: 6593500].
Henderson RW. Learners in your practice. Can Fam Physician. 95;41(-):32-33. No original data. [pmid: 7894277].
Herdson PB. Pathology, pathologists and problem-based learning. Pathology. 98;30(3):326-327. No original data, Not US or Canada. [pmid: 9770205].
Hinchman J, Beno L, Dennison D, et al. Evaluation of a training to improve management of pediatric overweight. J Contin Educ Health Prof. 2005;25(4):259-67. <15 trained physicians. [pmid: 16365901].
Hirsch IB, Goldberg HI, Ellsworth A, et al. A multifaceted intervention in support of diabetes treatment guidelines: a cont trial. Diabetes Res Clin Pract. 2002;58(1):27-36. <15 trained physicians. [pmid: 12161054].
Hochberger J, Euler K, Naegel A, et al. The compact Erlangen Active Simulator for Interventional Endoscopy: a prospective comparison in structured team-training courses on “endoscopic hemostasis” for doctors and nurses to the “Endo-Trainer” model. Scand J Gastroenterol. 2004;39(9):895-902. Not US or Canada. [pmid: 15513390].
Holloway RG, Gifford DR, Frankel MR, et al. A randomized trial to implement practice recommendations: design and methods of the Dementia Care Study. Control Clin Trials. 99;20(4):369-85. No training, Other. [pmid: 10440564].
Holmes DR, Fox RD, Tommaso C, et al. Renal and iliac artery stenting by interventional cardiologists and vascular surgeons: the Foundation to Advance Medical Education (FAME) initiative. Am Heart J. 2005;149(5):883-7. No comparison. [pmid: 15894972].
Holmes GR, Smith ME, Donald AG. Behavioral science in medical education: a 1985 updated bibliography. Psychol Rep. 85;57(3 Pt 1):895-9. No original data. [pmid: 3909189].
Holsgrove G. Getting the most out of distance learning. Practitioner. 91;235(1500):196-200. No evaluation, Does not apply. [pmid: 1852704].
Holsgrove G. Techniques for distance learning. Practitioner. 91;235(1501):296-300. No evaluation, Does not apply. [pmid: 1857665].
Hood AF. CME examination. J Am Acad Dermatol. 2005;53(3):389-392. No original data, Does not apply.
Horowitz CR, Goldberg HI, Martin DP, et al. Conducting a randomized controlled trial of CQI and academic detailing to implement clinical guidelines. Jt Comm J Qual Improv. 96;22(11):734-50. PI or QI. [pmid: 8937948].
Houge DR. Participant/observer evaluation in continuing medical education. J Med Educ. 81;56(6):527. Does not apply, No comparison. [pmid: 7346643].
HSJ awards 2005. Skills development. Winner: new standards for doctors' training that take in general management skills. Health Serv J 2005;115(5982):suppl 51–2 No original data, Does not apply
Huas D, Wallace P. Is participation in research as an investigator an effective form of continuing medical education?. Br J Gen Pract. 2000;50(461):982-3. Not US or Canada. [pmid: 11224971]. [pmcid: 1313886].
Hull AL, Wasman J, Goodnough LT. Effects of a CME program on physicians' transfusion practices. Acad Med. 89;64(11):681-5. <15 trained physicians, PI or QI. [pmid: 2803434].
Hull SA. Rheumatology education for general practice. Ann Rheum Dis. 91;50(Suppl 3):449-52. No original data. [pmid: 2059097].
Hummel LJ. An investigation of physician self-directed learning activities. Proc Annu Conf Res Med Educ. 85;24:213-8. No evaluation, Does not apply.
Hunt DM. Appraisal and assessment. Ann R Coll Surg Engl. 98;80(6 Suppl):281-3. No original data, No training. [pmid: 10343563].
Hunter TB. Electronic aids to education and practice in radiology: the personal computer in the radiologist's office. J Digit Imaging. 89;2(2):71-4. No original data. [pmid: 2488159].
Hutchinson L. Evaluating and researching the effectiveness of educational interventions. BMJ. 99;318(7193):1267-9. No original data. [pmid: 10231262].
Hux JE, Melady MP, DeBoer D. Confidential prescriber feedback and education to improve antibiotic use in primary care: a controlled trial. CMAJ. 99;161(4):388-92. PI or QI. [pmid: 10478162].
Hyler SE. APA Online CME Practice Guideline for the Treatment of Patients with Major Depressive Disorder. J Psychiatr Pract. 2002;8(5):315-9. No original data, <15 trained physicians, No evaluation, Does not apply. [pmid: 15985894].
Illes J, Glover GH, Wexler L, et al. A model for faculty mentoring in academic radiology. Acad Radiol. 2000;7(9):717-724. No comparison. [pmid: 10987334].
Inui TS, Yourtee EL, Williamson JW. Improved outcomes in hypertension after physician tutorials. A controlled trial. Ann Intern Med. 76;84(6):646-51. Pre 1981. [pmid: 937876].
Irvine Doran DM, Baker GR, Murray M, et al. Achieving clinical improvement: an interdisciplinary intervention. Health Care Manage Rev. 2002;27(4):42-56. <15 trained physicians, Other. [pmid: 12433246].
Jacobs B. Hardly child's play: implementing a pediatric-specific, integrated CPOE system. Midwest pediatric hospital tackles all the hurdles—needs assessment, clinician buy-in, training and measuring results—as it strengthens its patient safety efforts with wireless CPOE. Health Manag Technol. 2004;25(8):30-2. Does not apply, Other.
Jacobs K, Aja D, Hermenau D. Adult learning through case simulation. Am J Occup Ther. 94;48(11):1089-92. No original data. [pmid: 7840129].
Jansen JJ, Scherpbier AJ, Metz JC, et al. Performance-based assessment in continuing medical education for general practitioners: construct validity. Med Educ. 96;30(5):339-44. Not US or Canada, No comparison. [pmid: 8949472].
Jennett PA, Laxdal OE, Hayton RC, et al. Designing education interventions to improve physician performance in office practice. Mobius. 84;4(4):55-61. No evaluation. [pmid: 10269873].
Johannes B, Salnitski VP, Goeters KM, et al. Learning with simulation only—artificial skills. J Gravit Physiol. 2004;11(2):P27-8. No original data, <15 trained physicians. [pmid: 16231436].
Johnston M. Supporting learners. Nurs Times. 91;87(12):47-8. No evaluation, Does not apply. [pmid: 2008347].
Jones DL. Viability of the commitment-for-change evaluation strategy in continuing medical education. Acad Med. 90;65(9 Suppl):S37-8. No comparison. [pmid: 2400497].
Jones JM, James J, Rodin G, et al. The evaluation of a two-day interdisciplinary continuing education event in psychosocial oncology. J Cancer Educ. 2004;19(3):161-4. <15 trained physicians. [pmid: 15458871].
Jones R, Spencer J. Conference report: teaching old docs new tricks: research dissemination and professional behavioural change. Fam Pract. 93;10(2):229-30. No original data, No training. [pmid: 8359616].
Joos SK, Hickam DH, Gordon GH, et al. Effects of a physician communication intervention on patient care outcomes. J Gen Intern Med. 96;11(3):147-55. <15 trained physicians. [pmid: 8667091].
Jordan JA, Gallagher AG, McGuigan J, et al. Virtual reality training leads to faster adaptation to the novel psychomotor restrictions encountered by laparoscopic surgeons. Surg Endosc. 2001;15(10):1080-4. Not US or Canada. [pmid: 11727074].
Kaegi L. Using guidelines to change clinical behavior: dissemination through Area Health Education Centers and Geriatric Education Centers. QRB Qual Rev Bull. 93;19(5):165-9. No original data, Does not apply. [pmid: 8101363].
Kanter MH, van Maanen D, Anders KH, et al. A study of an educational intervention to decrease inappropriate preoperative autologous blood donation: its effectiveness and the effect on subsequent transfusion rates in elective hysterectomy. Transfusion. 99;39(8):801-7. <15 trained physicians.
Karlsten R, Strom K, Gunningberg L. Improving assessment of postoperative pain in surgical wards by education and training. Qual Saf Health Care. 2005;14(5):332-5. <15 trained physicians, Not US or Canada. [pmid: 16195565]. [pmcid: 1744078].
Karp JG, Hyler I, Wald M, et al. The use of an audiotaped analysis in a continuous case seminar. Psychoanal Q. 93;62(2):263-9. <15 trained physicians. [pmid: 8502730].
Katz HP, Goldfinger SE, Fletcher SW. Academia-industry collaboration in continuing medical education: description of two approaches. J Contin Educ Health Prof. 2002;22(1):43-54. No evaluation, Does not apply. [pmid: 12004640].
Katz S, Feigenbaum A, Pasternak S, et al. An interactive course to enhance self-efficacy of family practitioners to treat obesity. BMC Med Educ. 2005;5(1):4. Not US or Canada, No comparison. [pmid: 15679894]. [pmcid: 548513].
Kaufman J, Forman WB. Hospice and palliative care: an educational intervention for healthcare professionals in a rural community. Am J Hosp Palliat Care. 2005;22(6):415-8. <15 trained physicians, No comparison. [pmid: 16323710].
Kauth MR, Sullivan G, Henderson KL. Supporting clinicians in the development of best practice innovations in education. Psychiatr Serv. 2005;56(7):786-8. No original data, No evaluation, Does not apply. [pmid: 16020807].
Kemper KJ, Amata-Kynvi A, Sanghavi D, et al. Randomized trial of an internet curriculum on herbs and other dietary supplements for health care professionals. Acad Med. 2002;77(9):882-9. <15 trained physicians. [pmid: 12228083].
Kennedy A, Gask L, Rogers A. Training professionals to engage with and promote self-management. Health Educ Res. 2005;20(5):567-78. Not US or Canada. [pmid: 15741189].
Keyserling TC, Ammerman AS, Davis CE, et al. A randomized controlled trial of a physician-directed treatment program for low-income patients with high blood cholesterol: the Southeast Cholesterol Project. Arch Fam Med. 97;6(2):135-45. <15 trained physicians, PI or QI, Other.
Khan MS, Bann SD, Darzi A, et al. Assessing surgical skill. Plast Reconstr Surg. 2003;112(7):1886-9. No training, No evaluation. [pmid: 14663235].
Khan MS, Bann SD, Darzi A, et al. Assessing surgical skill. Plast Reconstr Surg. 2003;112(7):1886-9. No original data. [pmid: 14663235].
Kiessling A, Henriksson P, O'Malley PG, et al. Case method learning for general practitioners reduces cholesterol concentrations in coronary artery disease. Evid.-Based Med. 2003;8(3):95. No original data, Not US or Canada.
Kim M, Kim Y, Park JH. Development and utilization of computer-assisted learning (CAL) program for medical education. Medinfo. 95;8(Pt 2-):1173-1176. Not US or Canada. [pmid: 8591398].
Kinsinger LS, Harris R, Qaqish B, et al. Using an office system intervention to increase breast cancer screening. J Gen Intern Med. 98;13(8):507-14. PI or QI. [pmid: 9734786].
Kirby RL. Inspection-palpation-percussion-auscultation and an outcome-oriented alternative approach to the musculoskeletal examination. MED EDUC. 81;15(2):106-109. <15 trained physicians. [pmid: 7207269].
Kjeldmand D, Holmstrom I, Rosenqvist U. Balint training makes GPs thrive better in their job. Patient Educ Couns. 2004;55(2):230-5. Not US or Canada. [pmid: 15530759].
Klein LE, Charache P, Johannes RS. Effect of physician tutorials on prescribing patterns of graduate physicians. J Med Educ. 81;56(6):504-11. <15 trained physicians. [pmid: 7346637].
Knapp JF, Dowd MD, Kennedy CS, et al. Evaluation of a curriculum for intimate partner violence screening in a pediatric emergency department. Pediatrics. 2006;117(1):110-6. No comparison. [pmid: 16396867].
Knox JDE. Training of teachers in general medical practice. MED EDUC. 84;18(5):379-380. Not US or Canada, Does not apply.
Kort WJ, Marquet RL, Smith AR, et al. Evaluation of five training courses in microsurgery. Neth J Surg. 88;40(3):90-2. Not US or Canada, No comparison. [pmid: 3405446].
Kramer J. Teaching and learning in rural general practice. Aust Fam Physician. 2004;33(9):737-9. No original data, No training, No evaluation, Not US or Canada, Does not apply. [pmid: 15487369].
Kristofco RE, Hall SA, Chick E. Needs assessment survey. CME preferences, practices of West Virginia physicians. W V Med J. 87;83(5):223-5. No training, Does not apply. [pmid: 3473795].
Krombach G, Ganser A, Fricke C, et al. Virtual placement of frontal ventricular catheters using frameless neuronavigation: an “unbloody training” for young neurosurgeons. Minim Invasive Neurosurg. 2000;43(4):171-5. Not US or Canada. [pmid: 11270825].
Kuban KC, O'Shea M, Allred E, et al. Video and CD-ROM as a training tool for performing neurologic examinations of 1-year-old children in a multicenter epidemiologic study. J Child Neurol. 2005;20(10):829-31. No comparison. [pmid: 16417880].
Labelle M, Beaulieu M, Paquette D, et al. An integrated approach to improving appropriate use of anti-inflammatory medication in the treatment of osteoarthritis in Quebec (Canada): the CURATA model. Med Teach. 2004;26(5):463-70. No comparison. [pmid: 15369888].
LaDuca A, Leone-Perkins M, De Champlain A. Evaluating continuing competence of physicians through multiple assessment modalities: the Physicians' Continued Competence Assessment Program (PCCAP). Acad Med. 97;72(5):457-8. No evaluation, No comparison.
Ladyshewsky R. Simulated patients and assessment. Med Teach. 99;21(3):266-269. No original data, Not US or Canada.
Lalonde J. How physicians learn. Better methods of delivering CME using online practice-based learning. Cost Qual. 2000;6(3):29-31. No original data, No evaluation. [pmid: 11184817].
Lang L. CME series focuses on Patient-Centered GI Practice. Gastroenterology. 2004;127(1):5. No original data.
Lau MA, Dubord GM, Parikh SV. Design and feasibility of a new cognitive-behavioural therapy course using a longitudinal interactive format. Can J Psychiatry. 2004;49(10):696-700. No comparison. [pmid: 15560317].
Laube DW, Kretzschmar RM, Guenther SM, et al. A clinical skills instruction program: the acute abdomen. J Med Educ. 82;57(9):726-8. <15 trained physicians. [pmid: 7108934].
Lawson KA, Wilcox RE, Littlefield JH, et al. Educating treatment professionals about addiction science research: demographics of knowledge and belief changes. Subst Use Misuse. 2004;39(8):1235-58. <15 trained physicians, No comparison. [pmid: 15461020].
Lee E, McNally DL, Zuckerman IH. Evaluation of a physician-focused educational intervention on medicaid children with asthma. Ann Pharmacother. 2004;38(6):961-6. No comparison. [pmid: 15122003].
Lehmann HP, Lehmann CU, Freedman JA. The use of simulations in computer-aided learning over the World Wide Web. JAMA. 97;278(21):1788. No original data. [pmid: 9388163].
Lennard M. Vocational training for general practice—achievements of the last 15 years. Bristol Med Chir J. 85;100(375):72-3. No original data, No evaluation. [pmid: 3837680].
Lenow JL, Bales R, Smullens SN. The JeffCare preceptor model for asthma: a primary care physician tutorial training model. Dis Manag. 2003;6(1):35-42. No comparison. [pmid: 12899566].
Leviton LC, Goldenberg RL, Baker CS, et al. Methods to encourage the use of antenatal corticosteroid therapy for fetal maturation: a randomized controlled trial. JAMA. 99;281(1):46-52. <15 trained physicians. [pmid: 9892450].
Levy K, Aghababian RV, Hirsch EF, et al. An Internet-based exercise as a component of an overall training program addressing medical aspects of radiation emergency management. Prehospital Disaster Med. 2000;15(2):18-25. Not US or Canada. [pmid: 11183457].
Lewis CC, Pantell RH, Sharp L. Increasing patient knowledge, satisfaction, and involvement: randomized trial of a communication intervention. Pediatrics. 91;88(2):351-8. <15 trained physicians. [pmid: 1861939].
Linder JF, Blais J, Enders SR, et al. Palliative education: a didactic and experiential approach to teaching end-of-life care. J Cancer Educ. 99;14(3):154-60. No comparison. [pmid: 10512332].
Lloyd-Jones G, Margetson D, Bligh JG. Problem-based learning: a coat of many colours. Med Educ. 98;32(5):492-4. No original data. [pmid: 10211290].
Lorenz R A. Training health professionals to improve the effectiveness of patient education programs. Diabetes Educ 86;(12 Suppl):204–9 No original data
Love RR. Changing the health promotion behaviors of primary care physicians: lessons from two projects. Jt Comm J Qual Improv. 95;21(7):339-43. No original data, No comparison. [pmid: 7581737].
Lowy L. Continuing education in the later years: learning in the third age. Gerontol Geriatr Educ. 83;4(2):89-106. No original data. [pmid: 6677559].
Lozano P, Finkelstein JA, Carey VJ, et al. A multisite randomized trial of the effects of physician education and organizational change in chronic-asthma care: health outcomes of the Pediatric Asthma Care Patient Outcomes Research Team II Study. Arch Pediatr Adolesc Med. 2004;158(9):875-83. <15 trained physicians, Other. [pmid: 15351753].
Lyden P, Raman R, Liu L, et al. NIHSS training and certification using a new digital video disk is reliable. Stroke. 2005;36(11):2446-9. No comparison. [pmid: 16224093].
Lytle JS, Lytle BV, Youmans KG. Learning at a distance: people, technology, and learning experiments. J AHIMA. 95;66(7):64-7. No original data. [pmid: 10143535].
Mackay DM, Hardy S. Learning and teaching resource discovery in the Health and Life Sciences—partnership and interoperability. Health Info Libr J. 2005;22(Suppl 2):70-4. Not US or Canada. [pmid: 16279978].
Madridejos-Mora R, Amado-Guirado E, Perez-Rodriguez MT. Effectiveness of the combination of feedback and educational recommendations for improving drug prescription in general practice. Med Care. 2004;42(7):643-8. Not US or Canada. [pmid: 15213488].
Mainous AG 3rd, Hueston WJ, Love MM, et al. An evaluation of statewide strategies to reduce antibiotic overuse. Fam Med. 2000;32(1):22-9. PI or QI. [pmid: 10645510].
Makam R, Rajan CS, Brendon T, et al. Training and assessment of psychomotor skills for performing laparoscopic surgery using BEST-IRIS virtual reality training simulator. Stud Health Technol Inform. 2004;98:228-30. <15 trained physicians, Not US or Canada. [pmid: 15544276].
Manfredi C, Czaja R, Freels S, et al. Prescribe for health. Improving cancer screening in physician practices serving low-income and minority populations. Arch Fam Med. 98;7(4):329-37. <15 trained physicians. [pmid: 9682686].
Manley M, Epps RP, Husten C, et al. Clinical interventions in tobacco control. A National Cancer Institute training program for physicians. JAMA. 91;266(22):3172-3. No original data, No evaluation. [pmid: 1956107].
Margalit AP, Glick SM, Benbassat J, et al. Effect of a biopsychosocial approach on patient satisfaction and patterns of care. J Gen Intern Med. 2004;19(5 Pt 2):485-91. Not US or Canada. [pmid: 15109309]. [pmcid: 1492324].
Margolis KL, Money BE, Kopietz LA, et al. Evaluation of two interventions to improve physician diagnostic accuracy in recognizing glaucomatous changes of the optic disk. Proc Annu Conf Res Med Educ. 87;26(-):28-33. <15 trained physicians.
Marguet CG, Young MD, L'Esperance JO, et al. Hand assisted laparoscopic training for postgraduate urologists: the role of mentoring. J Urol. 2004;172(1):286-9. No training, No comparison. [pmid: 15201796].
Markert RJ, Barton JC, Rodin AE. Measuring participant learning and change in practice behavior for continuing medical education programs. Annu Conf Res Med Educ. 81;20:34-9. No original data, No comparison. [pmid: 7347542].
Markert RJ, O'Neill SC, Bhatia SC. Using a quasi-experimental research design to assess knowledge in continuing medical education programs. J Contin Educ Health Prof. 2003;23(3):157-61. Other. [pmid: 14528786].
Massey RU. Problem-based learning: a better way?. Conn Med. 94;58(12):753. No original data, Does not apply. [pmid: 7835049].
Mast L. Application of the problem-based learning model for continuing professional education: a continuing medical education program on managed care issues—Part II. Am J Manag Care. 97;3(1):77-82. <15 trained physicians, No comparison. [pmid: 10169252].
Mathers NJ, Challis MC, Howe AC, et al. Portfolios in continuing medical education—effective and efficient?. Med Educ. 99;33(7):521-30. Not US or Canada. [pmid: 10354337].
Mayooran Z, Rombauts L, Brown TI, et al. Reliability and validity of an objective assessment instrument of laparoscopic skill. Fertil Steril. 2004;82(4):976-8. Not US or Canada. [pmid: 15482787].
Mazze R, Deeb L, Palumbo PJ. Altering physicians' practice patterns—a nationwide educational experiment: evaluation of the Clinical Education Program of the American Diabetes Association. Diabetes Care. 86;9(4):420-5. No comparison. [pmid: 3743317].
McBride P, Underbakke G, Plane MB, et al. Improving prevention systems in primary care practices: the Health Education and Research Trial (HEART) [see comment]. The Journal of family practice. 2000;49(2):115. Other. [pmid: 10718687].
McKenzie A, Ngobeni O, Bonongo F. Is health education effective?. Nurs RSA. 92;7(7):26-7. No original data, No training, No evaluation. [pmid: 1356228].
McNabb WL, Cook S, Fischer B, et al. Dissemination of a continuing education program in diabetes to health care professionals. Diabetes Educ. 94;20(1):35-40. <15 trained physicians. [pmid: 8137702].
Medicare learning online. Optometry 2004;75(10):658–9 Does not apply
Mendoza N, Park CL, Thammasitboon S, et al. Physician education using case-based learning seminar in peditric asthma management. Pediatric research. 2001;49(4):138A. Abstract, <15 trained physicians.
Merckaert I, Libert Y, Delvaux N, et al. Factors that influence physicians' detection of distress in patients with cancer: can a communication skills training program improve physicians' detection?. Cancer. 2005;104(2):411-21. Not US or Canada. [pmid: 15952179].
Modell HI. Use of computer simulations to promote active learning in multiple teaching settings. Physiologist. 85;28(5):445-446. No evaluation, No comparison. [pmid: 3906700].
Modell HI. Use of computer simulations to promote active learning in multiple teaching settings. Physiologist. 85;28(5):445-446. <15 trained physicians. [pmid: 3906700].
Monette J, Tamblyn RM, McLeod PJ, et al. Do medical education and practice characteristics predict inappropriate prescribing of sedative-hypnotics for the elderly?. Acad Med. 94;69(10 Suppl):S10-2. No training, No evaluation, Does not apply. [pmid: 7916812].
Moody L, Waterworth A. A flexible virtual reality tutorial for the training and assessment of arthroscopic skills. Stud Health Technol Inform. 2004;98:244-6. No original data, Not US or Canada. [pmid: 15544280].
Moonie SA, Strunk RC, Crocker S, et al. Community Asthma Program improves appropriate prescribing in moderate to severe asthma. J Asthma. 2005;42(4):281-9. <15 trained physicians. [pmid: 16032937].
Moore M, Van Schaik J, Montgomery CL. Physician retraining, lifelong learning, and the library. Bull Med Libr Assoc. 92;80(4):374-6. No original data, No evaluation. [pmid: 1422510].
Moore R. Continuing education in practice. Practitioner. 91;235(1506):663-5. No evaluation, Does not apply. [pmid: 1796031].
Moorthy K, Jiwanji M, Shah J, et al. Validation of a web-based training tool for lumbar puncture. Stud Health Technol Inform. 2003;94:219-25. <15 trained physicians, Not US or Canada. [pmid: 15455897].
Moral RR, Alamo MM, Jurado MA, et al. Effectiveness of a learner-centred training programme for primary care physicians in using a patient-centred consultation style. Fam Pract. 2001;18(1):60-3. Not US or Canada. [pmid: 11145630].
Moran T. A new approach. Physicians learn to better care for the dying. Tex Med. 99;95(4):42-7. No original data.
Morris PD, Pracy R. Training for ENT problems in general practice. Practitioner. 83;227(1380):995-9. No original data, Does not apply. [pmid: 6889265].
Morrison JC, Sumrall DD, Chevalier SP, et al. The effect of provider education on blood utilization practices. Am J Obstet Gynecol. 93;169(5):1240-5. No comparison. [pmid: 8238191].
Mozes B, Lubin D, Modan B, et al. Evaluation of an intervention aimed at reducing inappropriate use of preoperative blood coagulation tests. Arch Intern Med. 89;149(8):1836-8. Not US or Canada. [pmid: 2764655].
Mozes B, Lubin D, Modan B, et al. Evaluation of an intervention aimed at reducing inappropriate use of preoperative blood coagulation tests. Arch Intern Med. 89;149(8):1836-8. No comparison. [pmid: 2764655].
Murphy AW, Bury G, Dowling J, et al. The teaching of immediate cardiac and trauma care to general practitioners in a skills-based outreach format: an assessment in terms of information gain. Med Educ. 99;33(10):774-6. Not US or Canada. [pmid: 10583772].
Murphy PS. Effect of nutrition education on nutrition counseling practices of family physicians. Acad Med. 89;64(2):98-102. <15 trained physicians, Does not apply. [pmid: 2917044].
Mutch PB, Wenberg BG. Continuing learning needs assessment for Michigan practitioners. J Am Diet Assoc. 86;86(2):247-9. <15 trained physicians, Does not apply. [pmid: 3944396].
Myers P, Mahmood K. Teaching exchange. GP educational needs assessment: The identification of “key facts”. EDUC GEN PRACT. 97;8(3):238-241. Not US or Canada, Does not apply.
Naimark DMJ, Bott MT, Tobe SW, et al. Promotion of urine microalbuminuria screening among primary care physicians: a randomized, controlled, educational intervention trial [abstract]. Journal of the American Society of Nephrology : JASN. 2001;12(Program and Abstracts):231A. Abstract.
Naimark D M J, Bott M T, Tobe S W. Facilitating the adoption of microalbuminuria (mau) screening among type II diabetic patients in primary care: preliminary results of a randomized educational intervention trial [abstract]. Journal of the American Society of Nephrology : JASN. 2002;13(September, Program and AbstractsAlbuminuria; di [Diagnosis]; Kidney; Patient Education; Diabetes Mellitus,Non-Insulin-Dependent): Abstract
Nakada SY, Hedican SP, Bishoff JT, et al. Expert videotape analysis and critiquing benefit laparoscopic skills training of urologists. JSLS. 2004;8(2):183-6. No comparison. [pmid: 15119667].
Nasmith Louise, Steinert Yvonne. The evaluation of a workshop to promote interactive lecturing. Teaching and Learning in Medicine. 2001;13(1):43-48. Other. [pmid: 11273379].
Neff JA, Gaskill SP, Prihoda TJ, et al. Continuing medical education versus clinic-based STD and HIV education interventions for primary care service providers: replication and extension. AIDS Educ Prev. 98;10(5):417-32. <15 trained physicians. [pmid: 9799938].
Neff James, Alan Amodei, Nancy Martinez, et al. HIV/AIDS mental health training for health care providers: An evaluation of three models. American Journal of Orthopsychiatry. 99;69(2):240-246. No original data, <15 trained physicians. [pmid: 10234389].
Neff James, Alan Amodei, Nancy Martinez, et al. HIV/AIDS mental health training for health care providers: An evaluation of three models. American Journal of Orthopsychiatry. 99;69(2):240-246. No comparison. [pmid: 10234389].
Neff James, Alan Gaskill, Sharon P, et al. Preliminary evaluation of continuing medical education-based versus clinic-based sexually transmitted disease education interventions for primary care practitioners. Teaching and Learning in Medicine. 98;10(2):74-82. <15 trained physicians.
Neff-Smith M, Scott G, Spencer EM, et al. Ethics program evaluation: The Virginia hospital ethics fellows example. HEC FORUM. 97;9(4):375-388. No original data, Does not apply, No comparison. [pmid: 10175653].
Nestel D, Kneebone R, Barnet A. Teaching communication skills for handover: perioperative specialist practitioners. Med Educ. 2005;39(11):1157. <15 trained physicians, No comparison. [pmid: 16262830].
Neumayer L, Wako E, Fergestaad J, et al. Impact of journal articles and grand rounds on practice: CT scanning in appendicitis. J Gastrointest Surg. 2002;6(3):338-41. No comparison. [pmid: 12022984].
Newman M, Van den Bossche P, et al. Responses to the pilot systematic review of problem-based learning. Med Educ. 2004;38(9):921-3. No original data, Does not apply. [pmid: 15327670].
Newman P, Peile E. Valuing learners' experience and supporting further growth: Educational models to help experienced adult learners in medicine. Br Med J. 2002;325(7357):200-202. No original data. [pmid: 12142310]. [pmcid: 117453].
Noguchi M, Minami Y, Iijima T, et al. Reproducibility of the diagnosis of small adenocarcinoma of the lung and usefulness of an educational program for the diagnostic criteria. Pathol Int. 2005;55(1):8-13. Not US or Canada. [pmid: 15660697].
Nohr C, Bygholm A. A problem-oriented, project organized, distance learning program in health informatics. Medinfo. 95;8(Pt 2):1274-7. Not US or Canada. [pmid: 8591425].
Norton PG, Ginsburg LS, Dunn E, et al. Educational interventions to improve practice of nonspecialty physicians who are identified in need by peer review. J Contin Educ Health Prof. 2004;24(4):244-52. No original data, Does not apply. [pmid: 15709564].
Nyquist JG, Naylor AJ, Woodward-Lopez G, et al. Use of performance-based assessment to evaluate the impact of a skill-oriented continuing education program. Acad Med. 94;69(10 Suppl):S51-3. <15 trained physicians. [pmid: 7916827].
O'Connor PJ, Desai J, Solberg LI, et al. Randomized trial of quality improvement intervention to improve diabetes care in primary care settings. Diabetes Care. 2005;28(8):1890-7. PI or QI. [pmid: 16043728].
O'Dowd TC, Sprackling PD. Continuing medical education in general practice. BMJ. 89;298(6686):1472. No original data, Not US or Canada. [pmid: 2503078].
Olson L, Anctil C, Fullerton L, et al. Increasing emergency physician recognition of domestic violence. Ann Emerg Med. 96;27(6):741-6. No comparison. [pmid: 8644963].
Omori J, Jacobs J. Multimedia solutions in a problem-based learning curriculum. Hawaii Med J. 2004;63(12):369-70. No original data, Does not apply. [pmid: 15704547].
Osteen AM, Gannon MI. Continuing medical education. JAMA. 88;260(8):1105-9. No original data. [pmid: 3404612].
Oswald NT, Alderson TS. A core curriculum in general practice. Med Educ. 97;31(5):352-3. Not US or Canada. [pmid: 9488856].
Ota D, Loftin B, Saito T, et al. Virtual reality in surgical education. Comput Biol Med. 95;25(2):127-37. No original data. [pmid: 7554831].
Pangaro L. Assessment and outcomes in medical education. Mil Med. 2003;168(9 Suppl):21-6. No original data, No training, No evaluation. [pmid: 14527187].
Panikkar J, Draycott T, Cook J. The evaluation of computer-aided learning in medicine. Postgrad Med J. 98;74(878):706-708. No original data. [pmid: 10320883].
Parslow GR. Computer-based learning. Biochem Educ. 99;27(3):159. No original data.
Parzakonis J. Kidney Learning System: 21st century education. Nephrol News Issues 2004;18(8):49, 51 No original data, Does not apply
Pasternak Nancy, Stern Rau, Lou Ann L, et al. From Chaos to Consistency: The Implementation of Wound Treatment TIERS in home care. Home Health Care Management & Practice. 2003;15(4):314-324. <15 trained physicians, No evaluation, Does not apply.
Patil NG, Saing H, Wong J. Role of OSCE in evaluation of practical skills. Med Teach. 2003;25(3):271-272. <15 trained physicians, Not US or Canada. [pmid: 12881048].
Peters JH, Fried GM, Swanstrom LL, et al. Development and validation of a comprehensive program of education and assessment of the basic fundamentals of laparoscopic surgery. Surgery. 2004;135(1):21-7. <15 trained physicians, No evaluation, Does not apply. [pmid: 14694297].
Physician training spreads people skills. Profiles Healthc Mark 92;(45):27 No original data, No evaluation
Pichert JW. Outcomes of a diabetes professional education seminar. Diabetes Educ. 84;9(4):37-9. No comparison. [pmid: 6559687].
Pinsky L, Robins L, benIzzy J. The story in medicine: skills for MDs. Med Educ. 2004;38(11):1200-1. <15 trained physicians, No comparison. [pmid: 15507037].
Portfolio-based learning in general practice. Report of a working group on higher professional education. Occas Pap R Coll Gen Pract 93;(63):1–22 Not US or Canada, Does not apply
Poses RM, Cebul RD, Wigton RS. You can lead a horse to water—improving physicians' knowledge of probabilities may not affect their decisions. Med Decis Making. 95;15(1):65-75. <15 trained physicians. [pmid: 7898300].
Preparing for the certification and recertification examination. J Am Board Fam Pract 2000;13(2):155–8 No original data, No evaluation
Price DW, Xu S, McClure D. Effect of CME on primary care and OB/GYN treatment of breast masses. J Contin Educ Health Prof. 2005;25(4):240-7. No comparison. [pmid: 16365900].
Purkis IE. Commitment for changes: an instrument for evaluating CME courses. J Med Educ. 82;57(1):61-3. No original data, No comparison. [pmid: 7054512].
Puterman M, Gorodischer R, Leiberman A. Tracheobronchial foreign bodies: the impact of a postgraduate educational program on diagnosis, morbidity, and treatment. Pediatrics. 82;70(1):96-8. Not US or Canada. [pmid: 7088641].
QI project improves patient outcomes. Hosp Peer Rev 2002;27(6):77–8 Abstract, No comparison, PI or QI
Raasch BA, Hays R, Buettner PG. An educational intervention to improve diagnosis and management of suspicious skin lesions. J Contin Educ Health Prof. 2000;20(1):39-51. Not US or Canada. [pmid: 11232071].
Ramamurthi B. Postgraduate course in general practice to improve primary level health care. J Indian Med Assoc. 94;92(8):275-6. No original data, Not US or Canada, Does not apply. [pmid: 7963620].
Randell D. E-learning for continuing education: exploring a new frontier. MLO Med Lab Obs. 2001;33(8):24-8. No original data, No evaluation. [pmid: 11519191].
Rappolt S, Pearce K, McEwen S, et al. Exploring organizational characteristics associated with practice changes following a mentored online educational module. J Contin Educ Health Prof. 2005;25(2):116-24. Does not apply, No comparison. [pmid: 16078810].
Raskova J, Trelstad RL. Replacing lectures with reading, small-group discussion, and computer-assisted learning. Acad Med. 96;71(5):537-8. <15 trained physicians. [pmid: 10676275].
Raub AC, Bowler FL, Escovitz GH. A physician retraining program. Assessment update. JAMA. 82;248(22):2994-8. No comparison. [pmid: 7143672].
Razavi D, Merckaert I, Marchal S, et al. How to optimize physicians' communication skills in cancer care: results of a randomized study assessing the usefulness of posttraining consolidation workshops. J Clin Oncol. 2003;21(16):3141-9. Not US or Canada. [pmid: 12915605].
Razavi Darius, Delvaux Nicole, Farvacques Christine, et al. Brief psychological training for health care professionals dealing with cancer patients: A one-year assessment. General Hospital Psychiatry. 91;13(4):253-260. <15 trained physicians, Not US or Canada.
Razavi Darius, Delvaux Nicole, Farvacques Christine, et al. Immediate effectiveness of brief psychological training for health professionals dealing with terminally ill cancer patients: A controlled study. Social Science & Medicine. 88;27(4):369-375. <15 trained physicians, Not US or Canada.
Reeves S. A joint learning venture between new nurses and junior doctors. Nurs Times. 2000;96(38):39-40. <15 trained physicians, Not US or Canada. [pmid: 11968317].
Regan C, Regan B. Teaching dermatology in general practice: The potential of digital cameras and information technology. Educ Gen Pract. 2000;11(2):193-197. No original data, No evaluation.
Reid DS, Weaver LE, Sargeant JM, et al. Telemedicine in Nova Scotia: report of a pilot study. Telemed J. 98;4(3):249-58. No comparison. [pmid: 9831749].
Reintgen D, Cruse CW, Wells K, et al. The effectiveness of skin cancer screening and continuing medical education programs toward increasing the survival of patients with malignant melanoma. Surg Oncol. 92;1(6):379-84. No training. [pmid: 1341274].
Requirements for infection control education and practice compliance established for physicians and other healthcare workers in Minnesota. Infect Control Hosp Epidemiol 93;14(8):503 No original data, No training
Ricci MA, Caputo MP, Callas PW, et al. The use of telemedicine for delivering continuing medical education in rural communities. Telemed J E Health. 2005;11(2):124-9. No comparison. [pmid: 15857252].
Richmond R, Mendelsohn C, Kehoe L. Family physicians' utilization of a brief smoking cessation program following reinforcement contact after training: a randomized trial. Prev Med. 98;27(1):77-83. Not US or Canada. [pmid: 9465357].
Ricketts C, Price J, Chamberlain S. Interactive online assessment training for busy practitioners. Med Educ. 2005;39(5):525-6. Not US or Canada. [pmid: 15842710].
Riker RR, White BW. The effect of physician education on the rates of donation request and tissue donation. Transplantation. 95;59(6):880-4. <15 trained physicians. [pmid: 7701584].
Robbins JA. Training the primary care internist to provide care in skilled nursing facilities. J Med Educ. 83;58(10):811-3. <15 trained physicians. [pmid: 6620342].
Robinson GE, Stewart DE. A curriculum on physician-patient sexual misconduct and teacher-learner mistreatment. Part 1: Content. Can Med Assoc J. 96;154(5):643-649. No original data, Does not apply. [pmid: 8603320].
Robinson K, Sutton S, von Gunten CF, et al. Assessment of the Education for Physicians on End-of-Life Care (EPEC) Project. J Palliat Med. 2004;7(5):637-45. No comparison. [pmid: 15588354].
Robinson S, Lawson S. Evaluating the impact of Information Skills Training within primary care. Health Info Libr J. 2005;22(1):63-5. Not US or Canada. [pmid: 15810933].
Rodney WM, Ruggiero C. Outcomes following continuing medical education on flexible sigmoidoscopy. Fam Pract. 87;4(4):306-10. No comparison. [pmid: 3692039].
Roe M H. Short course updates physicians' microbiology skills. MLO Med Lab Obs 91;23(5):37–8, 40, 42–6 No evaluation, No comparison
Rogers J, Swee D, Vallario R. Role of case studies in evaluating medical problem solving. J FAM PRACT. 84;18(5):775-778. No original data. [pmid: 6716075].
Rogers J, Swee D, Vallario R. Role of case studies in evaluating medical problem solving. J FAM PRACT. 84;18(5):775-778. Does not apply. [pmid: 6716075].
Rolfsson G, Nordgren A, Bindzau S, et al. Training and assessment of laparoscopic skills using a haptic simulator. Stud Health Technol Inform. 2002;85:409-11. No original data, No training, Not US or Canada. [pmid: 15458123].
Rosch J, Hajek M, Svarz R, et al. Interactive internet broadcasting of a complex educational interventional radiology symposium. J Vasc Interv Radiol. 2003;14(7):833-6. Not US or Canada, No comparison. [pmid: 12847190].
Rosen GM, Harris I, Mahowald MW. Objective structured clinical examinations (OSCE) for sleep. Sleep Med. 2005;6(1):75-80. <15 trained physicians. [pmid: 15680300].
Rucker L, Morrison E. A longitudinal communication skills initiative for an academic health system. Med Educ. 2001;35(11):1087-1088. <15 trained physicians, Not US or Canada, No comparison, Other. [pmid: 11715978].
Rucker L, Morrison E. The “EBM Rx”: an initial experience with an evidence-based learning prescription. Acad Med. 2000;75(5):527-8. <15 trained physicians, Does not apply. [pmid: 10824802].
Rutala PJ, Fulginiti JV, McGeagh AM, et al. Predictive validity of a required multidisciplinary standardized-patient examination. Acad Med. 92;67(10 Suppl):S60-2. <15 trained physicians. [pmid: 1388558].
Rutherford RB. Physicians in the vascular diagnostic laboratory: educational background, prerequisite skills, credentialing, and continuing medical education. Semin Vasc Surg. 94;7(4):217-22. No original data, Does not apply. [pmid: 7881613].
Ryan CA, Finer NN. Changing attitudes and practices regarding local analgesia for newborn circumcision. Pediatrics. 94;94(2 Pt 1):230-3. No comparison. [pmid: 8036079].
Sanci LA, Day NA, Coffey CMM, et al. Simulations in evaluation of training: A medical example using standardised patients. Evaluation and Program Planning. 2002;25(1):35-46. Not US or Canada.
Sanders MR, Tully LA, Turner KM, et al. Training GPs in parent consultation skills. An evaluation of training for the Triple P-Positive Parenting Program. Aust Fam Physician. 2003;32(9):763-8. Not US or Canada. [pmid: 14524224].
Sandlow LJ, Bashook PG, Maxwell JA. Medical care evaluation: an experience in continuing medical education. J Med Educ. 81;56(7):580-6. Does not apply. [pmid: 7241556].
Sandrick K. Effective online CME: it's only a matter of time. Bull Am Coll Surg. 2000;85(4):33-6. No original data.
Sandrick K. Effective online CME: it's only a matter of time. Bull Am Coll Surg. 2000;85(4):33-6. No evaluation.
Sargeant JM, Purdy RA, Allen MJ, et al. Evaluation of a CME problem-based learning internet discussion. Acad Med. 2000;75(10 Suppl):S50-2. No comparison. [pmid: 11031172].
Savatsky PD, Haitz MC, Sterns NS. Patterns of continuing medical education: a generation unit analysis of physicians in three community hospitals. Soc Sci Med [A]. 81;15(5):665-72. No training, Does not apply.
Schatzki SC. The art of learning medicine. AJR Am J Roentgenol. 92;158(3):518. No original data, No evaluation. [pmid: 1738987].
Schectman JM, Schorling JB, Nadkarni MM, et al. Can prescription refill feedback to physicians improve patient adherence?. Am J Med Sci. 2004;327(1):19-24. <15 trained physicians. [pmid: 14722392].
Scherer LA, Chang MC, Meredith JW, et al. Videotape review leads to rapid and sustained learning. Am J Surg. 2003;185(6):516-20. <15 trained physicians. [pmid: 12781877].
Schoenknecht H. How to use humor to help educate physicians in necessary PPS skills. Hosp Top 85;63(6):30–1, 38–9 No original data, Does not apply
Schramm M, Gollnick H. Continuous education for acne—basics, pathogenesis, differential diagnosis, clinic and therapy. Development of an interactive hypermedia application on CD-ROM for computer-based learning and instruction. Dermatology. 98;196(1):100-1. No evaluation.
Schroeder SA, Myers LP, McPhee SJ, et al. The failure of physician education as a cost containment strategy. Report of a prospective controlled trial at a university hospital. JAMA. 84;252(2):225-30. <15 trained physicians. [pmid: 6727021].
Schroeder SA. Strategies for reducing medical costs by changing physicians' behavior: efficacy and impact on quality of care. Int J Technol Assess Health Care. 87;3(1):39-50. No original data. [pmid: 10301603].
Schwid HA, Rooke GA, Ross BK, et al. Use of a computerized advanced cardiac life support simulator improves retention of advanced cardiac life support guidelines better than a textbook review. Critical care medicine. 99;27(4):821-4. <15 trained physicians.
Schwiebert L, Peter Davis, Alan. Impact of Feedback on Teaching by Volunteer Faculty in a Third-Year Family Medicine Clerkship.. 93;(4Clinical Experience/Family Practice (Medicine)/Feedback/Medical Education/Supervision/Volunteer Training/Higher Education/Instructional Improvement/Physicians/Professional Education/Volunteers): <15 trained physicians
Seale J P, Shellenberger S, Boltri J M et al. Effects of screening and brief intervention training on resident and faculty alcohol intervention behaviours: a pre- post-intervention assessment. BMC Fam Pract 2005;646 <15 trained physicians, No comparison
Searle J, Grover S, Santin A, et al. Randomised trial of an integrated educational strategy to reduce investigation rates in young women with dysfunctional uterine bleeding. Aust N Z J Obstet Gynaecol. 2002;42(4):395-400. Not US or Canada. [pmid: 12403289].
Sedlack RE, Petersen BT, Kolars JC. The impact of a hands-on ERCP workshop on clinical practice. Gastrointest Endosc. 2005;61(1):67-71. No comparison. [pmid: 15672058].
See WA, Cooper CS, Fisher RJ. Predictors of laparoscopic complications after formal training in laparoscopic surgery. JAMA. 93;270(22):2689-92. No evaluation. [pmid: 8133586].
Shade SD, Barber GM. When and where you want it: continuing education from a distance. Gerontol Geriatr Educ. 2004;24(4):95-114. No comparison. [pmid: 15142830].
Shain RN, Crouch SH, Weinberg PC. Evaluation of the gynecology teaching associate versus pelvic model approach to teaching pelvic examination. J MED EDUC. 82;57(8):646-647. <15 trained physicians. [pmid: 7097743].
Shakespeare TP, Mukherjee RK, Lu JJ, et al. Evaluation of an audit with feedback continuing medical education program for radiation oncologists. J Cancer Educ. 2005;20(4):216-21. <15 trained physicians, Not US or Canada. [pmid: 16497133].
Shannon S. Facilitating learning groups in CME. Lancet. 2004;363(9411):826. No original data, No training. [pmid: 15016494].
Shannon S. Needs assessment for CME. Lancet. 2003;361(9361):974. No original data, No evaluation. [pmid: 12649005].
Shannon S. Practice-based CME. Lancet. 2003;361(9357):618. No original data, No evaluation. [pmid: 12598179].
Shapiro MJ, Morey JC, Small SD, et al. Simulation based teamwork training for emergency department staff: does it improve clinical team performance when added to an existing didactic teamwork curriculum?. Qual Saf Health Care. 2004;13(6):417-21. <15 trained physicians. [pmid: 15576702]. [pmcid: 1743923].
Shapiro SL, Schwartz GE. Mindfulness in medical education: Fostering the health of physicians and medical practice. Integr Med. 98;1(3):93-94. No original data, <15 trained physicians.
Shifman L, Scott CS, Fawcett N, et al. Utilizing a game for both needs assessment and learning in adolescent sexuality education. Soc Work Groups. 86;9(2):41-56. <15 trained physicians, Does not apply. [pmid: 12284188].
Shunk R. A cardiac physical examination curriculum. Acad Med. 2000;75(5):552-553. <15 trained physicians. [pmid: 10824836].
Simpson DE, Ullian JA. Curriculum design and evaluation in faculty development. Fam Med. 97;29(4):251. No original data, Does not apply. [pmid: 9110160].
Singh NP, Gupta S. Objective structured clinical examination. J Assoc Physicians India. 98;46(7):645-652. No original data, Does not apply. [pmid: 12152853].
Skeff KM, Campbell M, Stratos G. Assessment by attending physicians of a seminar method to improve clinical teaching. J MED EDUC. 84;59(12):944-950. Other. [pmid: 6502663].
Skeff KM, Stratos G, Campbell M, et al. Evaluation of the seminar method to improve clinical teaching. J Gen Intern Med. 86;1(5):315-22. Does not apply, Other. [pmid: 3772621].
Sliwa JA, Makoul G, Betts H. Rehabilitation-specific communication skills training: improving the physician-patient relationship. Am J Phys Med Rehabil. 2002;81(2):126-32. <15 trained physicians, No comparison. [pmid: 11807349].
Sloan RE, McMillan J. Developing mentoring skills for general practitioners using a simulated doctor. Med Educ. 2003;37(11):1044-5. Not US or Canada. [pmid: 14629442].
Sloan RE, McMillan J. Developing mentoring skills for general practitioners using a simulated doctor. Med Educ. 2003;37(11):1044-5. <15 trained physicians. [pmid: 14629442].
Smedley RR. Analyzing the questions of physicians participating in CME programs. Acad Med. 97;72(5):456. No evaluation, Does not apply. [pmid: 10676392].
Smith WD, Berguer R. A simple virtual instrument to monitor surgeons' workload while they perform minimally invasive surgery tasks. Stud Health Technol Inform. 2004;98:363-9. No training, Does not apply. [pmid: 15544306].
Smits PBA, Verbeek JHAM, De Buisonje CD. Problem based learning in continuing medical education: A review of controlled evaluation studies. Br Med J. 2002;324(7330):153-156. No original data, Not US or Canada, Not US or Canada. [pmid: 11799034]. [pmcid: 64518].
Solomon D, Townley P, Dunn K. A distance-learning program for telemedicine presenters. Acad Med. 98;73(5):612-3. No evaluation, Does not apply. [pmid: 9643936].
Sommers LS, Marton KI. The curriculum template: creating continuing medical education curricula for physicians in practice in managed care settings. West J Med. 2000;173(5):337-40. No evaluation, Does not apply. [pmid: 11069875]. [pmcid: 1071160].
Soumerai SB, McLaughlin TJ, Gurwitz JH, et al. Effect of local medical opinion leaders on quality of care for acute myocardial infarction: a randomized controlled trial. JAMA. 98;279(17):1358-63. <15 trained physicians, No comparison, PI or QI. [pmid: 9582043].
Stammer L. Take-out training. E-learning on the menu can improve the bottom line. Healthc Inform 2001;18(8):19–22, 24 No original data, No evaluation
Steginga SK, Pinnock C, Baade PD, et al. An educational workshop on the early detection of prostate cancer—a before-after evaluation. Aust Fam Physician. 2005;34(10):889-91. Not US or Canada, No comparison. [pmid: 16217583].
Stein MR, Parish SJ, Arnsten JH. The OSCE as a formative evaluation tool for substance abuse teaching. Med Educ. 2005;39(5):529-530. <15 trained physicians. [pmid: 15842715].
Steinert Y, Nasmith L, Daigle N. Executive skills for medical faculty: a workshop description and evaluation. Med Teach. 2003;25(6):666-8. No comparison. [pmid: 15369902].
Stevenson GW, Cockshott WP. Continuing medical education and assessment of radiologists. Clin Radiol. 88;39(6):575-7. No original data, No evaluation. [pmid: 3243047].
Straus SE, Ball C, Balcombe N, et al. Teaching evidence-based medicine skills can change practice in a community hospital. J Gen Intern Med. 2005;20(4):340-3. Not US or Canada, No comparison. [pmid: 15857491]. [pmcid: 1490095].
Stross JK, Hiss RG, Watts CM, et al. Continuing education in pulmonary disease for primary-care physicians. Am Rev Respir Dis. 83;127(6):739-46. No comparison. [pmid: 6859657].
Sullivan SD, Lee TA, Blough DK, et al. A multisite randomized trial of the effects of physician education and organizational change in chronic asthma care: cost-effectiveness analysis of the Pediatric Asthma Care Patient Outcomes Research Team II (PAC-PORT II). Arch Pediatr Adolesc Med. 2005;159(5):428-34. No evaluation, Does not apply. [pmid: 15867115].
Sullivan S, Lee T, Blough D, et al. Cost-effectiveness of physician peer leader education and practice-based redesign in managed care: the pediatric asthma care PORT-II trial [Abstract]. The Journal of allergy and clinical immunology. 2004;113(2 Suppl):S339. Abstract.
Swiggart W, Spickard A, Dodd DT. Lessons learned from a CME course in the proper prescribing of controlled drugs. Tenn Med. 2002;95(5):192-3. No evaluation, Does not apply. [pmid: 12012851].
Symposium: Improving clinical performance assessment: a multi-institutional trial of the OSCE (objective structured clinical examination).. Proc Annu Conf Res Med Educ 87;26(-):267–274 No original data, <15 trained physicians
Szonyi G, Millard RJ. Controlled trial evaluation of a General Practitioner education package on incontinence: use of a mailed questionnaire. Br J Urol. 94;73(6):615-20. Not US or Canada. [pmid: 8032826].
Taffinder N, Sutton C, Fishwick R J et al. Validation of virtual reality to teach and assess psychomotor skills in laparoscopic surgery: results from randomised controlled studies using the MIST VR laparoscopic simulator. Stud Health Technol Inform 98;50124–30 <15 trained physicians, Not US or Canada
Teshima DY, Sekiguchi L. Collaborating with a problem-based learning physician curriculum. CLIN LAB SCI. 93;6(5):274-275. <15 trained physicians.
The endocrinologist CME examination: July/August 2005. Endocrinologist 2005;15(4):249–251 No original data, No evaluation, Does not apply
Thomas Craig W, Guy Sybille M, Ogilvie Larry P. An evaluation of a practitioner training program designed to assist families of people with severe psychiatric disorders. Psychiatric Rehabilitation Journal. 99;23(1):34-41. <15 trained physicians, Not US or Canada, No comparison.
Thompson RS, Michnich ME, Friedlander L, et al. Effectiveness of smoking cessation interventions integrated into primary care practice. Med Care. 88;26(1):62-76. Does not apply, Other. [pmid: 3336245].
Tinterow MM. Mandatory CME: an assessment by the Kansas medical profession. J Kans Med Soc. 82;83(6):295-8. No evaluation, Does not apply. [pmid: 7108336].
Townsend RN, Clark R, Ramenofsky ML, et al. ATLS-based videotape trauma resuscitation review: education and outcome. J Trauma. 93;34(1):133-8. <15 trained physicians. [pmid: 7679741].
Training and assessment of competence. Surg Endosc 94;8(6):721–2 No original data, Not US or Canada, Does not apply
Trowbridge Randall, Dugan William, Jay Stephen J, et al. Determining the effectiveness of a clinical-practice intervention in improving the control of pain in outpatients with cancer. Academic Medicine. 97;72(9):798-800. <15 trained physicians. [pmid: 9311323].
Ultrasound Quarterly CME Examination December 2005: Postmark Deadline: November 30, 2006. Ultrasound Q 2005;21(4):309–314 No human data, No original data, Does not apply, No comparison
Ultrasound quarterly CME examination September 2005. Ultrasound Q. 2005;21(3):207–208 No original data, Does not apply
Umble KE, Cervero RM, Yang B, et al. Effects of traditional classroom and distance continuing education: a theory-driven evaluation of a vaccine-preventable diseases course. Am J Public Health. 2000;90(8):1218-24. <15 trained physicians. [pmid: 10937000]. [pmcid: 1446344].
Use physician education to cut prescription drug costs. Capitation Manag Rep 99;6(7):100–3, 97 No comparison, Other
Vacek JL. Practice-based continuing education combined with process improvement methods improves delivery of preventive services to children. Evid-Based Healthc. 2004;8(4):177-179. Other.
Valdiserri RO, Koziol SM, Korth WW, et al. A workshop to improve the teaching skills of physician faculty members. J MED EDUC. 86;61(6):469-471. No comparison. [pmid: 3712412].
van Dulmen AM, Holl RA. Effects of continuing paediatric education in interpersonal communication skills. Eur J Pediatr. 2000;159(7):489-95. Not US or Canada. [pmid: 10923220].
van Olden GD, Meeuwis JD, Bolhuis HW, et al. Clinical impact of advanced trauma life support. Am J Emerg Med. 2004;22(7):522-5. Not US or Canada. [pmid: 15666253].
van Os TW, van den Brink RH, et al. Are effects of depression management training for General Practitioners on patient outcomes mediated by improvements in the process of care?. J Affect Disord. 2004;80(23):173-9. Not US or Canada. [pmid: 15207930].
Vanchieri C. Virtual reality: will practice make perfect?. J Natl Cancer Inst. 99;91(3):207-9. No original data. [pmid: 10037096].
Vaughan W P, Morlock L L, Lenhard R E et al. Demonstration of the effectiveness of the professional education component of a comprehensive cancer control project using serial “patterns of care” (POC) studies. Prog Clin Biol Res 83;130425–32 No original data, PI or QI
Vegni E, Moja EA. Effects of a course on ophthalmologist communication skills: a pilot study. Educ Health (Abingdon). 2004;17(2):163-71. Not US or Canada. [pmid: 15763759].
Verstappen WH, van der Weijden T, et al. Improving test ordering in primary care: the added value of a small-group quality improvement strategy compared with classic feedback only. Ann Fam Med. 2004;2(6):569-75. Not US or Canada. [pmid: 15576543]. [pmcid: 1466745].
Walker DE, Balvert L. A practical program to maintain neonatal resuscitation skills. CMAJ. 94;151(3):299-304. No original data, <15 trained physicians, No evaluation. [pmid: 8039083].
Wallace RK, Ford AB, Wallace RW. Geriatric medical education: a project in faculty development. J Am Geriatr Soc. 83;31(2):106-8. No evaluation, No comparison. [pmid: 6822705].
Walsh PL. An assessment of an operational educational accountability system for continuing education in the health professions. Mobius. 82;2(4):28-38. No original data, No evaluation. [pmid: 10261909].
Ward R, Fidler H, Lockyer J, et al. Physician outcomes and implications for planning an intensive educational experience on attention-deficit hyperactivity disorder. Acad Med. 99;74(10 Suppl):S31-3. No comparison. [pmid: 10536586].
Warren DK, Zack JE, Mayfield JL, et al. The effect of an education program on the incidence of central venous catheter-associated bloodstream infection in a medical ICU. Chest. 2004;126(5):1612-8. No comparison, Other. [pmid: 15539735].
Watts MS. CEHP (continuing education in the health professions)—a new discipline rooted in the practice?. J Contin Educ Health Prof. 89;9(1):61-5. No original data, No evaluation. [pmid: 10294010].
Waxman HS, Kimball HR. Assessing continuing medical education. Am J Med. 99;107(1):1-4. No original data. [pmid: 10403345].
Weir E, Stieb DM, Abelsohn A, et al. Design, delivery and evaluation of an email-based continuing professional development course on outdoor air pollution and health. Med Teach. 2004;26(2):166-73. No comparison. [pmid: 15203526].
Weiss KB, Lozano P, Finkelstein JA, et al. A randomized controlled clinical trial to improve asthma care for children through provider education and health systems change: A description of the pediatric asthma care patient outcome research team (PAC-PORT II) study design. Health Serv Outcomes Res Methodol. 2003;4(4):265-282. No original data, Other.
Weller J, Dowell A, Kljakovic M, et al. Simulation training for medical emergencies in general practice. Med Educ. 2005;39(11):1154. <15 trained physicians, Not US or Canada, No comparison, PI or QI. [pmid: 16262826].
Wells K, Sherbourne C, Duan N, et al. Quality improvement for depression in primary care: do patients with subthreshold depression benefit in the long run?. Am J Psychiatry. 2005;162(6):1149-57. <15 trained physicians, No comparison. [pmid: 15930064].
Wenzel RP. The development of academic programs for quality assessment. Arch Intern Med. 91;151(4):653-4. No original data. [pmid: 2012443].
West RF. A construct validity study of Kolb's learning style types in medical education. J Med Educ. 82;57(10 Pt 1):794-6. <15 trained physicians, Does not apply. [pmid: 7120335].
Westerhoff K, McCarthy WH, Menzies SW. Increase in the sensitivity for melanoma diagnosis by primary care physicians using skin surface microscopy. Br J Dermatol. 2000;143(5):1016-20. Not US or Canada. [pmid: 11069512].
Wexler R. Open learning. Pointing the way. Nurs Times. 91;87(13):32-3. <15 trained physicians, Does not apply. [pmid: 2008364].
White BD, Zaner RM. Clinical ethics training for staff physicians: designing and evaluating a model program. J Clin Ethics. 93;4(3):229-35. No comparison. [pmid: 8219308].
White MI, Grzybowski S, Broudo M. Commitment to change instrument enhances program planning, implementation, and evaluation. J Contin Educ Health Prof. 2004;24(3):153-62. Does not apply, No comparison. [pmid: 15490547].
White MK, Malik T. Teaching clinician-patient communication in the treatment of breast diseases. J Womens Health. 99;8(1):39-44. <15 trained physicians. [pmid: 10094079].
Whitman N, Magill MK. Is attending a teaching skills workshop worth your time?. Fam Med. 98;30(4):255-6. No evaluation, No comparison. [pmid: 9568493].
Whittle SR, Murdoch-Eaton DG. Development of lifelong learning and self-evaluation skills through special study modules. Med Educ. 2001;35(11):1073-4. <15 trained physicians, Not US or Canada. [pmid: 11715958].
Wilkes M, Bligh J. Evaluating educational interventions. BMJ. 99;318(7193):1269-72. No original data. [pmid: 10231263].
Williams BC, Woolliscroft JO, Heindel JE. A managed care curriculum implemented across four academic departments using mandated evaluation instruments. Acad Med. 99;74(5):604-605. <15 trained physicians, No evaluation. [pmid: 10676230].
Williams MQ, Olson S. Teaching critical thinking skills through visual formats. CLIN LAB SCI. 92;5(6):360-365. No original data, Does not apply.
Winston I, Szarek JL. Problem-based learning using a human patient simulator. Med Educ. 2005;39(5):526-527. <15 trained physicians. [pmid: 15842711].
Wirtschafter DD, Sumners J, Jackson JR, et al. Continuing medical education using clinical algorithms. A controlled-trial assessment of effect on neonatal care. Am J Dis Child. 86;140(8):791-7. <15 trained physicians. [pmid: 3728407].
Wolters R, Wensing M, Klomp M, et al. Effects of distance learning on clinical management of LUTS in primary care: a randomised trial. Patient Educ Couns. 2005;59(2):212-8. Not US or Canada. [pmid: 16257627].
Worley P, March R, Worley E. Scanning the horizon of training for general practice. Med Teach. 2000;22(5):452-455. No original data.
Wright FC, Law CH, Last LD, et al. A blended knowledge translation initiative to improve colorectal cancer staging. BMC Health Serv Res. 2006;6(1):4. No evaluation, Other. [pmid: 16412251]. [pmcid: 1395360].
Yanoff JM, Leedy RF, Seitchik M, et al. A model for training family practice preceptors. J Med Educ. 82;57(10 Pt 1):809. No evaluation, Does not apply. [pmid: 7120344].
Yens DP, Peters JT, Stimmel B, et al. Evaluation of an innovative self-instructional program in the surgical subspecialties. Proc Annu Conf Res Med Educ. 84;23(-):105-110. <15 trained physicians.
Yentis SM. The use of patients for learning and maintaining practical skills. J R Soc Med. 2005;98(7):299-302. No training, No evaluation, Does not apply. [pmid: 15994588]. [pmcid: 1168911].
Young JM, Ward J. Can distance learning improve smoking cessation advice in family practice? A randomized trial. J Contin Educ Health Prof. 2002;22(2):84-93. Not US or Canada. [pmid: 12099124].
Youngblood P, Stringer J, Moreno E. Development and formative evaluation of a longitudinal web-based nutrition curriculum. Acad Med. 2000;75(5):540-1. <15 trained physicians, Does not apply. [pmid: 10824820].
Zak R. Continuing medical education. Interactive technology enhances instruction for both teacher and learner. Healthc Inform. 2004;21(7):40. No original data, No training, No evaluation, Does not apply. [pmid: 15311548].
Zaza C, Sellick S. Assessing the impact of evidence-based continuing education on nonpharmacologic management of cancer pain. J Cancer Educ. 99;14(3):164-7. No comparison, Other. [pmid: 10512334].
Zebrack JR, Anderson RC, Torre D. Enhancing EBM skills using goal setting and peer teaching. Med Educ. 2005;39(5):513-514. <15 trained physicians. [pmid: 15842694].
Zhang H, Payandeh S, Dill J et al. Acquiring laparoscopic manipulative skills: a virtual tissue dissection training module. Stud Health Technol Inform 2004;98419–21 No original data, No original data
Zwar NA, Gordon JJ, Sanson-Fisher RW. Evaluation of an educational program in rational prescribing for GP trainees. Aust Fam Physician. 95;24(5):833-8. <15 trained physicians, Not US or Canada. [pmid: 7794146].
Zwar N, Henderson J, Britt H, et al. Influencing antibiotic prescribing by prescriber feedback and management guidelines: a 5-year follow-up. Fam Pract. 2002;19(1):12-7. Not US or Canada. [pmid: 11818344].