# Appendix C: Detailed Electronic Database Search Strategies

## Detailed Electronic Database Search Strategies for Primary Literature on Effectiveness of Continuing Medical Education

Terms | Returns
MEDLINE Strategy
((((“Education, Continuing”[MeSH] OR “Education, Medical”[MeSH]) NOT (“Education, Dental, Continuing”[MeSH] OR “Education, Nursing, Continuing”[MeSH] OR “Education, Pharmacy, Continuing”[MeSH] OR “Education, Medical, Undergraduate”[MeSH] OR “Internship and Residency”[MeSH]) OR (“continuing medical education”[tiab] OR CME[tiab]) OR ((educat*[tiab] OR train*[tiab] OR curriculum[tiab]) AND (physician* OR Family practi*[tiab] OR Family medicine[tiab] OR General practi*[tiab] OR internist*[tiab] OR Surgeon*[tiab] OR Primary care[tiab] OR Allergist*[tiab] OR Immunologist*[tiab] OR Anesthesiology*[tiab] OR Dematolog*[tiab] OR Emergency medicine[tiab] OR Forensic medicine[tiab] OR Hospitalist*[tiab] OR Internal medicine[tiab] OR Cardiolog*[tiab] OR Endocrinolog*[tiab] OR Gastroenterolog*[tiab] OR Hematolog*[tiab] OR Oncolog*[tiab] OR Nephrolog*[tiab] OR Pulmonolog*[tiab] OR Rhematolog*[tiab] OR Neurolog*[tiab] OR Patholog*[tiab] OR Pediatric*[tiab] OR Psychiatr*[tiab] OR Radiolog*[tiab] OR Obstetrician*[tiab] OR Gynecolog*[tiab]))) AND (behav*[tiab] OR practice*[tiab] OR evaluat*[tiab] OR assess*[tiab] OR learn*[tiab] OR skill*[tiab] OR outcome*[tiab] OR effective*[tiab] OR analy*[tiab] OR intervention*[tiab] OR examin*[tiab])) NOT (dental*[tiab] OR dentist*[tiab] OR student*[tiab] OR undergraduate*[tiab] OR athlet*[tiab])) AND English[lang] NOT (animal[mh] NOT human [mh]) AND (1981:2006[dp]) NOT (review[pt] OR meta-analysis[pt] OR editorial[pt] OR comment[pt] OR letter[pt]) | 38174
EMBASE Strategy
((((‘medical education’:de) NOT (‘clinical supervision’:de OR ‘dental education’:de OR ‘medical school’:de OR ‘physician assistant education’:de OR ‘residency education’:de)) OR (‘continuing medical education’:ti,ab) OR cme:ti,ab OR ((educat*:ti,ab OR train*:ti,ab OR curriculum:ti,ab) AND (physician*:ti,ab OR (family:ti,ab AND practi*:ti,ab) OR (family:ti,ab AND medicine:ti,ab) OR (general:ti,ab AND practi*:ti,ab) OR internist*:ti,ab OR surgeon*:ti,ab OR (primary:ti,ab AND care:ti,ab) OR allergist*:ti,ab OR immunologist*:ti,ab OR anesthesiolog*:ti,ab OR dermatolog*:ti,ab OR (emergency:ti,ab AND medicine:ti,ab) OR (forensic:ti,ab AND medicine:ti,ab) OR hospitalist*:ti,ab OR (internal:ti,ab AND medicine:ti,ab) OR cardiolog*:ti,ab OR endocrinolog*:ti,ab OR gastroenterolog*:ti,ab OR hematolog*:ti,ab OR oncolog*:ti,ab OR nephrolog*:ti,ab OR pulmonolog*:ti,ab OR rhemaolog*:ti,ab OR neurolog*:ti,ab OR patholog*:ti,ab OR pediatric*:ti,ab OR psychiatr*:ti,ab OR radiolog*:ti,ab OR obstetric*:ti,ab OR gynecolog*:ti,ab))) AND (behav*:ti,ab OR practice*:ti,ab OR evaluat*:ti,ab OR assess*:ti,ab OR learn*:ti,ab OR skill*:ti,ab OR outcome*:ti,ab OR effective*:ti,ab OR analy*:ti,ab OR intervention*:ti,ab OR examin*:ti,ab)) NOT (dental*:ti,ab OR dentist*:ti,ab OR student*:ti,ab OR undergraduate*:ti,ab OR athlet*:ti,ab) AND [English]/lim NOT ([animals]/lim NOT [humans]/lim) AND [1981-2006]/py NOT ([conference paper]/lim OR [editorial]/lim OR [erratum]/lim OR [letter]/lim OR [note]/lim OR [review]/lim) | 44765
The Cochrane Central Register of Controlled Trials (CENTRAL)
(((((Continuing medical education):ti,ab,kw OR (CME):ti,ab,kw) OR ((educat* OR train* OR curriculum):ti,ab,kw NEAR (physician* OR Family practi* OR Family medicine OR General practice OR internist* OR Surgeon* OR Primary care OR Allergist OR Immunologist OR Anesthesiolog* OR Dematolog* OR Emergency medicine OR Forensic medicine OR Hospitalist* OR Internal medicine OR Cardiolog* OR Endocrinolog* OR Gastroenterolog* OR Hematolog* OR Oncolog* OR Nephrolog* OR Pulmon* OR Rhematolog* OR Neurolog* OR Patholog* OR Pediatric* OR Psychiatr* OR Radiolog* OR Obstetrician* OR Gynecolog*):ti,ab,kw)) AND (behav* OR evaluat* OR assess* OR learn* OR skill* OR outcome* OR effective* OR analy* OR examin* OR intervention*):ti,ab,kw) NOT (dental* OR dentist* OR student* OR undergraduate* OR athlet*):ti,ab,kw), LIMIT DATE RANGE from 1981 to 2006 | 1843
PsycINFO
(((((MM “Continuing Education” OR MM “Inservice Training” OR MM “Medical Education”) NOT (MM “Medical Internship” OR MM “Medical Residency”)) OR (TI “continuing medical education” OR TI “CME” OR AB “continuing medical education” OR AB “CME”) OR ((AB educat* OR AB train* OR AB curriculum) AND (AB physician* OR AB Family practi* OR AB Family medicine OR AB General practi* OR AB internist* OR AB Surgeon* OR AB Primary care OR AB Allergist OR AB Immunologist OR AB Anesthesiology* OR AB Dematolog* OR AB Emergency medicine OR AB Forensic medicine OR AB Hospitalist* OR AB Internal medicine OR AB Cardiolog* OR AB Endocrinolog* OR AB Gastroenterolog* OR AB Hematolog* OR AB Oncolog* OR AB Nephrolog* OR AB Pulmonolog* OR AB Rhematolog* OR AB Neurology* OR AB Patholog* OR AB Pediatric* OR AB Psychiatr* OR AB Radiolog* OR AB Obstetrician* OR AB Gynecolog*))) AND (AB behav* OR AB evaluat* OR AB assess* OR AB learn* OR AB skill* OR AB outcome* OR AB effective* OR AB analy* OR AB examin*)) NOT (AB dental* OR AB dentist* OR AB student* OR AB undergraduate* OR AB athlet*)) AND (LA English NOT (PO animal NOT PO human) AND DT 198101–200602 NOT (PZ abstract collection OR PZ bibliography OR PZ column/opinion OR PZ comment/reply OR PZ editorial OR PZ erratum/correction OR PZ letter OR PZ obituary OR PZ all chapters OR PZ original chapter OR PZ reprinted chapter OR PZ reprinted journal article OR PZ publication information OR PZ review)) [FURTHER LIMITED TO ALL JOURNALS] | 8738
ERIC
(((((MM “Continuing Education” OR MM “Inservice Training” OR MM “Medical Education”) NOT (MM “Medical Internship” OR MM “Medical Residency”)) OR (TI “continuing medical education” OR TI “CME” OR AB “continuing medical education” OR AB “CME”) OR ((AB educat* OR AB train* OR AB curriculum) AND (AB physician* OR AB Family practi* OR AB Family medicine OR AB General practi* OR AB internist* OR AB Surgeon* OR AB Primary care OR AB Allergist OR AB Immunologist OR AB Anesthesiology* OR AB Dematolog* OR AB Emergency medicine OR AB Forensic medicine OR AB Hospitalist* OR AB Internal medicine OR AB Cardiolog* OR AB Endocrinolog* OR AB Gastroenterolog* OR AB Hematolog* OR AB Oncolog* OR AB Nephrolog* OR AB Pulmonolog* OR AB Rhematolog* OR AB Neurology* OR AB Patholog* OR AB Pediatric* OR AB Psychiatr* OR AB Radiolog* OR AB Obstetrician* OR AB Gynecolog*))) AND (AB behav* OR AB evaluat* OR AB assess* OR AB learn* OR AB skill* OR AB outcome* OR AB effective* OR AB analy* OR AB examin*)) NOT (EL “Early Childhood Education” OR EL “Preschool Education” OR EL “Elementary Secondary Education” OR EL “Elementary Education” OR EL “Primary Education” OR EL “Adult Basic Education” OR EL “Intermediate Grades” OR EL “Secondary Education” OR EL “Middle Schools” OR EL “Junior High Schools” OR EL “High Schools” OR EL “High School Equivalency Programs” OR EL “Postsecondary Education” OR EL “Two Year Colleges”)) AND (LA English AND DT 198101–200602 AND PT Journal Article NOT (PO animal NOT PO human)) | 2002

## Detailed Electronic Database Search Strategies for Systematic Reviews on Effectiveness of Simulation Techniques in Medical Education

Terms | Returns
MEDLINE Strategy
(((“Education, Medical”[MeSH] OR ((educat*[tiab] OR train*[tiab] OR curriculum[tiab]) AND (medical*[tiab] OR resident*[tiab] OR residenc*[tiab] OR physician*[tiab] OR surgery[tiab] OR surgeon*[tiab] OR surgical*[tiab])))) AND (“Patient Simulation”[MeSH] OR Computer Simulation[MeSH] OR Manikins[MeSH] OR simulation*[tiab] OR simulat*[tiab] OR mannikin[tiab] OR manikin[tiab] OR mannequin*[tiab] OR virtual[tiab] OR computer-based[tiab] OR “standardized patient”[tiab] OR “standardized patients”[tiab])) AND ((review[tiab] or review[pt] or meta-analys*[tiab] or meta-analysis[pt]) AND English[lang] NOT (letter[pt] or comment[pt] or editorial[pt])) NOT (animal[mh] NOT human [mh]) AND (“1990/01/01”[pdat] : “2006/02/28”[pdat]) | 466
EMBASE Strategy
((((‘medical education’/exp) NOT (‘clinical supervision’/exp OR ‘dental education’/exp OR ‘physician assistant education’/exp)) OR ((educat*:ti,ab OR train*:ti,ab OR curriculum:ti,ab) AND (medical*:ti,ab OR resident*:ti,ab OR residenc*:ti,ab OR surgery:ti,ab OR surgical*:ti,ab OR physician*:ti,ab OR (family:ti,ab AND practi*:ti,ab) OR (family:ti,ab AND medicine:ti,ab) OR (general:ti,ab AND practi*:ti,ab) OR internist*:ti,ab OR surgeon*:ti,ab OR (primary:ti,ab AND care:ti,ab) OR allergist*:ti,ab OR immunologist*:ti,ab OR anesthe*:ti,ab OR anaesthe*:ti,ab OR dermatolog*:ti,ab OR (emergency:ti,ab AND medicine:ti,ab) OR (forensic:ti,ab AND medicine:ti,ab) OR hospitalist*:ti,ab OR (internal:ti,ab AND medicine:ti,ab) OR cardiolog*:ti,ab OR endocrinolog*:ti,ab OR gastroenterolog*:ti,ab OR hematolog*:ti,ab OR oncolog*:ti,ab OR nephrolog*:ti,ab OR pulmonolog*:ti,ab OR rhemaolog*:ti,ab OR neurolog*:ti,ab OR patholog*:ti,ab OR pediatric*:ti,ab OR psychiatr*:ti,ab OR radiolog*:ti,ab OR obstetric*:ti,ab OR gynecolog*:ti,ab))) AND (‘skill’/exp OR ‘simulator’/exp OR ‘simulation’/exp OR ‘virtual reality’/exp OR simulation*:ti,ab OR simulat*:ti,ab OR mannikin:ti,ab OR manikin:ti,ab OR mannequin*:ti,ab OR virtual:ti,ab OR computer-based:ti,ab OR (standardized:ti,ab AND patient*:ti,ab))) AND (review:ti,ab,it OR ‘meta analysis’:ti,ab,it OR metaanalysis:ti,ab,it) NOT (letter:it OR comment:it OR editorial:it OR ‘conference paper’:it OR erratum:it OR note:it) AND [English]/lim NOT ([animals]/lim NOT [humans]/lim) AND [1981-2006]/py | 2359
The Cochrane Database of Systematic Reviews and the Cochrane Database of Abstracts of Reviews of Effects (DARE)
(Simulation or simulator or manikin or mannikin or mannequin or virtual or computer-based or “standardized patient” or “standardized patients”) AND education in title, abstract or keywords restricted to reviews | 3
PsycINFO
((((MM “Medical Education”) OR ((AB educat* OR AB train* OR AB curriculum) AND (AB physician* OR AB Family practi* OR AB “Family medicine” OR AB General practi* OR AB internist* OR AB Surgeon* OR AB “Primary care” OR AB Allergist OR AB Immunologist OR AB Anesthesiolog* OR AB Dematolog* OR AB “Emergency medicine” OR AB “Forensic medicine” OR AB Hospitalist* OR AB “Internal medicine” OR AB Cardiolog* OR AB Endocrinolog* OR AB Gastroenterolog* OR AB Hematolog* OR AB Oncolog* OR AB Nephrolog* OR AB Pulmonolog* OR AB Rhematolog* OR AB Neurolog* OR AB Patholog* OR AB Pediatric* OR AB Psychiatr* OR AB Radiolog* OR AB Obstetrician* OR AB Gynecolog* OR AB Medical OR AB resident* OR AB residenc* OR AB surgery OR AB surgical*))) AND (MM “Simulation” or MM “Virtual Reality” or MM “Human Machine Systems” or AB “simulation” or AB simulat* or AB manikin or AB mannikin or AB mannequin or AB virtual or AB “standardized patient” or AB “standardized patients”)) AND (LA English NOT (PO animal NOT PO human) AND DT 199001–200602 NOT (PZ abstract collection OR PZ bibliography OR PZ column/opinion OR PZ comment/reply OR PZ editorial OR PZ erratum/correction OR PZ letter OR PZ obituary OR PZ all chapters OR PZ original chapter OR PZ reprinted chapter OR PZ reprinted journal article OR PZ publication information))) AND (PZ review OR AB review OR AB meta-analys*) | 34
ERIC
((((DE “Medical Education”) OR ((AB educat* OR AB train* OR AB curriculum) AND (AB physician* OR AB “Family practice” OR AB “Family practitioner” OR AB “Family medicine” OR AB “General practice” OR AB “General practitioner” OR AB internist* OR AB Surgeon* OR AB “Primary care” OR AB Allergist OR AB Immunologist OR AB Anesthesiolog* OR AB Dematolog* OR AB “Emergency medicine” OR AB “Forensic medicine” OR AB Hospitalist* OR AB “Internal medicine” OR AB Cardiolog* OR AB Endocrinolog* OR AB Gastroenterolog* OR AB Hematolog* OR AB Oncolog* OR AB Nephrolog* OR AB Pulmonolog* OR AB Rhematolog* OR AB Neurolog* OR AB Patholog* OR AB Pediatric* OR AB Psychiatr* OR AB Radiolog* OR AB Obstetrician* OR AB Gynecolog* OR AB Medical OR AB resident* OR AB residenc* OR AB surgery OR AB surgical*))) AND (DE “Simulation” or DE “Virtual Reality” or AB “simulation” or AB simulat* or AB manikin or AB mannikin or AB mannequin or AB virtual or AB “standardized patient” or AB “standardized patients”)) AND (LA English AND DT 198101–200602 AND PT Journal Article NOT (PO animal NOT PO human))) AND (AB review* OR AB meta-analys* OR TI review* OR TI meta-analys*) | 14