# Appendix B: Hand Searched Journals

## All Journals Hand Searched

February 2005–February 2006

Academic Medicine

The American Journal of Managed Care

American Journal of Preventive Medicine

Annals of Internal Medicine

Chest

Canadian Medical Association Journal

The Journal of Continuing Education in the Health Professions

Journal of General Internal Medicine

Journal of Medical Education

The Journal of the American Medical Association

Medical Care

Medical Education