# Appendix A: Technical Experts and Peer Reviewers

## Technical Experts and Peer Reviewers

- Alejandro Aparicio, MD, FACP
- Director, Division of Continuing Physician Professional Development,
- American Medical Association
- Vice President for Medical Affairs,
- Ballard Health Care
- Chicago, IL

- Michael H. Baumann, MD, MS
- Professor of Medicine
- Division of Pulmonary and Critical Care Medicine
- University of Mississippi Medical Center
- Jackson, MS

- Frank C. Berry
- Continuing Medical Education Director
- MedChi, The Maryland State Medical Society
- Baltimore, Maryland

- Nancy L. Davis, PhD
- Director, Division of Continuing Medical Education
- American Academy of Family Physicians
- Leawood, KS

- Robert Galbraith, MD, MBA, FACP
- Executive Director of the Center for Innovation,
- National Board of Medical Examiners
- Philadelphia, PA

- James C. Hebert, MD, FACS
- Chair, Committee on Continuous Professional Development
- Associate Dean for Graduate Medical Education
- Vice Chair for Education, Department of Surgery
- American College of Surgeons
- University of Vermont, College of Medicine
- Burlington, Vermont

- S. Barry Issenberg, MD, FACP
- Associate Professor of Medicine
- Assistant Dean, Research in Medical Education
- Director, Division of Research and Technology
- Assistant Director, Center for Research in Medical Education
- University of Miami Miller School of Medicine
- Miami, Florida

- Jocelyn Lockyer, PhD
- Director, Continuing Medical Education and Professional Development
- Associate Professor, Department of Community Health Services
- University of Calgary
- Calgary, Alberta Canada

- Mary Martin Lowe, MA
- Director, Education and Improvement
- Accreditation Council for Continuing Medical Education
- Chicago, Illinois

- Don Moore, Jr., PhD
- Professor of Medical Education and Administration
- Director, Division of Continuing Medical Education
- Vanderbilt University School of Medicine
- Nashville, TN

- LTC Lisa K. Moores, MC, USA
- Former Chair, Council of NetWorks
- Vice Chair, Continuing Education Committee
- Member, Task Force on Performance Measurement
- Walter Reed Army Medical Center
- Gaithersburg, MD

- Charles Willis, MBA
- Former Director, Department of AMA PRA Standards & Policy Liaison Activities
- American Medical Association
- Administrative Director, Division of Continuing Physician Professional Development
- Chicago, IL