# Appendixes

Appendix A: Technical Experts and Peer Reviewers

Appendix B: Hand Searched Journals

Appendix C: Detailed Electronic Database Search Strategies

Appendix D: List of Excluded Articles

Appendix E: Data Abstraction Forms

Appendix F: Evidence Tables