# Acronyms and Abbreviations

ACCP | American College of Chest Physicians
AHRQ | Agency for Healthcare Research and Quality
APC | Activated Protein C
ASD | Acute Stress Disorder
bFGF | basic Fibroblast Growth Factor
CFPA | Coupled Plasma Filtration Absorption
CHF | Chronic Heart Failure
CONSORT | Consolidated Standards of Reporting Trials
CPB | Cardio Pulmonary Bypass Surgery
Da | Daltons
DVT | Deep Vein Thrombosis
EPH Tool | Effective Public Health Practice Project Quality Assessment Tool for Quantitative Studies
GAGs | Glycosaminoglycans
ICU | Intensive Care Unit
LA_50_ | Lethal Level of Accumulation at 50 Percent Effect Level
LMWH | Low Molecular Weight Heparin
LV | Left Ventricular
MU-EPC | McMaster University Evidence-based Practice Center
PE | Pulmonary Embolism
PTSD | Post-Traumatic Stress Disorder
RCT | Randomized Controlled Trial
RVT | Renal Vein Thrombosis
SRS | Systematic Review Software
SVT | Superficial Vein Thrombosis
TBSA | Total Body Surface Area
TEP | Technical Expert Panel
TFPI | Tissue Factor Pathway Inhibitor
TOO | Task Order Officer
U.S. | United States
UFH | Unfractionated Heparin
VEGF | Vascular Endothelial Growth Factor
VTE | Venous Thromboembolism