# References

1 Casu B. Structure of heparin and heparin fragments. Ann N Y Acad Sci. 1989;556:1-17. [pmid: 2660680].
2 Hirsh J. Heparin. N Engl J Med. May 30. 1991;324(22):1565-74. [pmid: 2027360].
3 Weitz JI. Low-molecular-weight heparins. N Engl J Med. Sep 4. 1997;337(10):688-98. [pmid: 9278467].
4 de Kort M, Buijsman RC, van Boeckel CA. Synthetic heparin derivatives as new anticoagulant drugs. Drug Discov Today. Jun 1. 2005;10(11):769-79. [pmid: 15922935].
5 Tyrell DJ, Horne AP, Preuss JMH, et al. Heparin in inflammation: potential therapeutic applications beyond anticoagulation. Adv Pharmacol. 1999;46:151-208. [pmid: 10332503].
6 Lee AY, Rickles FR, Julian JA, et al. Randomized comparison of low molecular weight heparin and coumarin derivatives on the survival of patients with cancer and venous thromboembolism. J Clin Oncol. Apr 1. 2005;23(10):2123-9. [pmid: 15699480].
7 Elsayed E, Becker RC. The impact of heparin compounds on cellular inflammatory responses: a construct for future investigation and pharmaceutical development. J Thromb Thrombolysis. Feb. 2003;15(1):11-8. [pmid: 14574071].
8 Peplow PV. Glycosaminoglycan: a candidate to stimulate the repair of chronic wounds. Thromb Haemost. Jul. 2005;94(1):4-16. [pmid: 16113778].
9 Wang J, Zheng H, Qiu X, et al. Modulation of the intestinal response to ionizing radiation by anticoagulant and non-anticoagulant heparins. Thromb Haemost. Nov. 2005;94(5):1054-9. [pmid: 16366003].
10 Murray DWG. Best CH. JAMA. 1938;110:118-27.
11 Jorpes JE. Heparin in the treatment of thrombosis. New York: Oxford University Press; 1946.
12 Wilson JE III, Bynum LJ, Parkey RW. Heparin therapy in venous thromboembolism. Am J Med. Apr. 1981;70(4):808-16. [pmid: 7211918].
13 Crafoord C. Heparin and post-operative thrombosis. Acta chirurgica Scandinavica. 1939;82:487-98.
14 Freedman MD. Pharmacodynamics, clinical indications, and adverse effects of heparin. J Clin Pharmacol. Jul. 1992;32(7):584-96. [pmid: 1322434].
15 Baglin T, Barrowcliffe TW, Cohen A, et al. Guidelines on the use and monitoring of heparin. Br J Haematol. Apr. 2006;133(1):19-34. [pmid: 16512825].
16 Clagett GP, Reisch JS. Prevention of venous thromboembolism in general surgical patients. Results of meta-analysis. Ann Surg. Aug. 1988;208(2):227-40. [pmid: 2456748]. [pmcid: 1493611].
17 Nurmohamed MT, Rosendaal FR, Buller HR, et al. Low-molecular-weight heparin versus standard heparin in general and orthopaedic surgery: a meta-analysis. Lancet. Jul 18. 1992;340(8812):152-6. [pmid: 1352573].
18 Koch A, Bouges S, Ziegler S, et al. Low molecular weight heparin and unfractionated heparin in thrombosis prophylaxis after major surgical intervention: update of previous meta-analyses. Br J Surg. Jun. 1997;84(6):750-9. [pmid: 9189079].
19 Handoll HH, Farrar MJ, McBirnie J, et al. Heparin, low molecular weight heparin and physical methods for preventing deep vein thrombosis and pulmonary embolism following surgery for hip fractures. Cochrane Database Syst Rev 2002;(4):CD000305
20 Mismetti P, Laporte-Simitsidis S, Tardy B, et al. Prevention of venous thromboembolism in internal medicine with unfractionated or low-molecular-weight heparins: a meta-analysis of randomised clinical trials. Thromb Haemost. Jan. 2000;83(1):14-9. [pmid: 10669147].
21 Leizorovicz A, Cohen AT, Turpie AG, et al. Randomized, placebo-controlled trial of dalteparin for the prevention of venous thromboembolism in acutely ill medical patients. Circulation. Aug 17. 2004;110(7):874-9. [pmid: 15289368].
22 Upchurch GR Jr, Demling RH, Davies J, et al. Efficacy of subcutaneous heparin in prevention of venous thromboembolic events in trauma patients. Am Surg. Sep. 1995;61(9):749-55. [pmid: 7661468].
23 Geerts WH, Jay RM, Code KI, et al. A comparison of low-dose heparin with low-molecular-weight heparin as prophylaxis against venous thromboembolism after major trauma. N Engl J Med. Sep 5. 1996;335(10):701-7. [pmid: 8703169].
24 Lassen MR, Borris LC, Nakov RL. Use of the low-molecular-weight heparin reviparin to prevent deep-vein thrombosis after leg injury requiring immobilization. N Engl J Med. Sep 5. 2002;347(10):726-30. [pmid: 12213943].
25 Barritt DW, Jordan SC. Anticoagulant drugs in the treatment of pulmonary embolism. A controlled trial. Lancet. Jun 18. 1960;1:1309-12. [pmid: 13797091].
26 Douketis JD, Ginsberg JS, Burrows RF, et al. The effects of long-term heparin therapy during pregnancy on bone density. A prospective matched cohort study. Thromb Haemost. Feb. 1996;75(2):254-7. [pmid: 8815571].
27 Gould MK, Dembitzer AD, Doyle RL, et al. Low-molecular-weight heparins compared with unfractionated heparin for treatment of acute deep venous thrombosis. A meta-analysis of randomized, controlled trials. Ann Intern Med. May 18. 1999;130(10):800-9. [pmid: 10366369].
28 Bousser MG, Chiras J, Bories J, et al. Cerebral venous thrombosis—a review of 38 cases. Stroke. Mar. 1985;16(2):199-213. [pmid: 3975957].
29 Einhaupl KM, Villringer A, Meister W, et al. Heparin treatment in sinus venous thrombosis. Lancet. Sep 7. 1991;338(8767):597-600. [pmid: 1679154].
30 Abdu RA, Zakhour BJ, Dallis DJ. Mesenteric venous thrombosis-1911 to 1984. Surgery. Apr. 1987;101(4):383-8. [pmid: 3563882].
31 Wichers IM, Di Nisio M, Buller HR, et al. Treatment of superficial vein thrombosis to prevent deep vein thrombosis and pulmonary embolism: a systematic review. Haematologica. May. 2005;90(5):672-7. [pmid: 15921382].
32 Collins R, MacMahon S, Flather M, et al. Clinical effects of anticoagulant therapy in suspected acute myocardial infarction: systematic overview of randomised trials. Br Med J. Sep 14. 1996;313(7058):652-9. [pmid: 8811758]. [pmcid: 2351968].
33 Hirsh J, Raschke R. Heparin and low-molecular-weight heparin: the Seventh ACCP Conference on Antithrombotic and Thrombolytic Therapy. Chest. Sep. 2004;126(3 Suppl):188S-203S. [pmid: 15383472].
34 Oler A, Whooley MA, Oler J, et al. Adding heparin to aspirin reduces the incidence of myocardial infarction and death in patients with unstable angina. A meta-analysis. JAMA. Sep 11. 1996;276(10):811-5. [pmid: 8769591].
35 Magee KD, Sevcik W, Moher D, et al. Low molecular weight heparins versus unfractionated heparin for acute coronary syndromes. Cochrane Database Syst Rev 2003;(1):CD002132
36 Thompson JF, Mullee MA, Bell PR, et al. Intraoperative heparinisation, blood loss and myocardial infarction during aortic aneurysm surgery: a Joint Vascular Research Group study. Eur J Vasc Endovasc Surg. Jul. 1996;12(1):86-90. [pmid: 8696904].
37 Merrer J, De Jonghe B, Golliot F, et al. Complications of femoral and subclavian venous catheterization in critically ill patients: a randomized controlled trial. JAMA. Aug 8. 2001;286(6):700-7. [pmid: 11495620].
38 Lim W, Cook DJ, Crowther MA. Safety and efficacy of low molecular weight heparins for hemodialysis in patients with end-stage renal failure: a meta-analysis of randomized trials. J Am Soc Nephrol. Dec. 2004;15(12):3192-206. [pmid: 15579523].
39 Beijering RJ, ten Cate H, Nurmohamed MT, et al. Anticoagulants and extracorporeal circuits. Semin Thromb Hemost. 1997;23(2):225-33. [pmid: 9200350].
40 Pruitt BAJr, Goodwin CW, Mason AJr. Epidemiological, demographic, and outcome characteristics of burn injury. In: Herndon DN, ed. Total burn care, 2nd edition London: W.B. Saunders; 2002.
41 Brigham PA, McLoughlin E. Burn incidence and medical care use in the United States: estimates, trends, and data sources. J Burn Care Rehabil. Mar. 1996;17(2):95-107. [pmid: 8675512].
42 Williams WG. Pathophysiology of burn wound. In: Herndon DN, ed. Total burn care, 2nd edition London: W.B. Saunders; 2002.
43 Fitzpatrick JC, Cioffi WG, Jr. Diagnosis and Treatment of inhalation injury. In: Herndon DN, ed. Total burn care, 2nd edition London: W.B. Saunders; 2002.
44 Heimbach DM, Mann R, Engrav L. Evaluation of the burn wound management decisions. In: Herndon DN, ed. Total burn care, 2nd edition London: W.B. Saunders; 2002.
45 Pruitt B Jr, Mason A, Goodwin C. Epidemiology of burn injury and demography of burn care facilities. Problems in General Surgery. 1990;7(2):235-51.
46 Monafo WW. Then and now: 50 years of burn treatment. Burn. 1992;18(Suppl. 2):S7-S10.
47 Monafo WW, Bessey PQ. Benefits and limitations of burn wound excision. World J Surg. Jan. 1992;16(1):37-42. [pmid: 1290264].
48 Ryan CM, Schoenfeld DA, Thorpe WP, et al. Objective estimates of the probability of death from burn injuries. N Engl J Med. 1998;338(6):362-5. [pmid: 9449729].
49 Warden G, Warner PM. Functional sequelae and disability assesment. In: Herndon DN, ed. Total burn care, 2nd edition London: W.B. Saunders; 2006.
50 Thomas CR, Meyer WJ, III, Blakeney PE. Psychiatric disorders associated with burn injury. In: Herndon DN, ed. Total burn care, 2nd edition London: W.B. Saunders; 2006.
51 Patterson DR, Everett JJ, Bombardier CH, et al. Psychological effects of severe burn injuries. Psychol Bull. Mar. 1993;113(2):362-78. [pmid: 8451340].
52 Rizzone LP, Stoddard FJ, Murphy JM, et al. Posttraumatic stress disorder in mothers of children and adolescents with burns. J Burn Care Rehabil. Mar. 1994;15(2):158-63. [pmid: 8195257].
53 Blakeney PE, Fauerbach JA, Meyer WJ, III, et al. Psychosocial recovery and reintegration of patients with burn injuries. In: Herndon DN, ed. Total burn care, 2nd edition London: W.B. Saunders; 2006.
54 Tarnowski KJ, Ranaske LK, Gavaghan-Jones MP, et al. Psychological sequalae of pediatric burn injuries: a review. Clin Psychol Rev. 1991;11:371-98.
55 Zapata-Sirvent RL, Hansbrough JF, Greenleaf GE, et al. Reduction of bacterial translocation and intestinal structural alterations by heparin in a murine burn injury model. J Trauma-Inj Infect Crit Care. 1994;36(1):1-6.
56 Horner BM, Myers SR. Don't miss HIT (heparin induced thrombocytopenia). Burns. Feb. 2004;30(1):88-90. [pmid: 14693093].
57 Wahl WL, Brandt M-M, Ahrns K, et al. The utility of D-dimer levels in screening for thromboembolic complications in burn patients. J Burn Care Rehabil. 2002;23(6):439-43. [pmid: 12432321].
58 Wahl WL, Brandt MM, Ahrns KS, et al. Venous thrombosis incidence in burn patients: preliminary results of a prospective study. J Burn Care Rehabil. 2002;23(2):97-102. [pmid: 11882798].
59 Desai MH, Mlcak R, Richardson J, et al. Reduction in mortality in pediatric patients with inhalation injury with aerosolized heparin/acetylcystine therapy. J Burn Care Rehabil. 1998;19(3):210-2. [pmid: 9622463].
60 Mims JA, Sarji KE, Kleinfelder JS, et al. Heparin-induced platelet-aggregation in burn patients. Thromb Res. 1977;10(2):291-9. [pmid: 850911].
61 Curreri PW, Wilterdink ME, Baxter CR. Characterization of elevated fibrin split products following thermal injury. Ann Surg. Feb. 1975;181(2):157-60. [pmid: 1111446]. [pmcid: 1343745].
62 Loebl EC, Marvin JA, Curreri W, et al. Erythrocyte survival following thermal injury. J Surg Res. Feb. 1974;16(2):96-101. [pmid: 4818344].
63 Wahl WL, Brandt M-M. Potential risk factors for deep venous thrombosis in burn patients. J Burn Care Rehabil. 2001;22(2):128-31. [pmid: 11302600].
64 Waymack JP, Tweddell JS, Warden GD. Renal vein thrombosis in burned children. J Burn Care Rehabil. 1988;9(5):472-3. [pmid: 3192603].
65 Kuz'muk VV, Repin AV, Tarasov MS. Several indices of the blood coagulation system in burns. Lab Delo. 1971;10:615-6. [pmid: 4114124].
66 Iashvili BP, Baluda VP, Lukhoyanova TI, et al. The effects of administration of drugs influencing haemostasis during treatment of patients with burns. Burns Incl Therm Inj. Feb. 1986;12(3):184-7. [pmid: 2423204].
67 Khadzhiiski O, Diakov R, Petrova M. Contractubex used in the treatment of postburn scars and keloids. Khirurgiia (Sofiia). 2001;57(34):44-8. [pmid: 12024674].
68 Mariano F, Tetta C, Stella M, et al. Regional citrate anticoagulation in critically ill patients treated with plasma filtration and adsorption. Blood Purification. 2004;22(3):313-9. [pmid: 15256798].
69 Acharya BS. Treatment of superficial burns in the accident department. Practitioner. Sep. 1973;211(263):371-2. [pmid: 4271355].
70 Peng Y, Yuan Z, Li H. Removal of inflammatory cytokines and endotoxin by veno-venous continuous renal replacement therapy for burned patients with sepsis. Burns. 2005;31(5):623-8. [pmid: 15975721].
71 Ono I, Ohura T, Hammamoto J. Clinical observations of coadministration of antithrombin III preparation with heparin in burned patients. J Burn Care Rehabil. 1984;5(1):25-9.
72 Venakatachalapathy TS, Mohan Kumar S, Saliba MJ. A comparative study of burns treated with topical heparin and without heparin. 2005.
73 Srivastava JL, Ramesh Babu K, Tewari VK, et al. Heparin in the management of extensive burns. Indian J Plast Surg. 1988;21(1):7-12.
74 Zayas GJ, Bonilla AM, Saliba MJ. Heparin reduced mortality and sepsis in severely burned children. 2006.
75 Reyes AE, Astiazaran JA, Chavez CC, et al. Burns treated with and without heparin: controlled use in a thermal disaster. Ann Burns Fire Disasters. 2001;14(4):183-91.
76 Walenga JM, Frenkel EP, Bick RL. Heparin-induced thrombocytopenia, paradoxical thromboembolism, and other adverse effects of heparin-type therapy. Hematol Oncol Clin North Am. Feb. 2003;17(1):259-ix. [pmid: 12627671].
77 Hawkins D, Evans J. Minimising the risk of heparin-induced osteoporosis during pregnancy. Expert Opin Drug Saf. May. 2005;4(3):583-90. [pmid: 15934862].
78 Melzack R. The short-form McGill Pain Questionnaire. Pain. Aug. 1987;30(2):191-7. [pmid: 3670870].
79 Deans KJ, Haley M, Natanson C, et al. Novel therapies for sepsis: a review. J Trauma. Apr. 2005;58(4):867-74. [pmid: 15824673].
80 Herndon DN, Barrow RE, Rutan RL, et al. A comparison of conservative versus early excision. Therapies in severely burned patients. Ann Surg. May. 1989;209(5):547-52. [pmid: 2650643]. [pmcid: 1494069].
81 Gray DT, Pine RW, Harnar TJ, et al. Early surgical excision versus conventional therapy in patients with 20 to 40 percent burns. A comparative study. Am J Surg. Jul. 1982;144(1):76-80. [pmid: 7046487].
82 Davidson BL, Geerts WH, Lensing AW. Low-dose heparin for severe sepsis. N Engl J Med. Sep 26. 2002;347(13):1036-7. [pmid: 12324565].
83 Kent DM, Fendrick AM, Langa KM. New and dis-improved: on the evaluation and use of less effective, less expensive medical interventions. Med Decis Making. May. 2004;24(3):281-6. [pmid: 15155017].
84 Ryan CM, Schoenfeld DA, Thorpe WP, et al. Objective estimates of the probability of death from burn injuries. N Engl J Med. Feb 5. 1998;338(6):362-6. [pmid: 9449729].
85 Tarnowski KJ, Rasnake LK, Drabman RS. Behavioural assessment and treatment of pediatric burn injuries: a review. Behav Ther. 1987;18:417-41.
86 Stoddard FJ, Sheridan RL, Saxe GN, et al. Treatment of pain in acutely burned children. J Burn Care Rehabil. Mar. 2002;23(2):135-56. [pmid: 11882804].
87 Thurber CA, Martin-Herz SP, Patterson DR. Psychological principles of burn wound pain in children. I: theoretical framework. J Burn Care Rehabil. Jul. 2000;21(4):376-87. [pmid: 10935822].
88 Martin-Herz SP, Thurber CA, Patterson DR. Psychological principles of burn wound pain in children. II: Treatment applications. J Burn Care Rehabil. Sep. 2000;21(5):458-72. [pmid: 11020055].
89 Stoddard FJ, Saxe G, Ronfeldt H, et al. Acute stress symptoms in young children with burns. J Am Acad Child Adolesc Psychiatry. Jan. 2006;45(1):87-93. [pmid: 16327585].
90 Robert R, Blakeney PE, Villarreal C, et al. Imipramine treatment in pediatric burn patients with symptoms of acute stress disorder: a pilot study. J Am Acad Child Adolesc Psychiatry. Jul. 1999;38(7):873-82. [pmid: 10405506].
91 Drake JE, Stoddard FJ Jr, Murphy JM, et al. Trauma severity influences acute stress in young burned children. J Burn Care Res. Mar. 2006;27(2):174-82. [pmid: 16566561].
92 Saxe GN, Stoddard F, Hall E, et al. Pathways to PTSD, part I: children with burns. Am J Psychiatry. Jul. 2005;162(7):1299-304. [pmid: 15994712].
93 Paradiso C. Hemofiltration: an alternative to dialysis. Heart Lung. May. 1989;18(3):282-90. [pmid: 2722539].
94 Altman DG, Schulz KF, Moher D, et al. The revised CONSORT statement for reporting randomized trials: explanation and elaboration. Ann Intern Med. Apr 17. 2001;134(8):663-94. [pmid: 11304107].
95 Dans AL, Dans LF, Guyatt GH, et al. Users' guides to the medical literature: XIV. How to decide on the applicability of clinical trial results to your patient. Evidence-Based Medicine Working Group. JAMA. Feb 18. 1998;279(7):545-9. [pmid: 9480367].
96 Baryza MJ, Baryza GA. The Vancouver Scar Scale: an administration tool and its interrater reliability. J Burn Care Rehabil. Sep. 1995;16(5):535-8. [pmid: 8537427].
97 Dantzer E, Queruel P, Salinier L, et al. Dermal regeneration template for deep hand burns: clinical utility for both early grafting and reconstructive surgery. Br J Plast Surg. Dec. 2003;56(8):764-74. [pmid: 14615251].
98 Daltroy LH, Liang MH, Phillips CB, et al. American Burn Association/Shriners Hospitals for Children burn outcomes questionnaire: construction and psychometric properties. J Burn Care Rehabil. Jan. 2000;21(1 Pt 1):29-39. [pmid: 10661536].
99 Kazis LE, Liang MH, Lee A, et al. The development, validation, and testing of a health outcomes burn questionnaire for infants and children 5 years of age and younger: American Burn Association/Shriners Hospitals for Children. J Burn Care Rehabil. May. 2002;23(3):196-207. [pmid: 12032370].
100 Munster AM, Horowitz GL, Tudahl LA. The abbreviated Burn-Specific Health Scale. J Trauma. Apr. 1987;27(4):425-8. [pmid: 3573091].
101 Saxe G, Chawla N, Stoddard F, et al. Child Stress Disorders Checklist: a measure of ASD and PTSD in children. J Am Acad Child Adolesc Psychiatry. Aug. 2003;42(8):972-8. [pmid: 12874500].
102 Baur KM, Hardy PE, Van Dorsten B. Posttraumatic stress disorder in burn populations: a critical review of the literature. J Burn Care Rehabil. May. 1998;19(3):230-40. [pmid: 9622468].