# Executive Summary

## Introduction

The non-anticoagulant effects of heparin and related molecules form the rationale for using heparin in the treatment of burns. Recent basic science literature suggests heparin may have a biological role as an anti-inflammatory, anti-angiogenic, and anti-metastatic agent. More importantly, at the molecular level, heparin may be an enhancer of wound healing, which has enormous implications for the treatment of acute and chronic burn wounds. In the immediate post-burn setting, the benefits of heparin's postulated anti-inflammatory and enhanced wound healing properties could include reduced pain (hence better compliance with dressing changes or physiotherapy), infection, length of hospital stay, and mortality. The long-term benefits of this expanded range of uses of heparin in the treatment of burn injury could include improved function and range of motion of extremities, reduced scarring, and possibly decreased psychiatric or psychosocial sequalae.

An expanded range of treatment options for burn injury is desirable given that 1.25 million people on average are treated annually for burns in the United States. Four percent of these people will require hospitalization and specialized burn care. Approximately 25 percent of people with severe burn injuries (greater than 75 percent of total body surface area) will die even after receiving advanced treatment at specialized burn centers. The morbidity from burn injury is also great. Short term morbidity includes the pain of the injury and subsequent surgical therapy. Over the medium to long term, the psychosocial impact of disfigurement, and the potential for post-traumatic stress disorder, can have lasting ill effects on patients and patients' loved ones.

This report was commissioned to address two key questions about the uses of heparin in the treatment of burn injury:

1 What is the evidence for the benefits and harms of heparin use in thermal injury care?
  a Does the method of application make a difference?
  b Do the outcomes vary by the type or degree of burn?
  c How do the outcomes of burn treatment with heparin compare to current treatment without heparin?
2 What are the contraindications of heparin use in burns?

Addressing these questions will serve to identify the strength of the evidence for using heparin to treat burns and gaps in existing research. As well, answering these questions will facilitate the establishment of future research priorities.

## Methods

A comprehensive search of the literature was conducted to capture all relevant, published studies on the topic of heparin and burns. The following electronic databases were searched:

1 MEDLINE® (1966-current);
2 EMBASE (1980-current);
3 CINAHL (Cumulative Index to Nursing & Allied Health) (1982-current);
4 The Cochrane Central Database of Controlled Trials (1995-current);
5 Web of Science (1976-current); and
6 BIOSIS (1976-current).

In addition, literature in the U.S. and European Patent Offices was searched for relevant studies, members of the TEP and the partner organization were asked to supplement the database search with additional references of published and unpublished studies, and the reference lists of articles that passed full text screening were also searched for relevant studies.

Inclusion/exclusion criteria. A list of inclusion/exclusion criteria was developed to screen studies for this evidence report. The criteria were:

Language. There was no language restriction. Studies published in any language could be included in the report.

Study Design. Studies required a comparison group for inclusion. Case series, case reports, editorials, letters, comments, opinions, abstracts, animal experiments, and conference proceedings were excluded from the report.

Population. Human patients of any age, with burns of all types, grades, and total body surface area (TBSA) involvement, could be included in the report.

Outcomes. Studies with the following outcomes could be included:

- Need for surgical procedure (e.g., grafting, debridement, fasciotomy, quality of graft take [percentage], re-grafting, reconstructive surgery);
- Pain;
- Mortality (prior to, or after, discharge from hospital);
- Length of stay in hospital;
- Scarring (size, hypertrophic scarring);
- Decrease in range of motion, function, or activities of daily living;
- Respiratory measures (e.g., length of intubation);
- Thrombosis and emboli;
- Complications (e.g., bleeding, infection);
- Rehabilitation;
- Quality of Life; and
- Psychiatric adjustment (e.g., post-traumatic stress disorder [PTSD], anxiety, depression).

## Data Collection and Reliability of Study Selection

A team of raters was trained to apply the inclusion/exclusion criteria. Standardized forms were developed for this purpose, as well as for data abstraction. The forms were created and stored online using Systematic Review Software (SRS; TrialStat Corp., Ottawa, Ontario).

For title and abstract screening, two independent raters evaluated the citations that were obtained from the literature search. Articles that met the inclusion/exclusion criteria, or for which there was insufficient information to determine if they met the criteria, were retrieved for further assessment. Once retrieved, the entire text of the article was screened to determine if the inclusion/exclusion criteria were satisfied. At this stage, an article could be excluded from further review only if both raters agreed that it did not satisfy the inclusion/exclusion criteria. In cases of disagreement, the raters met to arrive at a consensus. Articles that successfully passed the full text screening phase went on to full data abstraction.

Quality assessment of abstracted studies. The quality of the studies that passed full text screening was assessed using the Effective Public Health Practice Project, Quality Assessment Tool for Quantitative Studies. Two raters, either a local expert or a MU-EPC staff member, conducted the quality assessment for each article. Differences were resolved by consensus.

## Results

The search strategy yielded 471 citations. Of these, 132 proceeded to full text screening and 19 (representing 18 unique studies) advanced to the data abstraction phase. The countries of origin for the 19 abstracted articles were: U.S. (n = 8), Soviet Union (n = 2), India (n = 2), Bulgaria, Italy, United Kingdom, China, Japan, El Salvador, and Mexico (n = 1 each for the last seven countries). Sample sizes ranged from 6 to 327, with a mean of 62. The samples were composed of patients who presented to hospital burn units or emergency rooms with burn injuries. Nine articles contained reports of the breakdown of patients by sex; males formed the majority in eight articles. Mean ages were reported in seven articles. In the five articles with adult populations, the lowest mean age was 30 years and the highest mean age was 57 years. In the two articles with pediatric populations, the lowest mean age was 3.2 years and the highest mean age was 8 years. The etiology of burn, reported in eight articles, included flame, inhalation injury, and ‘thermal’ injury. One article contained patients with any burn etiology. Eight articles also contained information about the degree of burn.

### Key Question 1. What is the evidence for the benefits and harms of heparin use in thermal injury care?

Does the method of application make a difference? There were insufficient data in the abstracted articles to answer this question. None of the articles contained comparisons of systemic heparin (intravenous or subcutaneous) or topical heparin in the treatment of burn injury.

Do the outcomes vary by the type or degree of burn? There were insufficient data to answer this question. None of the abstracted articles contained analyses of heparin stratified by the type or degree of burn. In fact, the abstracted articles were characterized by vague reports of the etiology, type, or degree of burn in the samples.

How do the outcomes of burn treatment with heparin compare to current treatment without heparin? Multiple roles for heparin in the treatment of burns were examined in the abstracted articles. These roles included wound healing and pain control, as well as the treatment of sepsis, inhalation injury, and venous thrombosis. However, there was insufficient data available to answer the key question. This was because only 10 of the abstracted studies contained clinical outcomes (the remaining nine were primarily laboratory studies that did not contain clinical outcomes), publication dates spanned three decades, and the research was conducted in a multitude of different countries with varying standards of burn care. Thus, the available evidence was severely limited with respect to its relevance and applicability to current treatment standards in many locales. Another issue concerned the many methodological deficiencies of the abstracted articles. These deficiencies hampered the ability to judge the reported effectiveness of heparin in burn treatment. Deficiencies included:

1 Poorly defined burn etiology and degree;
2 Unclear method of treatment allocation;
3 Unclear duration of treatment, especially the point at which heparin was first administered;
4 Outcome variables that were vague and unlikely to be reproducible; and
5 Use of descriptive statistics only (no comparative statistics).

### Key Question 2. What are the contraindications of heparin use in burns?

Four of the abstracted articles listed contraindications to the use of heparin in burn patients. These contraindications were bleeding diathesis, bleeding history, active bleeding or associated trauma with potential bleeding, active intestinal ulcer, thrombocytopenia, liver disease, renal disorders, or allergy to heparin. The authors of two of these articles wrote that these contraindications served as study exclusion criteria, while the authors of the other two articles wrote that none of the patients in their studies had any of these contraindications.

### Quality Assessment of Abstracted Articles

The overall quality of the 19 abstracted articles was poor. Selection bias could not be ruled out for many of the articles because the authors did not report on patient recruitment or participation rate. Similarly, non-reporting was a problem in the area of study design: only one article contained a specific description of how treatments (exposures) were allocated amongst study participants. None of the authors discussed blinding. For confounding, half of the articles had reports of potential differences between treatment groups on important confounders, and no attempts were made in any of the articles to control for possible confounding. Statistical methods (when reported) were simple between-group comparisons. Many authors did not mention the type of statistical test used in the comparisons, nor did they provide p-values. In some instances, no statistical comparisons were performed.

## Limitations

There was insufficient evidence from the abstracted articles to answer the first key question. Although the authors of some of the articles claimed that heparin had benefits for outcomes such as pain, cosmesis, and wound healing, this evidence was of limited clinical utility because of the poor quality of the research. Some articles were beset by vague descriptions of study participants, burn etiology, or treatment regimen. Articles without these deficiencies had problems regarding the use of invalid comparison groups or invalid outcomes. The major issue with comparison groups was the use of controls that were treated at earlier points in time, or at different hospitals, than people who received heparin. In both cases, different treatment protocols could have confounded the observed associations between treatment and outcome. Regarding outcomes, an important one in burn injury - pain - was never examined using a validated measurement instrument such as the McGill Pain Scale. Instead, surrogate measures (e.g., amount of pain medication used during hospitalization) were employed to estimate the degree of pain relief in heparin versus control patients. For cosmesis, pictures were used to demonstrate the benefit associated with heparin use, but there were no apparent standards employed to govern the timing, photographic angles, or interpretation of the pictures. Confounding was not controlled in any of the abstracted articles. Furthermore, confounding could not be ruled out for the randomized controlled trials because none of the authors mentioned how subjects were randomized to treatment.

The evidence from the abstracted articles was not applicable to all clinical contexts. This was because the treatment protocols employed in the articles did not demonstrate a common standard of burn care. Reasons for the absence of commonality were temporal, i.e., the research was done before current standards were adopted, or contextual, i.e., the research was country-specific and standards of burn care differ between countries.

## Conclusions

There is no strong evidence in the 19 abstracted articles to indicate that the non-anticoagulant properties of heparin improve clinical outcomes in the treatment of burn injury. The lack of evidence is largely a function of the poor quality of the articles. However, some data in these poor quality articles suggest the possibility of clinical benefit, so the authors of this evidence report recommend future research into the use of heparin to treat burn injury.

## Future Research

Two sets of studies are recommended for future research. The first set would investigate heparin's wound healing properties. One randomized trial would involve the application of topical heparin to donor areas (commonly the upper leg) after skin graft in adult and adolescent populations. Comparisons would be done with controls who receive standard treatment for the donor areas. Outcomes would include the healing time of the donor area, pain, itching, and scarring. In addition, research of this type may have an impact on factors that contribute to the psychiatric morbidity associated with burn injuries and their care, especially morbidity in relation to skin grafting and the pain and discomfort of donor sites. Psychiatric outcomes that would be evaluated include Acute Stress Disorder (ASD) and PTSD. If heparin is shown to promote wound healing of the donor area, then the next study would involve people (adults, adolescents, and children) with bilateral extremity burns to the arms, hands, or legs. People would serve as their own controls: topical heparin plus standard treatment would be applied to one extremity and standard treatment alone would be applied to the other extremity. Outcomes would be the same as in the first study, plus there would be an evaluation of quality of life.

The second study would consist of a randomized controlled trial to investigate the use of aerosolized heparin in the treatment of burn-related inhalation injury. The study would be conducted in both the adult and pediatric populations. The objectives regarding treatment of inhalation injury would be to decrease the reintubation rate, and length of stay in the intensive care unit (ICU). Other objectives would be to reduce the incidence of acute respiratory distress or atelectasis. As with the first set of studies, there should be an investigation of psychiatric outcomes. In addition to ASD, PTSD, and quality of life, the ICU context of the inhalation injury trial requires the inclusion of two additional psychiatric outcomes, i.e., ICU psychosis and delirium.

All these studies would have to be organized at multiple sites to ensure that adequate numbers of patients are recruited to achieve high statistical power (≥ 80%). A general list of potential outcomes includes:

- Mortality;
- Incidence of medical procedures following initial treatment with heparin or standard therapy (e.g., reintubation, excision, grafting);
- Functional performance (e.g., thumb opposition score, fingertip-to-palm distance, prehensile score);
- Pain (measured using the McGill Pain Scale);
- Scarring (measured using the Vancouver Scar Scale);
- Itching (measured via the amount of anti-pruritic medications used [e.g., Benadryl®])
- Quality of Life (measured using the Health Outcomes Burn Questionnaire for children and the Burn-Specific Health Scale for adults); and
- Post-traumatic Stress Disorder (measured using the Child Stress Disorders Checklist for children and a selected range of measurement methodologies for adults).