# Acknowledgments

The researchers at the Evidence-based Practice Center would like to acknowledge the following people for their contributions.

Our thanks go out to the members of the technical expert panel for their invaluable advice and consultations in defining the scope of this review: Dr. B. Atiyeh, Dr. David Herndon, Dr. Leo Klein, Dr. Ján Koller, Dr. Gurvaneet Randhawa, Dr. Michael Saliba, Dr. Glenn Warden, and Dr. Steven Wolf.

We would also like to thank Elena Prigoda for running the searches and Josh Fagbemi for managing the references in Refman and SRS.

We are grateful to Jessica Cheeseman, Dorothy Kendry, and Sarah Smith for their assistance in article retrieval.

Thank you to Jesmin Antony, Fulvia Baldassarre, Agata Dzierzgowska, Simo Goshev, Dr. Janusz Kaczorowski, Ritz Kakuma, Inna Lantsouzovski, Dr. Carolina Ruiz, Dr. Lina Santaguida, Arnd Sett, Elizabeth Simmons, and Dr. Lufang Yang for the many hours of screening, data abstraction, and translation of the non-English articles.

Finally, we would like to say a big thank you to Mary Gauld for managing all aspects of the project as well as Maureen Rice, Roxanne Cheeseman, and Cecile Royer for their invaluable input in the editing and formatting of this report.