# Discussion and Future Research

## Overall Summary of Evidence from the Abstracted Studies

There is no strong evidence in the 19 abstracted articles to indicate that the non-anticoagulant properties of heparin improve clinical outcomes in the treatment of burn injury. The lack of evidence is largely a function of the poor quality of the articles. Many of the articles did not contain clinical outcomes and in those that did, these outcomes were not always well defined. Additionally, the quality of several of the studies was low, with high potential for selection bias, inadequate control of confounding, and no mention of the use of blinding during exposure and outcome assessment.

Pain and cosmesis—outcomes of high clinical interest in burn injury—were often improperly measured in the studies in which they were considered. Instead of using a valid and reliable tool such as the McGill Pain Scale^78^ to measure pain, the authors of two studies^72,^ ^75^ measured pain by looking at the degree of use of pain medication. The problem with this approach is that physician judgment may be substituted for patient judgment when it comes to the use (and degree of use) of pain medication. Since the studies were not blinded, there may also have been an a priori belief that heparin-treated patients would not need pain medication, and this might have influenced whether they actually got the medication. Thus, one cannot be sure that use of pain medication adequately measures patient pain. In another study, the authors asserted that heparin provided more pain relief than conventional treatment because of the anecdotal observation that “The noisy din and distressing emotional ambience of the Emergency Room or the Burn Ward was soon replaced by a quiet calm [once patients received heparin].”^74^ Anecdotal observations such as this do not constitute evidence of a treatment effect.

For cosmesis, two studies relied on patient photographs to show a benefit for heparin-treated patients.^72,^ ^75^ However, in one of these studies, the authors did not show photographs of all of the patients.^72^ In both studies, the number of days after injury on which the published photographs were taken varied, as did the parts of the patients' bodies that were photographed. To be acceptable for demonstrating treatment efficacy in a research study, photographic evidence must be standardized, e.g., all patients should be photographed, each patient's photographs should be taken at the same points in time during follow-up, and the same parts of each patient's body should be photographed (from the same angles). As well, a protocol must be developed to ensure that photographic evidence is interpreted in a standardized manner, much like is done in studies where imaging tests are used to assess treatment efficacy.

## Contextual Issues Regarding the Evidence from Abstracted Studies

The time and location of many of the abstracted studies deserve particular note. The studies spanned more than three decades, beginning in 1971. During this period, burn care underwent a major transformation, the hallmark of which was markedly improved survival.^45,^ ^46^ At one American burn center, burn survivability—measured by the LA_50_— improved from 43 percent (young adults) and 23 percent (older adults) in 1940 to 60.8 percent (young) and 39.2 percent (older) in the late 1970s and early 1980s. Even more dramatic was the improvement in pediatric burn survival at this center, which was 51 percent in 1940 and 93 percent in 1986.^45^ Further transformation occurred with the development of networks of specialized burn treatment centers in some countries. These centers are capable of handling local injuries and the treatment of people with serious burn injuries who are transferred from distant locales. Burn care was aided by advancements in multiple areas of medicine, including critical care medicine, wound infection control, antimicrobial therapy, surgical therapy, specialized burn care research, and coordinated methods of burn patient transfer. Early excision therapy became possible within the context of these advances and it has become a standard component of surgical care for full thickness burn injuries in some countries.^46^

In the articles abstracted for this evidence report, the treatment protocols employed by some of the researchers did not match these aforementioned approaches to burn care. Thus, even if the evidence for using heparin in the treatment of burn injury was stronger, it would be difficult to apply this evidence to all clinical contexts. For example, Venkatachalapathy et al.,^72^ who conducted their work in Pondicherry, India, reported a lag of 1 to 8 hours between the time of burn injury and the initiation of treatment. The lags were caused by either medico-legal matters at referral hospitals or referral distances of up to 150 kilometers. In contrast, the regionalization of specialized burn care in the United States has enabled the development of burn patient transfer protocols, including use of air ambulances and accompanying medical support services, that minimize transfer delays due to bureaucracy or distance.^45^ In the studies by Zayas et al.,^74^ Reyes et al.,^75^ and Srivastava et al.,^73^ burn injuries included full thickness burns, but none of the authors reported whether early excision or grafting was used in the treatment of these injuries. Early excision and grafting of full thickness burn injuries is currently common practice in some countries.^47^

Some of the differences between study protocols and standards of burn care were temporal in nature. For example, Waymack et al.'s chart review was published in 1988 and included charts from 20 years earlier.^64^ Therefore, this study was not likely to contain treatment protocols that reflect the current state of the art. Additionally, given the publication dates of the articles, the types of heparin that were studied are probably not used today. Low molecular weight heparins (LMWHs) have largely replaced unfractionated heparin (UFH) for some clinical indications because LMWHs possess superior pharmacodynamic and pharmacokinetic properties, as well as fewer side effects.^3^ Recently, a synthetic LWMH was developed and is now available for clinical use.^4^

The other reason for the difference between study protocols and standards of burn care related to the originating country or region of the study. Of the 10 abstracted articles that pertained directly to the use of heparin in the treatment of burns (Table 7 - Group A), two were from India and two were from Latin America. In both locations, the research focus was on heparin's wound healing effects in relation to cosmesis, function, and mortality. In the United States, the research focus was on heparin's anticoagulant effects in relation to venous thrombosis (deep vein thrombosis,^57,^ ^58,^ ^63^ renal vein thrombosis^64^, as well as on heparin's anti-inflammatory effects in relation to inhalation injury.^59^

### Heparin and Sepsis

In the abstracted studies, claims regarding heparin use in burn care included beneficial effects with respect to the treatment of sepsis in pediatric^73,^ ^74^ and adult burn patients.^73^ Sepsis is associated with a heightened inflammatory response and adverse activation of the coagulation cascade.^79^ Eradication of sources of infection is one goal of sepsis treatment.

Early excision and grafting therapy has been utilized to ameliorate factors that can contribute to the development of sepsis. This therapy has led to improved survivability for pediatric burn patients.^80^ Wound sepsis and contamination both decreased in one study comparing early excision and grafting to conventional wound debridement therapy.^81^ Yet early excision and grafting may not be the current standard of burn care in some countries. New therapeutic efforts for treatment of sepsis have been targeted at the dysregulation of the coagulation system during sepsis. Heparin's place within this new area of research is both complicated and controversial. In phase III trials regarding sepsis and anticoagulant agents such as activated protein C (APC), tissue factor pathway inhibitor, and antithrombin III, heparin may have been a confounder. Hypothesized explanations for this effect included heparin's reversal of the pro-coagulant effects of sepsis or the negation of the anticoagulant effects of the aforementioned agents.^79^ Heparin may therefore have singular beneficial effects on the survival of patients with critical illness (including sepsis).^79^ The studies of Zayas et al.^74^ and Srivastava et al.,^73^ albeit methodologically weak, suggest that heparin's hypothetical role in the care of sepsis and burn injury specifically warrants further investigation. Furthermore, the investigation of heparin's role in the treatment of sepsis may be of particular importance due to issues of cost. Both Reyes et al.^75^ and Zayas et al.^74^ commented on the low cost of heparin. The implication is that this substance might entail a more affordable and sustainable medical intervention for patients with burn injury and sepsis in some countries. Davidson et al.^82^ reported comparable survival benefits with heparin relative to APC in the treatment of sepsis and Kent et al.^83^ noted that heparin was less expensive than APC (e.g., $8.00 for a 96-hour heparin infusion versus $6,700 for a 96-hour APC infusion).

### Heparin and smoke inhalation

Heparin may entail benefits for the treatment of smoke inhalation. One of the abstracted studies contained reports of beneficial outcomes in this area.^59^ Further investigation is warranted because inhalation injury remains a significant factor related to mortality in burn injury.^84^

### Heparin and Psychiatric and Psychosocial Outcomes

The pain associated with a burn injury or wound debridement can adversely affect the psychiatric or psychosocial health of people with burn injury. Wound healing, accompanied by hypertrophic scarring, contractures, functional disability, or cosmetic disfigurement, may also detract from adequate post-burn psychiatric and psychosocial adjustment. The abstracted studies were reviewed to see if there was any evidence to suggest that the use of heparin to treat burns would lead to improved psychiatric and psychosocial outcomes for burn victims.

The authors of the abstracted studies did not systematically examine the psychiatric or psychosocial adjustment of patients with burn injury. Zayas et al. anecdotally addressed the problem in their study of severe pediatric burn injury.^74^ They reported that heparin use eliminated burn pain and the concomitant ‘distress’ associated with wound care. The authors described children who received heparin as “cooperative” during wound care. Similar results were reported for adult patients who had significant burn injuries.^72^ However, the adult reports were also anecdotal and not based on any reliable and valid measures of psychiatric or psychosocial adjustment.

There has been considerable academic and clinical attention focused on the psychopharmacological and non-pharmacological means of ameliorating burn pain and the distress associated with acute wound care.^85^–^88^ Hospitalized, burn-injured children and adolescents in the acute injury phase have been identified to be at risk for developing acute stress disorder (ASD) or post-traumatic stress disorder (PTSD).^89^–^91^ In pediatric and adult patients with burn injury, the pain associated with the injury and subsequent care is thought to be an etiologically significant component of patients' early psychiatric and psychological adjustment.^51,^ ^92^ Zayas et al.,^74^ Venakatachalapthy et al.,^72^ and Srivastava et al.^73^ employed a mixture of anecdotal and objective measures of wound healing, scarring, and contractures, but they reported only immediate clinical outcomes at the time of discharge. They did not consider the psychiatric or psychosocial impact of the burn injuries. Heparin's place as an effective intervention for the prevention or amelioration of psychiatric and psychosocial outcomes associated with burn injuries awaits further systematic research.

## Conclusion

In conclusion, this report summarizes the evidence for the use of heparin to treat burns. After a thorough and systematic literature search and article screening process, 19 articles from 18 unique studies were abstracted and included in this report. From the perspective of heparin's non-anticoagulant properties, there was some evidence that heparin use might result in improved outcomes for burn patients in areas such as mortality, wound healing, pain, and cosmesis. However, this evidence was not strong, and therefore not supportive of, the use of heparin in the treatment of burns. The lack of strong evidence largely resulted from the fact that many of the abstracted studies suffered from serious methodological weaknesses and were altogether of poor quality. Although the evidence is beset by these problems, there still remains a great deal of clinical interest in, and active use of, heparin in burn care. This report contains recommendations for future research into heparin's use in the treatment of burn injury.

## Future Research into Heparin as a Treatment for Burns

Future research into the use of heparin to treat burns should have the following minimum design requirements: well-defined study populations, clearly defined and relevant clinical outcomes (measured using accepted and objective criteria), and valid comparison groups. Future studies should also utilize strong designs that minimize confounding (e.g., randomized controlled trials [RCTs]) and avoid the pitfalls of the 19 articles that were abstracted for this evidence report. These pitfalls included unclear methods of allocation and treatment,^67,^ ^69,^ ^93^ no power calculations or use of validated, well-defined outcomes,^67,^ ^69,^ ^72^ and little discussion of potential biases or study limitations (a problem with all of the abstracted studies). For RCTs, manuscripts should be written in accordance with the Consolidated Standards of Reporting Trials (CONSORT) guidelines, which promote consistent and transparent reporting of RCT results so that readers can assess study quality.^94^

## Design of Studies of Heparin in the Treatment of Burns

### Issues to Consider

The following issues are important to consider when designing studies of heparin in the treatment of burns.

Population. There is great heterogeneity within the burn patient population. These patients can be categorized by burn etiology, burn depth, and burn surface area. Each of these domains has important effects on clinical outcomes such as pain, scarring, length of stay, and mortality. Few of the abstracted studies appropriately defined the populations of interest with respect to these domains. Future studies should be sufficiently powered to perform subgroup analyses by these domains, or they should be designed to focus on a specific type of burn patient (e.g., patients with bilateral upper or lower extremity burns).

To maximize the applicability of study results, researchers should seek to enroll consecutive patients during a pre-specified time period rather than to rely on convenience samples that may be more atypical of the general patient population. For RCTs, which generally have poor generalizability, researchers should attempt to focus on less selective study populations.^95^

Intervention. Some of the abstracted studies contained poor definitions of the type of heparin that was used to treat patients. The following issues must be clarified in future studies:

- Heparin type, concentration, and carrier;
- Time of application, including how soon after injury, frequency of application, and duration of application; and
- Method of application, including concomitant treatments such as dressings.

Control group. Controls must be recruited during the same time frame and from the same locations as people who will be receiving active heparin. For RCTs, the determination of whether a study participant goes into the control or heparin group should be made randomly using a computer-generated algorithm.

The use of historical controls is inappropriate because temporal differences in patient characteristics or treatment protocols might lessen the comparative similarity of the study groups.

Modes of treatment between groups must be as similar as possible, save for the use of heparin in the active treatment group. For example, if heparin is applied using an oil-based carrier, then the control group must have the same carrier applied without heparin. A failure to do so might exaggerate the potential treatment benefits of heparin because it is plausible that the application of the carrier itself could create a protective barrier for the burns. Similar arguments can be made for other carriers.

Outcomes. Many of the abstracted studies focused on non-clinical, or poorly defined clinical, outcomes. To influence medical practice, well-defined, valid, and clinically relevant outcomes must be used in future studies. Validated outcome measures have been developed for use in burns, but they have not yet been applied to assess heparin. For example, one extremely germane outcome in burn injury is scar appearance, which can be measured using the Vancouver Scar Scale.^96^

### Focus of Future Studies of Heparin in the Treatment of Burn Injury

Two sets of studies are proposed to investigate the efficacy of heparin in the treatment of burn injury.

First set of studies. In some countries, the wound healing effects of heparin have been the focus of much research. However, the abstracted evidence is not strong enough to support heparin use as the standard of care for wound healing. Since the lack of strong evidence is due to the poor quality of the abstracted articles, further research into heparin's wound healing properties is justifiable and recommended. As discussed in Chapter 1, there is basic science evidence for heparin's use as a wound healing agent in burn injury, and there is clinical evidence that a temporary dermal replacement consisting of cross-linked collagen and chondroitin-6-sulfate (a molecule similar in structure to heparin) with a silicone coating can promote wound healing in the burned hand.^97^ Indeed, improved wound healing and the possibility of correspondingly improved cosmesis and function are desired objectives for burn care.^47^

Given that research into heparin's ability to heal burn wounds is in its early stages, a preliminary trial is recommended to study whether heparin can accelerate the healing of donor areas for skin grafts. The study population would consist of adults and adolescents who would be randomized to receive heparin plus standard treatment or standard treatment alone as wound care for the donor area of a skin graft (a wound equivalent to a partial thickness burn). In the heparin group, standard, UFH would be applied topically to the donor area approximately 24 hours after stoppage of bleeding. Outcomes would include healing time of the donor area, pain, itching, and scarring. If bleeding persists, heparinoids (e.g., non-anticoagulant heparin) instead of UFH can be used in the heparin group. Research of this type may have an impact on the psychiatric morbidity associated with burn injuries and care, especially morbidity from skin grafting and the pain and discomfort of donor areas. Therefore, psychiatric outcomes such as ASD and PTSD should be evaluated in the proposed study.

If outcomes in the preliminary trial are better in the heparin versus control group, then a second trial could be conducted in adults, adolescents, and children. This trial would involve people with bilateral upper or lower extremity burns (i.e., both hands, arms, or legs). Topical heparin would be applied to one extremity and standard care would be applied to both extremities. Each participant would act as his or her own control, and the extent to which the burn on each extremity heals would be compared using the same outcomes as in the preliminary trial discussed above. Extremity-specific outcomes may also be used in the comparison. For example, if burned hands are the extremity in question, then outcomes could include a thumb opposition score, fingertip-to-palm distance measure, and prehensile score.^97^ Psychiatric outcomes would also be the same as in the preliminary trial, plus there would be an assessment of quality of life.

The trials would be multi-center so that an adequate number of people could be recruited to obtain a power of at least 80 percent. In the case of burn injuries that require early excision and grafting, the route of heparin administration might be of particular relevance. Intravenous and subcutaneous routes may be preferable in this research arena because there would not be direct contamination of graft sites, whereas topical heparin in combination with early excision and grafting might negatively affect graft take and present an unethical risk for patients.

Second study. The second proposed study would involve a single RCT to examine the use of aerosolized heparin to treat critically injured burn patients who are suffering from inhalation injury. Pediatric and adult populations would be randomized to receive standard treatment plus aerosolized heparin or standard treatment alone. Based on the anti-inflammatory properties of heparin (which are summarized in the introduction), it is thought that heparin could contribute to improved outcomes in people with inhalation injury. One of the abstracted studies found positive benefits from using aerosolized heparin and acetylcystine in the treatment of inhalation injury in children, but selection bias could not be ruled out because the control and heparin groups were recruited at different points in time, the authors were not clear as to whether consecutive patients were approached for recruitment into the study, and the authors did not report a participation rate.^59^

Possible outcomes for the RCT on inhalation injury would include mortality, reintubation rate, length of stay in the intensive care unit (ICU), and incidence of pulmonary complications (e.g., acute respiratory distress syndrome, atelectasis, and pneumonia). As with the first set of studies, there should be an investigation of the psychiatric morbidity associated with burn injury and care. In addition to evaluating ASD, PTSD and quality of life, two additional psychiatric outcomes should be examined on account of the ICU context of the RCT, namely ICU psychosis and delirium. The RCT would be carried out in burn centers with advanced levels of technological support to meet patients' intensive care needs and facilitate the use of aerosolized heparin. In addition, burn care centers with advanced technological support would likely enable the identification and description of an optimal patient population. This is particularly important because inhalation injury is strongly associated with mortality, which may act as a confounder in this type of research if not well documented. Multi-site research will be necessary to ensure adequate patient recruitment and meet sample size requirements.

Additional basic science research. The trial of heparin's wound healing properties on donor areas for skin grafts could involve a basic science component. Blood samples or tissue biopsies could be taken from trial participants and examined to gain information on the mechanisms of heparin's action (e.g., heparin's effect on wound-healing cytokines).

Study outcomes. A variety of clinical outcomes should be considered for the next generation of studies on heparin and burns. The outcomes would vary slightly depending on whether adult or pediatric populations are studied. Some of these outcomes are:

1 Mortality;
2 Incidence of medical procedures following initial treatment with heparin or standard therapy (e.g., reintubation, excision, grafting);
3 Pain (measured using the McGill Pain Scale^78^);
4 Scarring (measured using the Vancouver Scar Scale^96^);
5 Itching (measured via the amount of anti-pruritic medications used [e.g., Benadryl®])
6 Quality of Life (measured using the Health Outcomes Burn Questionnaire^98,^ ^99^ for children and the Burn-Specific Health Scale^100^ for adults); and
7 Post-traumatic Stress Disorder (measured using the Child Stress Disorders Checklist^101^ for children and a selected range of measurement methodologies^102^ for adults).

Studies that are designed with the above precepts in mind will overcome the pitfalls of the abstracted articles and provide the clinical community with a clearer picture of the efficacy of the various uses of heparin in the treatment of burns.