# Results

## Literature Review and Screening

The literature search yielded 470 citations. A search of the reference lists of abstracted articles yielded one additional citation of interest, which passed through all levels of screening and went on to be abstracted. In total, 339 citations were excluded from further review following the two initial levels of title and abstract screening; 132 citations proceeded to full text screening. Of these 132 articles, 112 were excluded from further review and 19 advanced to the data abstraction phase. One article could not be retrieved despite persistent inter-library loan requests and attempts to contact the authors and publishing journal. Figure 2 depicts the flow of articles through the screening process. The remainder of this chapter contains a description of the general characteristics of the abstracted articles, a section addressing how the abstracted articles answer the two key questions, and a quality assessment of the abstracted articles.

Figure 2. Flow diagram showing the final number of articles meeting the eligibility criteria

### General Characteristics of the Abstracted Articles

Nineteen articles describing 18 unique research projects contained data on the use of heparin to treat burns (Table 5). In two articles from the University of Michigan, the same group of patients was used to assess outcomes related to deep vein thrombosis.^57,^ ^58^ Eight of the abstracted articles were based on research conducted in the U.S.^57^–^64^ The remainder were from the Soviet Union,^65^–^68^ United Kingdom,^69^ China,^70^ Japan,^71^ India,^72,^ ^73^ El Salvador,^74^ and Mexico.^75^ Sample sizes ranged from 6^64^ to 327.^63^ The sample size was not reported in one article.^62^ The mean sample size, counting the Michigan articles as one, was 62. Samples were composed of patients who presented to hospital burn units or emergency rooms with burn injuries.

Table 5 General characteristics of the abstracted studies

Study | Study Design | Length of Follow-up | Description of Sample | Sample Size | Number/ % Male | Mean Age/ Range | Etiology of Burn | Degree of Burn | TBSAInvolvement
Acharya, 1973, | Cohort | NR | Accident department admissions | Hirudoid cream: n = 36* | NR/NR | NR/NR | NR | 1^st^ | N/A
United Kingdom^69^ | | | | Anacal ointment: n = 16*
| | | | Antibiotics: n = 33
| | | | *Includes heparin
Curreri et al., 1975, | RCT | 14 days | Hospital admissions | 3 groups: heparin, aspirin, control (numbers in each group not reported) | NR/NR | NR/NR | NR | NR | > 30%
U.S.^61^
Desai et al., 1988, | Cohort | 7 days | Pediatric hospital admissions | Heparin: n = 47 (admitted 1990-1994) | NR/NR | Control group: 8.2 years/NR | Inhalation injury | 3^rd^ | 50–55 %
U.S.^59^ | | | | Control: n = 43 (admitted 1985-1989) | | Heparin group: 7.7 years/NR
Iashvili et al., 1986, | Cohort | 80 days | Burn center admissions | Heparin + nicotinic acid: n = 36 | 87/60% | NR/16 – 60 years | Group receiving 5 drugs and controls: inhalation injury | NR | NR
Soviet Union (Georgia)^66^ | | (mean follow-up over four groups) | | Heparin + Contrical: n = 36 | | | Other two groups: NR
| | | | Heparin + nicotinic acid + thrental + phytin + alpha-tocopheral: n = 36
| | | | Control: n = 36
Khadzhiiski et al., 2001, | RCT | 3 years | Hospital admissions | Heparin: n = 32 | NR/NR | NR/1 year and up (upper bound NR) | NR | 2^nd^ | 0–3% reported for one group
Bulgaria^67^ | | | | Control: n = 27
Kuz'muk et al., 1971, | Cohort | 20 days | Hospital admissions | Heparin: n = 50 (divided into two groups based on degree of burn and TBSA) | NR/NR | NR/NR | NR | 1^st^–3^rd^ | >10%
Russia^65^ | | | | Control: n = 30
Mariano et al., 2004, | NRC | Group 1: ~ 1 month | Intensive care unit admissions with burns, septic shock, polytrauma, and acute renal failure | Group 1: n = 6 (treated with citrate + Coupled Plasma Filtration Adsorption) | 10/77% | Group 1: 57 years/26 – 77 years | NR | NR | Group 1: 18–35%;
Italy^68^ | | Group 2: ~2 months | | Group 2: n = 7 (treated with heparin + Coupled Plasma Filtration Adsorption) | | Group 2: 44 years/21 – 60 years | | | Group 2: 40–60%
Mims et al., 1977, | NRC | 10 minutes per experiment (laboratory study) | Burn unit admissions | 34 blood samples from seven burn patients; unknown number of blood samples from 10 controls (normal volunteers) | NR/NR | NR/NR | Thermal | NR | 8.5–90%
U.S.^60^
Ono et al., 1984, | Cohort | N/A | Burn patients | Heparin: n = 4 | N/A/N/A | N/A/N/A | NR | NR | TBSA > 30%
Japan^71^ | | | | Control: n = 8
Peng et al., 2005, | RCT | 4 months | Burn unit admissions | Heparin + venovenous continuous renal replacement therapy: n = 10 | 19/95% | Heparin + venovenous: 34.3 years/NR; | NR | NR | 65.8 ± 13.7%
China^70^ | | | | Controls: n = 10 | | Controls: 32.0 years/NR
Reyes et al., 2001, | Cohort | NR | Admission to emergency room or intensive care unit following industrial explosion | Heparin on admission: n = 4 | 8/89% | 30 years/ | Flame | 2^nd^, 3^rd^ | 51% (30–90%)
Mexico^75^ | | | | Heparin starting day 5: n = 5 (2 patients received heparin before day 5) | | 17 – 40 years
Srivastava et al., 1988, | Cohort | NR | Admissions to burns and plastic surgery unit | Heparin (topical and systemic): n = 25 | Heparin: 11/44% | 8 – 55 years | NR | 3^rd^ | > 40%
India^73^ | | | | Control: n = 25 | Control: 14/56%
Venkatachalapathy et al., Unpublished, | RCT | 7 days | Burn unit admissions | Heparin: n = 50 | 49/49% | NR/15 – 35 years | Flame, scald | 2^nd^ | 5–50%
India^72^ | | | | Control: n = 50
Wahl et al., 2002, | Cohort | NR | Hospital admissions | DVT: n = 7 | 22/73% | DVT: 49 ± 23 years/NR; No | Flame or flash: n = 25 (9 with inhalation injury) | NR | 17 ± 23%
U.S. (a)^57^ + (b)^58†^ | | | | No DVT: n = 23 | | DVT: 44 ± 17 years/NR
Wahl and Brandt, 2001, | Cohort (data-base review) | 3.5 years | Burn center admissions | DVT: n = 8 (3 given low molecular weight heparin) | DVT: 7/88%; | DVT: 44 ± 17 years; | NR | 2^nd^, 3^rd^ | DVT: 34 ± 19%;
U.S.^63^ | | | | No DVT: n = 319 | No DVT: NR/NR | No DVT: 43 ± 19 years | | | No DVT: 17 ± 19%
Waymack et al., 1988, | Cohort (chart review) | N/A | Pediatric burn unit admissions with renal vein thrombosis | Heparin: n = 3 | NR/NR | NR/1.5 – 9 years | NR | NR | 33–90%
U.S.^64^ | | | | Control: n = 3
Zayas et al., Unpublished, | Cohort | 1 year | Pediatric hospital admissions | Heparin: n = 10 (admitted 1999) | 11/58% | 3.5 years/ 0.25 – 8 years | Flame, scald | 2^nd^, 3^rd^ | ≥ 20%
El Salvador^74^ | | | | Control: n = 9 (admitted 1998)

TBSA = total body surface area involvement; NR = not reported; RCT = randomized controlled trial; NRC = non-randomized comparison; DVT = deep vein thrombosis; N/A = not applicable.

† Wahl et al. studies labeled (a)^57^ and (b)^58^ were conducted using the same group of patients.

In eight of nine articles where the complete breakdown of patients was reported by sex, the majority of patients were male.^58,^ ^63,^ ^66,^ ^68,^ ^70,^ ^72^–^75^ The largest proportion of males was 0.95 (19/20)^70^ and the smallest proportion of males was 0.49 (49/100).^72^

The authors of seven articles reported the mean age of patients.^58,^ ^59,^ ^63,^ ^68,^ ^70,^ ^74,^ ^75^ In the five articles with adult populations, the lowest mean age was 30 years^75^ and the highest mean age was 57 years.^68^ In the two articles with pediatric populations, the lowest mean age was 3.2 years^74^ and the highest mean age was approximately 8 years.^59^ Age ranges, reported in ten articles,^58,^ ^63,^ ^64,^ ^66^–^68,^ ^72^–^75^ were as wide as 21 to 77 years^68^ and as narrow as 0.25 (3 months) to 8 years.^74^

The etiology of burn, reported in eight articles,^58^–^60,^ ^63,^ ^66,^ ^72,^ ^74,^ ^75^ included flame,^58,^ ^72,^ ^74,^ ^75^ scald,^72,^ ^74^ inhalation injury,^58,^ ^59,^ ^66^ and ‘thermal’.^60^ One article contained patients with any burn etiology.^63^ Eight articles also contained information about the degree of burn.^59,^ ^63,^ ^65,^ ^67,^ ^69,^ ^72,^ ^74,^ ^75^ Patients with first degree burns were included in two articles,^65,^ ^69^ second degree in six articles,^63,^ ^65,^ ^67,^ ^72,^ ^74,^ ^75^ and third degree in six articles.^59,^ ^63,^ ^65,^ ^73^–^75^

Total body surface area (TBSA) involvement was reported by the authors of 17 articles (exceptions were the authors of the Bulgarian^67^ and British^69^ articles). Reporting was in the form of a range (e.g., 8.5 to 90 percent TBSA),^59,^ ^60,^ ^64,^ ^66,^ ^68,^ ^72^ mean TBSA (e.g., 65.8 ± 13.7 percent),^57,^ ^58,^ ^62,^ ^63,^ ^70,^ ^74,^ ^75^ or the upper or lower bound of TBSA that would be required for a patient to be included in a research project (e.g., TBSA > 30 percent).^61,^ ^65,^ ^71,^ ^73^ No common level of TBSA involvement marked the articles. For example, one article included patients with TBSA involvement between 8.5 and 90 percent.^60^ Other articles included patients with TBSA > 30 percent^61,^ ^71^ or TBSA in the range of 50 to 60 percent.^59,^ ^62^

## Key Questions

### Question 1. What is the Evidence for the Benefits and Harms of Heparin Use in Thermal Injury Care?

The 19 abstracted articles did not contain strong evidence for the efficacy of heparin in treating burns. Three of the articles were randomized controlled trials (RCTs) in adult and pediatric burn patients. The first, by Srivastava et al., was a comparison of heparin and standard therapy to standard therapy alone. Heparin use was found to improve the following outcomes: mortality, infection rate, graft healing, and eschar separation.^73^ For mortality, three out of 25 people died in the heparin group, while 11 out of 25 people died in the control group. Infection rates were lower in the heparin group, with 20 people having wound infection versus all 25 people in the control group. Grafts healed 11 days faster on average in the heparin group and eschar separation was a mean of 9 days faster in the heparin group. The study had a clear monitoring protocol for adverse effects and no increases in bleeding were found as a result of heparin use. Despite the encouraging results, these findings must be weighed against the study's limitations. The authors described the study as randomized, but they did not discuss the allocation method. If allocation was improper, then healthier patients may have been disproportionately assigned to the heparin group. The authors also failed to address blinding, did not clearly define the clinical outcomes, and only reported descriptive statistics. Lastly, the treatment regimen was a combination of systemic and topical heparins, so any potential therapeutic benefits could not be attributed to one route of administration over the other.

The second RCT showed that topical heparin significantly reduced primary scarring in 37 heparin-treated adults and children.^67^ These people were compared to 27 controls who received standard therapy. However, the method of treatment allocation was not described in the publication and the outcome measures were not validated in burned patients. Thus, it is difficult to attribute the favorable outcome to heparin alone.

The third RCT, an unpublished study by Venkatachalapathy et al., was conducted to examine the effect of topical heparin on clinical outcomes in people with second degree burns (age range:15 to 35 years).^72^ Control patients received usual treatment, which included topical antimicrobial cream, debridements, and skin graftings in the early post-burn period. Outcomes included length of hospital stay, mortality, and number of skin grafts. The authors found a significantly (p<0.001) shorter length of hospital stay in the heparin-treated patients (all 50 heparin-treated patients had lengths of stay ≤ 40 days, while 28 of 50 control patients had stays of 40 to 50 days). There was also less mortality (0 heparin versus 5 controls) and fewer skin grafts (4 heparin versus 10 controls) in the heparin group. However, it was unclear how patients were allocated to treatment. The authors simply described the process as “randomly selected.” Indeed, there was an imbalance in the study groups: the control group had more patients with a larger burned surface area (a major predictor of morbidity and mortality in burns). If the controls were sicker, then that fact alone (not the use of heparin) could explain the better outcomes in the heparin group.

Two articles contained investigations of heparin's use in adult-only burn populations. The first, by Reyes et al., was a non-randomized, comparative (cohort) study of nine patients who were injured in a thermal disaster.^75^ Four patients received topical heparin immediately after hospital admission and they were reported to have better pain relief, less swelling, fewer fasciectomies, a shorter length of hospital stay, and earlier burn revascularization than five control patients who did not receive topical heparin until 5 days after hospitalization. While the results were positive for heparin, they must be interpreted cautiously due to two study limitations. First, the important outcome of pain relief was measured using doses of pain medication. Besides the fact that the degree of patient pain is not necessarily associated with doses of pain medication, patients' impressions of pain were never directly assessed in the study. Second, two patients in the control group received daily subcutaneous heparin before day 5 of hospitalization. This ‘contamination’ of the control group diminishes the ability to conclude that inter-group differences were due to the use versus non-use of heparin. The observed differences may have occurred because of random chance owing to the small sample size. Or, given that the heparin and control groups were not treated at the same hospital, subtle variations in institutional practice patterns (e.g., protocols for administering medications) could have led to the observed differences.

The other article about heparin use in adult burn patients was written by Acharya, who compared the effects of three therapies: 1) topical heparin, 2) topical heparin with topical steroid and antibiotic, and 3) topical steroid and antibiotic alone.^69^ In the article, the type and degree of burn were poorly defined (e.g., “superficial burn”) and the outcomes (e.g., pain and reduced inflammation) were vague and poorly validated. The study showed no difference between treatment groups, but the author failed to use statistical hypothesis tests and instead relied on descriptive statistics (e.g., number of patients in each group with “speedy” relief of pain) to make inter-group comparisons.

Three studies focused on the use of heparin to treat burns in pediatric populations. Desai et al. conducted a non-randomized trial (cohort study) to examine the effect of aerosolized heparin with acetylcysteine for 7 days on inhalational burn injuries in children.^59^ The heparin/acetylcysteine group (n = 47) had significantly less reintubations, less atelectasis, and a lower mortality rate than the standard therapy group (n = 43, p < 0.05). However, the results were beset by two major limitations. First, the standard therapy group was a historical cohort whose members received treatment between 1 and 5 years before the first members of the active treatment group received heparin/acetylcysteine. If there were changes in the protocols for managing pediatric burns during this 5 year period, then the observed differences could have been due to these changes, rather than to any possible effect of heparin. Second, heparin and acetylcysteine were tested together, so the impact of either active agent cannot be separated from the other.

Another pediatric study was a 20-year chart review of burned children who developed renal vein thrombosis (RVT).^64^ Six such children were identified in the review; three received heparin and three did not. The three children who did not receive heparin died within 5 days of developing RVT, while the children who received heparin survived. The authors conclude by recommending heparin therapy for burned children with RVT, but the comparison upon which this recommendation is based may be invalid. Although the historical cohort and small sample size are problematic, the main difficulty is that the controls may not have had the same exposure opportunity as the treated patients. Even if there were no contraindications to heparin in the controls, they were diagnosed with RVT within 24 hours of death (n = 2) or at necropsy (n = 1). Thus, the controls may not have had the chance to receive heparin, and they may have been sicker than the children who were treated with heparin.

The final pediatric article was an unpublished cohort study to compare nine children undergoing standard burn therapy in 1998 to 10 children undergoing standard therapy plus heparin (intravenous followed by topical) in 1999.^74^ The authors reported lower mortality (four versus eight deaths) and less pain in the heparin group. The mortality result must be interpreted carefully because the study groups were different with respect to co-morbidity. All nine children in the 1998 (control) group had sepsis, while three children in the 1999 (heparin) group had sepsis. The treatment for sepsis was not well described and may have changed over time, thereby accounting for the difference in mortality. The authors measured pain using subjective, observational criteria like patient behavior (e.g., crying, struggling) and a decrease in the “noisy din and distressing emotional ambience” of the hospital ward. These observations were not measured in a systematic, quantitative fashion and therefore should not be taken as indicative of a treatment effect.

Several abstracted articles met the inclusion criteria at the screening phase, but upon data abstraction they were found to contain little or no clinical data on the use of heparin to treat burns. Four such studies contained no presentation of clinical outcomes, with the focus instead on laboratory outcomes such as autologous red blood cell survival,^62^ fibrin degradation products,^61^ platelet aggregation,^60^ and blood coagulation.^65^ Another three studies examined treatment modalities such as continuous renal replacement and had mentioned heparin in passing, but no outcomes were presented based on heparin therapy.^68,^ ^70,^ ^71^ One study contained treatment regimens that included heparin, but it was not possible to separate the effect of heparin from concomitant therapies such as nicotinic acid, contrical, thrental, phytin, and alpha-tocopherol.^66^ Three studies focused on the possible risk factors for, and incidence of, deep vein thrombosis/pulmonary embolism (DVT/PE) in burn patients.^57,^ ^58,^ ^63^ Each study identified the number of patients with DVT/PE who had been on heparin prophylaxis, but reported no other outcomes by this grouping.

Given the above discussion (summarized in Table 6), some of the abstracted studies contain evidence that heparin has potential clinical benefits in the areas of reducing mortality,^59,^ ^72^–^74^ reducing pain,^72,^ ^75^ improving cosmesis, ^67,^ ^73,^ ^75^ and alleviating lung injury in inhalational burns.^59^ However, these studies suffer from numerous limitations (see above and the quality assessment section below). In light of these limitations, the evidence supporting the use of heparin in burn injury cannot be considered strong.

Table 6 Heparin treatment regimens and results - abstracted studies

Author | Type of Heparin | Method of HeparinAdministration | HeparinTreatment Regimen | Outcomes | Results | Adverse Effects - Heparin
Acharya ^69^ | Hirudoid anti-coagulant (100 g equivalent to 25,000 units of heparin) | Topical | NR | 1) Pain relief (relief within 5 minutes to 3 hours); 2) Healed (reduction of the burned or inflamed surface by ≥ 50% within 3 days) | 1) Hirudoid cream group: 27/36 pain relief and 19/36 healed; 2) Anacal ointment group: 16/16 pain relief and 4/16 healed; 3) Antibiotic group: 24/33 pain relief and 16/33 healed | NR
Curreri et al.^61^ | NR | Subcutaneous | 5,000 units | Fibrin split-product concentration | No quantitative data reported in the published article | NR
Desai et al.^59^ | NR | Aerosolized | 5,000 units of aerosolized heparin alternating with 3 ml of a 20% solution of acetylcystine, every 2 hours for the first 7 days after injury | 1) Reintubation; 2) Atelactasis; 3) Mortality | 1) Reintubation: heparin group 3/47, control group 12/43.; 2) Atelactasis: heparin group 20/47, control group 30/43; 3) Mortality: heparin group 2/47, control group 8/43^†^ | NR
Iashvili et al.^66^ | NR | Subcutaneous | 6,000 units in the 3 groups treated with heparin | 1) Changes in the gastrointestinal mucosa (e.g., ulcers, erosions, and hemorrhages); 2) Separation of the burn eschar; 3) Time between burning and development of the wound surface ready for auto grafting; 4) The period of treatment between burning and complete healing | 1) Changes in the gastrointestinal mucosa: control group12/20, group 4 (complete therapeutic regimen) 7/20; 2) Separation of the burn eschar: 7–9 days faster in group 4; 3) Time between burning and development of the wound surface ready for auto grafting: 44% shorter in group IV; 4) The period of treatment between burning and complete healing: Reduced 30 days in group 4 | NR
Khadzhiiski et al.^67^ | Heparin | Topical | 5,000 IU | Cicatrisation | Significant reduction in primary cicatrisation in 37 treated children and adults compared to 27 controls^†^ | NR
| (cream and dressing)
Kuz'muk et al.^65^ | NR | NR | NR | 1) Prothrombin activity; 2) Thrombotest value; 3) Plasma recalcification time; 4) Plasma tolerance to heparin; 5) Fibrinogen concentration | No quantitative data reported in the published article | NR
Loebl et al.^62^ | NR | Subcutaneous | 20,000 units in four divided doses | Autologous half-life of erythrocytes | No quantitative data reported in the published article | NR
Mariano et al.^68^ | NR | Continuous infusion | Heparin + CPFA as renal replacement therapy | 1) Blood flow; 2) Used cartridges/session; 3) Blood iCa^2+.^; 4) Blood pH and bicarbonates | No quantitative data reported in the published article | NR
Mims et al.^60^ | Beef lung and intestinal mucosal | NR | Heparin not used for treatment (heparin was used as a reagent) | Platelet aggregation | In contrast to controls, 15% of blood samples from burn patients demonstrated spontaneous aggregation, and 69% showed either first or second phase aggregation after exposure to heparin | NR
Ono et al.^71^ | NR | Infusion | 10,000 – 20,000 IU daily | 1) Platelet counts; 2) Fibrinogen levels; 3) Plasminogen levels; 4) Fibrin degradation product levels | No quantitative data reported in the published article | NR
Peng et al.^70^ | Heparin and low molecular weight heparin | Intravenous | 100 – 1,500 units | 1) Median stay in ICU; 2) Total days in hospital; 3) Mortality | No quantitative data reported in the published article | No heparin-related adverse effects observed
Reyes et al. 2001^75^ | NR | Infusion, subcutaneous, sprayed or dripped via needle, aerosolized | 1st application was 5,000 IU/ml dripped or sprayed on open burn surfaces or injected into burn blisters - retreatment at 5 – 10 minute intervals for 20 – 30 minutes | 1) Mean doses of pain medication; 2) Swelling; 3) Fasciectomy; 4) Burn revascularization | 1) Mean doses of pain medication: heparin group (received heparin day 1) = 4 doses, control group (received heparin day 5 and later) = 24 doses^†^; 2) Patients given heparin on day 1 had less burn swelling and body swelling, and no fasciectomies, compared to patients given heparin on day 5; 3) Burn revascularization was faster in patients given heparin on day 1 | Bleeding
Srivastava et al.^73^ | NR | Topical and systemic | 1) Systemic route: 10,000 units/10% burn area, repeated every 4–6 hours; increased to maximum 300–400 units/15% burn/kilogram body weight; 2) Topical application: 25,000 units/10% burn | 1) Mortality; 2) Mean healing time; 3) Full thickness Eschar separation; 4) Raw area fit for grafting; 5) Graft take | 1) Mortality: heparin group 3/25, control group 11/25; 2) Mean healing time: heparin group 6 days (superficial) and 15 days (deep dermal), control group 10 days (superficial) and 28 days (deep dermal); 3) Eschar separation: heparin group 12 days, control group 21 days; 4) Fit for grafting: heparin group 20 days, control group 36 days; 5) Graft take: heparin group 95%, control group 65% | No observed bleeding
Venakatachalapathy et al.^72^ | Heparin sodium solution (bovine intestinal mucosa) | Dripped onto burn surfaces or injected into burn blisters | 200 IU/ml | 1) Mortality; 2) Days in hospital; 3) Number of skin grafts | 1) Mortality: heparin group 0/50, control group 5/50; 2) Days in hospital: heparin group had 29 patients discharged in ≤ 10 days, control group had 3 patients discharged in ≤ 10 days^†^; 3) Number of skin grafts: heparin group 4/50, control group 10/50 | NR
Wahl et al. (a)^57^ + (b)^58‡^ | Low-molecular-weight heparin (enoxaparin) | Subcutaneous | 40 units 4×/day | Development of upper or lower extremity DVT or pulmonary embolism | 7 patients had DVT (1 patient had upper extremiy DVT and 2 patients had both upper and lower extremity DVT). | NR
| | | | | 6 patients had Superficial Vein Thrombosis (SVT) in the upper extremities.
Wahl and Brandt^63^ | Low-molecular-weight heparin | NR | NR | DVT | NR (for heparin) | NR
Waymack et al.^64^ | NR | NR | NR | 1) Mortality; 2) Normal pyelogram (heparin group) | 1) Mortality: heparin group 0/3, control group 3/3; 2) Normal pyelogram: heparin group 3/3, control group not given test | NR
Zayas et al.^74^ | Sodium aqueous heparin (swine intestine) | Intravenous and topical liquid | 1) Scald burns: intravenous one-day dose was 400 IU/kg body weight/15% burn size; 2) Explosion-fire-smoke burns: total one-day dose was 1,000 – 1,200 IU/kg body weight/15% burn size; 3) Topical use (2 – 3X daily): 5,000 IU/ml sprayed via needle onto burn wound surfaces or injected into burn blisters | 1) Survival; 2) Days in hospital; 3) Sepsis; 4) Bleeding | 1) Survival: heparin group 6/10, control group 1/ 9^†^; 2) Days in hospital: heparin group average 36.6 days, control group average 11.4 days (n = 7); 3) Sepsis: heparin group 4/10, control group 9/9^†^; 4) Bleeding: heparin group 1/10, control group 0/9 | Bleeding

NR = not reported; DVT = deep vein thrombosis; SVT = superficial vein thrombosis; CFPA = Coupled Plasma Filtration Adsorption.

† p < 0.05 (in studies without this indication, the results were not statistically significant at the 5% level or the authors did not report whether the results were significant)

‡ Wahl et al. studies labeled (a)^57^ and (b)^58^ were conducted using the same group of patients.

The a priori defined sub-questions to be answered by this review are:

1 Does the method of application make a difference?
2 Do the outcomes vary by the type or degree of burn?
3 How do the outcomes of burn treatment with heparin compare to current treatment without heparin?

Does the method of application make a difference? As illustrated above, there are insufficient data available to determine if the method of application of heparin in burn patients makes a difference with respect to clinical outcomes.

The following gaps exist within the literature. Four published studies^67,^ ^69,^ ^73,^ ^75^ and two unpublished manuscripts^72,^ ^74^ comparatively examined (e.g., treatment versus control) clinical outcomes in the use of heparin to treat burns. Another study had clinical outcomes, but the effect of heparin could not be separated from concomitant therapy.^59^ In these studies, no comparisons were made of systemic heparin (intravenous or subcutaneous) or topical heparin applications to the burn site.

Do the outcomes vary by the type or degree of burn? There are insufficient data available to answer this question. None of the abstracted studies contained analyses where the effectiveness of heparin was stratified by type or degree of burn. In fact, the abstracted studies were often characterized by vague reports of the etiology, type, or degree of burn in the samples.

How do the outcomes of burn treatment with heparin compare to current treatment without heparin? Multiple roles for heparin in the treatment of burns were examined in the abstracted studies. These roles included wound healing and pain control, as well as the treatment of sepsis, inhalation injury, and venous thrombosis. However, there were insufficient data available to answer the key question. This was because the abstracted studies were conducted in eight different countries with varying standards of burn care and published over a time span of three decades. Thus, the studies simply did not encompass any standard, current burn treatment. In addition, nine abstracted studies were primarily laboratory studies without clinical outcomes. ^57,^ ^58,^ ^60^–^63,^ ^65,^ ^68,^ ^70^

The ability to address the key question was further hampered by the major methodologic deficiencies that characterized many of the abstracted articles. Common problems included:

1 Poorly defined burn etiology and degree;
2 Unclear method of treatment allocation;
3 Absence of a control group with no topical anti-inflammatory;
4 Unclear duration of treatment, especially the point at which heparin is first administrated;
5 Outcome variables that are vague and unlikely to be reproducible; and
6 Use of descriptive statistics (no comparative statistics).

Conclusion. Further studies with well-defined populations, treatment regimens, and outcomes are needed to address all three of the above sub-questions. Outcomes must be valid, quantitative, and reproducible. The adverse effects of heparin treatment in burns must also be examined because there is a void on this topic in the literature.

### Question 2. What are the Contraindications of Heparin Use in Burns?

Findings from the abstracted articles. Four of the abstracted articles specifically addressed the issue of contraindications to the use of heparin in burn patients.^72^–^75^ This was limited to listing contraindications for subcutaneous or intravenous applications of heparin such as bleeding diathesis, bleeding history, active bleeding or associated trauma with potential bleeding, active intestinal ulcer, thrombocytopenia, liver disease, renal disorders, or allergy to heparin. The authors of two articles^72,^ ^73^ wrote that these contraindications were exclusion criteria, while the authors of the other two articles^74,^ ^75^ wrote that none of the patients in their studies had any of these contraindications.

Application of existing evidence to the domain of burn treatment. When using heparin in burn patients, it would be prudent to apply the same precautions as would be applied to the use of heparin in patients with thromboembolic disease.

The most common contraindication for heparin in patients with thromboembolic disease is bleeding. The risk of bleeding increases with higher heparin doses and is associated with patients' anticoagulant responses, the method of heparin administration, the co-administration of anti-platelet or fibrinolytic agents, and recent trauma or surgery. Bleeding is as frequent with low molecular weight heparins (LMWHs) as with unfractionated heparin (UFH). In one study, bleeding was observed in 5.2 percent of patients who were given continuous intravenous heparin and in 4.1 percent of patients who were given subcutaneous heparin.^2^ Both groups received approximately the same mean dose over 24 hours.

Heparin can cause thrombocytopenia and is therefore contraindicated in patients who have had recent surgery (primarily for venous problems) or pre-existing cardiovascular disease (primarily arterial).^76^ The incidence of thrombocytopenia was reported to be 0.3 percent in patients treated with heparin prophylaxis and 2.4 percent in patients treated with heparin therapeutically.^2^ Heparin-induced thrombocytopenia is an antibody-mediated process that can lead to arterial or venous thrombosis.

The estimated incidence of vertebral fractures in people receiving long-term UFH therapy is three out of 100. Approximately 30 out of 100 people who receive therapeutic doses of heparin for longer than one month will experience reduced bone density that can lead to osteopoenia or osteoporosis.^77^ The risk of osteoporosis was observed in groups of patients who had received long-term heparin therapy (> 6 months) at doses greater than 15,000 anti-Xa units. Much of the research on heparin and osteoporosis has been confined to pregnant women, so prolonged heparin use is contraindicated in this group.^76^ Osteoporosis is less common with LMWHs than with UFH.

Much of the available evidence regarding contraindications to heparin concerns subcutaneous or intravenous applications of the substance. In some of the abstracted articles, heparin was applied topically and there is no information regarding the contraindications of heparin when administered by this route.

Reported adverse effects of heparin in treating burns. Fifteen of the abstracted articles did not contain reports of adverse effects in the use of heparin to treat burns. The methods sections of these articles did not indicate that monitoring for adverse effects was an objective of any of this research. Srivastava et al. reported a clear monitoring protocol for adverse effects (in their case, bleeding) and they did not find any increases in bleeding secondary to heparin use.^73^ Two other articles contained reports of bleeding in heparin-treated patients^74^;^75^ and one article^70^ had mention of the fact that no heparin-related adverse effects were observed in the sample.

The incidence of bleeding was low when reported. One heparin-treated patient in a pediatric study (n = 19) bled on the burn surface, but the role of heparin as a contributing factor was unclear because the patient also had sepsis, which was a major cause of this person's death.^74^ In another study (n = 9), three patients who received topical heparin beginning on the fifth day of hospital admission developed bleeding on day 8 of the study.^75^ However, the authors attribute the bleeding to a treatment error: the dose of heparin was not reduced following burn revascularization. The bleeding may have been avoided if heparin was titrated properly.

## Quality Assessment of Abstracted Articles

### Overview

Ten of the nineteen abstracted articles (Group A) pertained directly to the use of heparin to treat burns or the complications of burns.^59,^ ^64,^ ^66,^ ^67,^ ^69,^ ^71^–^75^ The other nine articles (Group B) contained information that could be used to make indirect inferences about heparin and burns.^57,^ ^58,^ ^60^–^63,^ ^65,^ ^68,^ ^70^

Given that nine of the abstracted articles were published in 1988 or before, and five were RCTs, certain sections of the EPH Tool applied to only a fraction of the entire set of 19 articles. For example, the questions in the EPH Tool about sample size and power calculations applied to only the more recently published articles because reporting guidelines for published manuscripts are a relatively new phenomenon. Consequently, articles published two decades ago do not reflect the same reporting standards as today. Another example of the EPH Tool's restricted applicability is the section on intervention integrity, which is designed for RCTs because the investigator assigns the exposure.

To standardize the EPH Tool across all 19 articles, the questions that were universally applicable to all of the articles were considered in the quality assessment. These questions were: (1) selection bias - participants representative of study population, percentage of selected participants who agreed to participate, completion rate; (2) study design - allocation to treatment groups, use of valid data collection instruments; (3) control of confounding - reported differences between exposure groups with respect to important confounders, attempts to control confounding; (4) statistical methods - use of appropriate statistical methods, finding of statistical significance. The removal of certain questions meant that the EPH Tool's qualitative scoring algorithms could not be used to assign scores of weak, moderate, or strong to the various sections of the scale. Instead, written commentary is provided below on what the answers to the EPH Tool suggest for study quality. This information is summarized in Table 7.

Table 7 Quality assessment of abstracted articles

| Selection Bias | | | Study Design | | | Control of Confounding | | Statistical Methods
Authors | Participants Representative of Study Population | PR | CR | Explained TreatmentAssignmentof Subjects | Blinding | Use of Valid Data Collection Tools | Groups Differ on Confounders | Control of Confounding | Statistical Methods Used | SS of Results Reported
Group A
Acharya^69^ | Not likely | NR | ≥ 80% | No | NR | No | NR | No | NR | No
Desai et al.^59^ | Not to somewhat likely | NR | ≥ 80% | No | NR | No | NR | No | Between-group comparisons | Yes
Iashvili et al.^66^ | Very likely | NR | ≥ 80% | No | NR | Yes | Yes | No | NR | No
Khadzhiiski et al.^67^ | Not likely | NR | ≥ 80% | No | NR | No | NR | No | Between-group comparisons | No
Ono et al.^71^ | Not likely | NR | ≥ 80% | No | NR | No | | No | NR | No
Reyes et al.^75^ | Somewhat likely | ≥ 80% | ≥ 80% | Yes | NR | No | Yes | No | Between-group comparisons | Yes
Srivastava et al.^73^ | Not likely | NR | ≥ 80% | No | NR | No | NR | No | NR | No
Venakatachalapathy et al.^72^ | Very likely | ≥ 80% | ≥ 80% | No | NR | No | Yes | No | Between-group comparisons | Yes
Waymack et al.^64^ | Not likely | N/A | N/A | No | NR | No | Yes | No | NR | No
Zayas et al.^74^ | Somewhat likely | ≥ 80% | ≥ 80% | Yes | NR | No | Yes | No | Between-group comparisons | Yes
Group B
Curreri et al.^61^ | Not to somewhat likely | NR | ≥ 80% | No | NR | Yes | NR | No | Between-group comparisons | Yes
Kuz'muk et al.^65^ | Not likely | NR | NR | No | NR | NR | NR | No | NR | No
Loebl et al.^62^ | Not likely | ≥ 80% | ≥ 80% | No | NR | Yes | NR | No | Between-group comparisons | Yes
Mariano et al.^68^ | Not likely | NR | ≥ 80% | Yes | NR | Yes | NR | No | Between-group comparisons | Yes
Mims et al.^60^ | Not likely | NR | ≥ 80% | No | NR | Yes | Yes | No | Between-group comparisons | No
Peng et al.^70^ | Not likely | ≥ 80% | ≥ 80% | No | NR | Yes | | No | Between-group comparisons | Yes
Wahl et al.^57^ | Somewhat likely | ≥ 80% | ≥ 80% | No | NR | Yes | NR | No | Between-group comparisons | No
Wahl et al.^58^ | Somewhat likely | ≥ 80% | 75% | No | NR | Yes | Yes | No | Between-group comparisons | No
Wahl et al.^63^ | Somewhat to very likely | N/A | N/A | No | NR | Yes | Yes | No | Between-group comparisons | No

PR = participation rate; CR = completion rate; SS = statistical significance; NRC = non-randomized comparison; NR = not reported; RCT = randomized controlled trial; N/A = not applicable.

### Selection Bias

At least half of the articles were vulnerable to selection bias. The authors of five Group A articles^64,^ ^67,^ ^69,^ ^71,^ ^73^ and five Group B articles^60,^ ^62,^ ^65,^ ^68,^ ^70^ simply reported the numbers of patients that participated in the research. The authors did not mention the recruitment time period, nor whether consecutive sets of patients were assessed for study eligibility. The omissions in reporting, coupled with a conservative approach to quality assessment, meant that one could not rule out the possibility that highly selected groups of patients were used in these articles. Indeed, the authors of one article wrote that they used “a selected series” of patients.^69^ These ten articles were rated as not likely to contain participants who were representative of the study population. Conversely, two Group A articles^66,^ ^72^ were rated as very likely to contain representative participants, two^74,^ ^75^ were rated somewhat likely, and one^59^ was rated not to somewhat likely. Of the Group B articles, one^63^ was rated as somewhat to very likely, two were rated somewhat likely,^57,^ ^58^ and one^61^ was rated not to somewhat likely.

The omissions in reporting extended to the participation rate (e.g., the percentage of recruited patients who actually participated in the research). The authors of six Group A articles^59,^ ^66,^ ^67,^ ^69,^ ^71,^ ^73^ did not report any data on this subject, nor did the authors of four Group B articles.^60,^ ^61,^ ^65,^ ^68^ In articles that did contain information, the participation rate was 80 percent or better in four articles.^57,^ ^62,^ ^70,^ ^75^ In four Group A articles^59,^ ^64,^ ^69,^ ^71^ and six Group B articles,^57,^ ^58,^ ^60^–^62,^ ^65^ the authors reported little or no data (e.g., age, sex) on the characteristics of people who did participate.

Reporting was better for completion rates. Excluding a chart review,^64^ the other nine Group A articles had completion rates of 80 percent or more. One Group B article^58^ had a completion rate of 75 percent and six^57,^ ^60^–^62,^ ^68,^ ^70^ (excluding a database review^63^) had completion rates of 80 percent or more. Completion rates were not reported in one Group B article.^65^

### Study Design

Eight^59,^ ^64,^ ^66,^ ^69,^ ^71,^ ^73^–^75^ Group A articles reported on non-randomized, comparative (e.g., cohort) studies and two reported on RCTs.^67,^ ^72^ The major problem with the cohort studies was a lack of information on how the treatments (exposures) were allocated between exposure groups. Without this information, it is impossible to ascertain whether the characteristics of the different exposure groups could have influenced treatment allocation or treatment outcome. For example, in the chart review, all of the patients who did not receive heparin died.^64^ If these patients would not have been eligible to receive heparin, perhaps because they were too sick, then the comparison with heparin-treated patients is invalid. In the two RCTs, the method of randomization was not reported, thus raising questions about whether confounding variables had been evenly distributed among the treatment groups. Indeed, in one of the RCTs, more severely burned patients were randomized to the control group.^72^

In Group B, three articles^61,^ ^62,^ ^70^ were RCTs, three^58,^ ^63,^ ^65^ were non-randomized, comparison (cohort) studies, two^60,^ ^68^ were non-randomized, comparative laboratory studies, and one^57^ was a before/after study. Treatment allocation was also an issue in this group. The authors of the RCTs did not report the method of randomization, and one of the non-RCTs had an explanation for the allocation of heparin treatment.^68^ Of course, it should be noted that none of the studies in Group B were designed to evaluate the direct effect of heparin treatment in burn injury. Consequently, these authors cannot be expected to comment on the allocation of heparin.

None of the studies in either group contained mention of whether people who assessed study outcomes were blinded to treatment allocation. This raises the specter of bias due to differential misclassification. However, the presence and impact of said bias cannot be assessed given the dearth of information in the published study reports.

Valid data collection instruments were used in one article from Group A.^66^ In another article from Group A, a non-validated, and not fully explained, four-point scale was used to measure pain.^69^ For Group B, eight studies had valid data collection instruments. These instruments were primarily laboratory tests to measure biological factors such as platelet aggregation^60^ or D-dimer levels.^57^ One Group B article did not contain mention of the data collection instruments that were used in the research.^65^

### Control of Confounding

There was no attempt to control for possible confounding in any of the 19 articles. In three Group A articles^64,^ ^69,^ ^71^ and three Group B articles,^60,^ ^63,^ ^65^ there was no mention of basic potential confounders such as age, sex, or comorbidity. Differences between exposure groups with respect to important confounders were reported in five Group A articles^64,^ ^66,^ ^72,^ ^74,^ ^75^ and four Group B articles.^58,^ ^60,^ ^63,^ ^70^ Six non-RCTs^57,^ ^59,^ ^65,^ ^68,^ ^69,^ ^73^ in Groups A and B did not contain specific mention of any differences. Three of the RCT publications did not include comparisons of study participants across treatment groups.^61,^ ^62,^ ^67^ The authors of one RCT did report such comparisons for age, sex, and TBSA.^70^

### Statistical Methods

Statistical methods were basic between-group comparisons of data such as the mean number of doses of pain medication. This was the case for five Group A articles^59,^ ^67,^ ^72,^ ^74,^ ^75^ and five Group B articles.^57,^ ^58,^ ^63,^ ^68,^ ^70^ In Group A, which involved articles that directly examined heparin in burns, three^64,^ ^66,^ ^69^ of the articles did not appear to contain any comparative statistical methods and the authors of two articles^71,^ ^73^ made no attempt to do any statistical comparisons whatsoever. In three Group B articles,^60^–^62^ standard errors were reported and comparisons were done, but the types of statistical tests used in the analyses were not reported, nor were p-values provided.

Four articles in Group A^59,^ ^72,^ ^74,^ ^75^ and four articles in Group B^61,^ ^62,^ ^68,^ ^70^ contained information on whether statistically significant differences were found at the 5 percent level for outcomes involving heparin. This information was not contained in the remaining articles from either group.

### Conclusion

The overall quality of the 19 abstracted articles on heparin use in burn care is poor. Selection bias cannot be ruled out for many of the articles because the authors did not report on patient recruitment or participation rate. Similarly, non-reporting was a problem in the area of study design because only one published manuscript contained a report of how treatments (exposures) were allocated amongst study participants.^68^ As well, none of the authors provided information on whether outcome assessors were blinded as to treatment allocation. For confounding, potential differences between treatment groups on important confounders were reported in half of the articles, and no attempts were made in any of the articles to address possible confounding. Statistical methods - when reported - were simple between-group comparisons. Many authors did not report the type of statistical test nor provide a p-value. In some instances, no statistical comparisons were performed at all.