# Methods

## Analytic Framework

An analytic framework is a schematic representation of the strategy for organizing topics for review and guiding literature searches. Figure 1 illustrates the inter-relationships between the questions being asked in this evidence report. The key areas addressed are the use of heparin to treat burns, heparin's method of application (e.g., topical, intravenous), the clinical outcomes and contraindications of said treatment, and a comparison of heparin to other burn treatments. Heparin can be applied topically (e.g., cream or dressing material impregnated with heparin), subcutaneously, by infusion, via aerosol, or by a combination of any of the aforementioned methods. Burns are described by degree (first, second, third), total body surface area (TBSA) involvement, and type (flame, scald, flash, contact, smoke inhalation, electrical, or any combination of these types). The clinical outcomes are separated into early and late outcomes. Early outcomes include the need for acute hospitalization and surgery (e.g., grafting, debridement, and fasciotomy), quality of graft take (percentage), pain, mortality (prior to discharge from hospital), length of hospital stay, scarring (size, hypertrophic scarring, contractures), rehabilitation outcomes (decreased range of motion), intensive care unit (ICU) admissions and respiratory measures (e.g., length of intubation), incidence of thromboses and emboli, complications such as bleeding or infection, and acute psychiatric adjustment (delirium, acute stress disorder [ASD] and post-traumatic stress disorder [PTSD]). Late outcomes include rehabilitation, re-grafting, reconstructive surgery, quality of life, psychiatric adjustment (anxiety, depression), and mortality (after discharge from hospital). The three major contraindications to heparin use are thrombocytopenia, bleeding, and osteoporosis (after long term use). The benefits of heparin use in burn care, compared to other burn treatments without heparin, will be explored in the results and discussion sections of this report.

Figure 1. Analytical Framework

## Topic Assessment and Refinement

### Research Team

A multidisciplinary, local research team (‘local experts’) with expertise in epidemiology and systematic reviews (M. Oremus, PhD; P. Raina, PhD), pediatric psychiatry and pediatric burn injury consultation (M. Hanson, MD), clinical chemistry (E. Young, PhD), and surgery (R. Whitlock, MD; A. Dal Cin, MD) was assembled at the McMaster University Evidence-based Practice Center (MU-EPC) to plan an approach to completing this evidence report in a thorough, timely, and efficient manner. This team had regular meetings to reach consensus on key methodological issues.

A ‘kick-off’ teleconference with the partner organization (Saliba Burns Institute), the Agency for Healthcare Research and Quality (AHRQ) Task Order Officer (TOO), the local experts, and MU-EPC staff was held at the start of this project to define the magnitude of the topic and refine and clarify the preliminary research questions for this evidence report. A Technical Expert Panel (TEP), composed of internationally recognized experts in the field of burns, was assembled to provide high-level content expertise on heparin use and burns. Members of the TEP were requested to participate in teleconferences on an as-needed basis throughout the data refinement and data abstraction phases of this evidence report.

### Technical Expert Panel Teleconference Calls

The first TEP teleconference took place on November 29, 2005. Technical experts participating included Dr. Bishara Atiyeh (Clinical Professor Of Surgery, Plastic And Reconstructive Surgery, American University of Beirut Medical Center, Beirut, Lebanon), Dr. Leo Klein (Head, Department of Burns Medicine, Charles University and Teaching Hospital, Prague, Czech Republic), Dr. Jan Koller (Slovak Society of Plastic and Aesthetic Surgery, Bratislava, Slovakia), and Dr. Glenn Warden (Editor, Journal of Burn Care and Research, Salt Lake City, Utah) (see Appendix A *). A second TEP teleconference took place on February 3, 2006. Several topics were discussed during both calls, including the definition and scope of the key questions, search strategies, inclusion and exclusion criteria, and the composition of the screening and data abstraction forms.

* Appendixes are provided electronically at http://www.ahrq.gov/clinic/tp/heparntp.htm

## General Methods

### Key Questions

The original set of key questions for this evidence report was revised by the local experts and discussed during the TEP teleconferences. Additional discussants included the partner organization and the TOO.

The revised key questions are:

1 What is the evidence for the benefits and harms of heparin use in thermal injury care?
  a Does the method of application make a difference?
  b Do the outcomes vary by the type or degree of burn?
  c How do the outcomes of burn treatment with heparin compare to current treatment without heparin?
2 What are the contraindications of heparin use in burns?

### Literature Search Strategy

We conducted a comprehensive search of the literature to capture all relevant, published studies on the topic of heparin and burns. The following electronic databases were included in the search:

1 MEDLINE (1966-current);
2 EMBASE (1980-current);
3 CINAHL (Cumulative Index to Nursing and Allied Health) (1982-current);
4 The Cochrane Central Database of Controlled Trials (1995-current);
5 Web of Science (1976-current); and
6 BIOSIS (1976-current).

In addition, literature in the U.S. and European Patent Offices was searched for relevant studies, members of the TEP and the partner organization were asked to supplement the database search with additional references of published and unpublished studies, and the reference lists of articles that passed full text screening were also searched for relevant studies. Please see Appendix B for a detailed description of the search strategies used for this review.

Inclusion/exclusion criteria. A list of inclusion/exclusion criteria was developed to screen studies for this evidence report. The criteria are as follows:

Language. There was no language restriction. Studies published in any language could be included in the report.

Study design. Studies required a comparison arm for inclusion. Case series, case reports, editorials, letters, comments, opinions, abstracts, animal experiments, and conference proceedings were excluded from the report.

Population. Human patients of any age, with burns of all types, grades, and TBSA involvement, could be included in the report.

Outcomes. Studies with the following outcomes could be included:

1 Need for surgical procedure (e.g., grafting, debridement, fasciotomy, quality of graft take [percentage], re-grafting, reconstructive surgery);
2 Pain;
3 Transfusion rate;
4 Mortality (prior to, or after, discharge from hospital);
5 Length of stay in hospital;
6 Scarring (size, hypertrophic scarring);
7 Decrease in range of motion, function, or activities of daily living;
8 Respiratory measures (e.g., length of intubation);
9 Thrombosis and emboli;
10 Complications (e.g., bleeding, infection);
11 Rehabilitation;
12 Quality of life; and
13 Psychiatric adjustment (e.g., PTSD, anxiety, depression).

Appendix C * contains the list of excluded studies.

## Data Collection and Reliability of Study Selection

A team of research assistants was trained to apply the inclusion/exclusion criteria. Standardized forms were developed for this purpose, as well as for data abstraction (see Appendix D). The forms were created and stored online using Systematic Review Software (SRS; TrialStat Corp., Ottawa, Ontario).

For title and abstract screening, two independent raters evaluated the citations that were obtained from the literature search. Articles that met the inclusion/exclusion criteria, or for which there was insufficient information to determine if they met the criteria, were retrieved for further assessment. Once retrieved, the entire text of the article was screened to determine if the inclusion/exclusion criteria were satisfied. At this stage, an article could be excluded from further review if both raters agreed that it did not satisfy the inclusion/exclusion criteria. In cases of disagreement, the raters met to arrive at a consensus.

Articles that survived the full text screening phase went on to full data abstraction. Either a local expert or a MU-EPC staff member abstracted the data. Local experts who were responsible for addressing the key questions in the results chapter reviewed the abstractions to confirm the accuracy of the work.

### Quality Assessment of Abstracted Studies

The quality of the studies that passed the full text screening was assessed using the Effective Public Health Practice Project Quality Assessment Tool for Quantitative Studies (EPH Tool [see Appendix E *]).^55^ The EPH Tool was developed for systematic reviews of the effectiveness of public health interventions.

The EPH Tool can be utilized with observational studies or clinical trials. It is divided into several sections, including selection and allocation bias, confounding, blinding, validity and reliability of data collection instruments, analysis (e.g., use of appropriate statistical methods), and intervention integrity (e.g., percentage of participants who actually received the allocated intervention or exposure). Each section contains from one to seven questions; algorithms^56^ are used to transform question responses into a qualitative score for each section. The score options are weak, moderate, or strong.

Two raters, either a local expert or a MU-EPC staff member, conducted the quality assessment for each article that passed the full text screening phase. Differences were resolved by consensus.

## Summary of Findings: Descriptive and Analytic Approaches

Descriptive approaches were used to summarize the characteristics of abstracted articles and answer the key questions. The local experts judged that a meta-analysis was not feasible because the abstracted articles were far too heterogeneous with respect to study participants, study design, treatment modalities, and outcomes. Instead, data were collected on the characteristics of study participants, methods of diagnosis, treatments, and outcomes. The quality of this information was judged and the findings were summarized in both text and tables. This evidence report provides a greater understanding of the effectiveness of using heparin in burn treatment, identifies gaps in existing research, and suggests a plan for future research.

## Peer Review Process

The partner organization, local experts, and members of the TEP were asked to identify potential peer reviewers from relevant professional organizations, consumer organizations, and purchasers of care. A list of potential reviewers was compiled by the MU-EPC and submitted to AHRQ for approval prior to the circulation of the draft report. The reviewers were asked to review the report and provide feedback on clinical and methodological content, as well as on the readability and presentation of information. Their comments and suggestions will be incorporated into the report where possible.