# Appendix E - Quality Assessment - Effective Public Health Practice Project Quality Assessment Tool 2003

To see the Quality Assessment Tool 2003, please select the link below. This link will take you to a PDF version of the Tool.

Effective Public Health Practice Project Quality Assessment Tool 2003