# Appendix D - Forms

To see the Forms, please select the link below. This link will take you to a PDF version of the forms.

Forms