# Appendix C - List of Excluded Studies

## References

Agnelli G, Sonaglia F. Prevention of venous thromboembolism. Thromb Res. 2000;97(1):V49-V62. Status: Excluded because no comparison group. [pmid: 10668808].
Akhtar M, Gang RK. Treatment of Burns with Topical Heparin - Study of Its Analgesic Effect. Chirurgia Plastica. 1979;5(1):51-3. Status: Excluded because no comparison group.
Aronson SB, Elliott JH, Moore TE Jr, et al. Pathogenetic approach to therapy of peripheral corneal inflammatory disease. Am J Ophthalmol. Jul. 1970;70(1):65-90. Status: Excluded because no use of heparin in burns. [pmid: 4316175].
Askoseljavaara S, Alho A, Sundell B, et al. Heparin Improves and Alpha-Blocker Treatment Possibly Impairs Host-Resistance in Burns. Burns. 1977;4(2):140-2. Status: Excluded because no use of heparin in burns.
Author(s) Unknown. Ophthalmic levocabastine for allergic conjunctivitis. Med Lett Drugs Ther 1994; 36(920):35–6 Status: Excluded because no use of heparin in burns
Bahm J. The fatal fight for upper limb preservation in severe electrical burns. Microsurgery. 1997;17(5):286-9. Status: Excluded because no comparison group. [pmid: 9220445].
Ballinger WF, Wise L. Gastric mucus: quantitative and qualitative studies in humans and dogs. Br J Surg. Sep. 1969;56(9):701-2. Status: Excluded because no use of heparin in burns. [pmid: 4241276].
Barret JP, Desai MH, Herndon DN. Effects of tracheostomies on infection and airway complications in pediatric burn patients. Burns. 2000;26(2):190-3. Status: Excluded because no use of heparin in burns. [pmid: 10716364].
Berkessy S. Letter: High-dosage heparin treatment of large burns. JAMA. Dec 17. 1973;226(12):1464. Status: Excluded because no comparison group. [pmid: 4800818].
Boyce ST, Greenhalgh DG, Kagan RJ, et al. Skin anatomy and antigen expression after burn wound closure with composite grafts of cultured skin cells and biopolymers. Plast Reconstr Surg. Apr. 1993;91(4):632-41. Status: Excluded because no use of heparin in burns. [pmid: 8446717].
Boyce ST, Goretsky MJ, Greenhalgh DG, et al. Comparative assessment of cultured skin substitutes and native skin autograft for treatment of full-thickness burns. Ann Surg. Dec. 1995;222(6):743-52. Status: Excluded because no use of heparin in burns. [pmid: 8526581]. [pmcid: 1235023].
Braunstein KM, Dodds KA, Stewart G, et al. Heparin Cofactor Activity Following Thermal Injury. Am J Clin Pathol. 1978;70(4):632-6. Status: Excluded because no use of heparin in burns. [pmid: 707431].
Brean L, Bormioli M, Angela GC, et al. Coagulation disorders due to burns. Disseminated intravascular coagulation (DIC) and its possible prevention. Minerva Med. Aug 29. 1975;66(55):2729-42. Status: Excluded because no comparison group. [pmid: 1161170].
Burkhardt H, Zellner PR, Moller I. Factor XIII deficiency in burns. Chirurg. Aug. 1977;48(8):520-3. Status: Excluded because not retrievable. [pmid: 902534].
Buyukcelik A, Akbulut H. Thromboembolism in patients with cancer. Turkish Journal of Haematology. 2004;21(1):7-11. Status: Excluded because no comparison group.
Cancio LC, Mozingo DW, Pruitt BA Jr. Strategies for diagnosing and treating asphyxiation and inhalation injuries: How to recognize warning signs and minimize morbidity/mortality risk. J Crit Illn. 1997;12(4):217-29. Status: Excluded because no comparison group.
Cancio LC. Current concepts in the pathophysiology and treatment of inhalation injury. Trauma. 2005;7(1):19-35. Status: Excluded because no use of heparin in burns.
Chen X-L, Sun Y-X, Hu D-L. An unusual case of volatile organic compounds explosion burns. Burns. 2005;31(2):240-2. Status: Excluded because no comparison group. [pmid: 15683702].
Clagett GP, Anderson FA Jr, Geerts W, et al. Prevention of venous thromboembolism. Chest. 1998;114(5 Suppl):531S-60S. Status: Excluded because no comparison group. [pmid: 9822062].
Cox CS. Heparin for smoke inhalation injury. Crit Care Med. 2003;31(4):1291. Status: Excluded because no comparison group. [pmid: 12682515].
Criado PR, Ramos RDO, Criado RFJ, et al. Severe cutaneous adverse reactions to drugs - Relevant aspects to diagnosis and treatment - Part I: Anaphylaxis and anaphylactoid reactions, erythroderma and the clinical spectrum of Stevens-Johnson syndrome & toxic epidermal necrolysis (Lyell's disease). An Bras Dermatol. 2004;79(4):471-88. Status: Excluded because no use of heparin in burns.
Danielsson P, Nilsson L, Nettelblad H, et al. Is there a need for antithrombin III substitution early after burn injury?. Burns. Jun. 1997;23(4):300-5. Status: Excluded because no comparison group. [pmid: 9248638].
Davanzo F, Ruggeroni ML, Trojsi C, et al. A new therapy for hydrofluoric acid burns. Med Lav. 1987;78(4):333-6. Status: Excluded because no comparison group. [pmid: 3683281].
DeAngelis V, Matrisciano F. Use of acetyl-cysteine in corneal burns: Our experiences. Rass Int Clin Ter. 1991;71(22):1035-7. Status: Excluded because no comparison group.
Dellinger RP. Respiratory and critical care medicine: Preface. Sem Respir Crit Care Med. 2001;22(1):1-2. Status: Excluded because no use of heparin in burns.
Demling R, Wolberg WH. Effect of heparin and cold immersion on burn edema. Surg Forum. 1977;28:29-30. Status: Excluded because animal study. [pmid: 617449].
Demling RH, Mazess R, Hanson J, et al. Effect of Heparin on Edema After 2nd-Degree and 3rd-Degree Burns. J Surg Res. 1979;26(1):27-32. Status: Excluded because animal study. [pmid: 759724].
Demling RH. The burn edema process: Current concepts. J Burn Care Rehabil. 2005;26(3):207-27. Status: Excluded because no comparison group. [pmid: 15879742].
Di Stefano F, Giglio A, Vinci M, et al. Low molecular weight heparins for long-term therapy of peripheral vascular disease. Results of a controlled study. Curr Ther Res Clin Exp. 1988;44(1):1-10. Status: Excluded because no use of heparin in burns.
Dougherty W, Waxman K. The complexities of managing severe burns with associated trauma. Surg Clin North Am. 1996;76(4):923-58. Status: Excluded because no comparison group. [pmid: 8782481].
Dunlavey ES. Topical antibiotics in dermatology for uses other than acne. Curr Probl Dermatol. 2000;12(5):216-21. Status: Excluded because no use of heparin in burns.
Durango Gutierrez LF, Vargas GF. Management of the burnt patient. Iatreia. 2004;17(1):54-61. Status: Excluded because no comparison group.
Ellis RJ, Cunningham MT, Cook JD. Laboratory heparin resistance in burn injury complicated by venous thrombosis. Burns. 1999;25(8):749-52. Status: Excluded because no comparison group. [pmid: 10630858].
Eriksson E, Plymforshell K, Robson MC. Distant Micro-Circulatory Changes After A Major Burn - Effects of Methyl Prednisolone, Dextran-40, Heparin and Normal Saline. Burns. 1981;7(3):158-61. Status: Excluded because animal study.
Fecher AM, O'Mara MS, Goldfarb IW, et al. Analysis of deep vein thrombosis in burn patients. Burns. 2004;30(6):591-3. Status: Excluded because no comparison group. [pmid: 15302428].
Finta B, Haines DE. Catheter ablation therapy for atrial fibrillation. Cardiol Clin. 2004;22(1):127-45. Status: Excluded because no use of heparin in burns. [pmid: 14994853].
Fitts CT, Cathcart RS III, Artz CP, et al. Acute gastrointestinal tract ulceration: Cushing's ulcer, steroid ulcer, Curling's ulcer and stress ulcer. Am Surg. Apr. 1971;37(4):218-23. Status: Excluded because no comparison group. [pmid: 4252987].
Fortun J, Navas E. A critical approach to the pathogenesis, diagnosis, treatment and prevention of catheter-related bloodstream infections and nosocomial endocarditis. Clin Microbiol Infect. 1999;5(2 Suppl.):2S40-50. Status: Excluded because no use of heparin in burns.
Geerts WH, Heit JA, Clagett GP, et al. Prevention of venous thromboembolism. Chest. 2001;119(1 Suppl.):132S-75S. Status: Excluded because no use of heparin in burns. [pmid: 11157647].
Gehrke CF, Penner JA, Niederhuber J, et al. Coagulation defects in burned patients. Surg Gynecol Obstet. Oct. 1971;133(4):613-6. Status: Excluded because no use of heparin in burns. [pmid: 4255400].
Geiger JP, Gielchinsky I. Acute pulmonary insufficiency. Treatment in Vietnam casualties. Arch Surg. Apr. 1971;102(4):400-5. Status: Excluded because no use of heparin in burns. [pmid: 4994911].
Georgieva SA, Kobzeva TV. Blood Heparin Activity in Patients with Burns. Khirurgiya 1982(4):21–3 Status: Excluded because no comparison group
Ghislain P-D, Roujeau J-C. Treatment of severe drug reactions: Stevens-Johnson syndrome, toxicepidermal necrolysis and hypersensitivity syndrome. Dermatol Online J. 2002;8(1):147-58. Status: Excluded because no use of heparin in burns.
Goodwin MN Jr. Selected anatomic burn pathology review for clinicians and pathologists. Aviat Space Environ Med. Oct. 1989;60(10 Pt 2):B39-B43. Status: Excluded because no use of heparin in burns. [pmid: 2818385].
Gorman R, Gordan L, Zumberg M, et al. Successful use of argatroban as an anticoagulant in burn-related severe acquired antithrombin III deficiency after heparin failure. Thromb Haemost. 2001;86(6):1596-7. Status: Excluded because no comparison group. [pmid: 11776342].
Grabosch A, Rokos H. Neopterin as parameter of cell-mediated immunity response in thermally injured patients. Burns. 1992;18(2):113-6. Status: Excluded because no comparison group. [pmid: 1590924].
Guimbretiere J, Lebeaupin R, Pannier M. Burns and Heparin-Therapy. Anesthesie Analgesie Reanimation. 1977;34(6):1339-44. Status: Excluded because no comparison group.
Guimbretiere J. Unbalanced coagulation among burned patients. Convergences Medicales. 1982;1(4):289-97. Status: Excluded because no comparison group.
Hainaut J, Guilbaud J, Dhennin C, et al. Quantitation of at Iii on Chromogenic Substrate - Prognosis of Thermal-Injury with Heparin Treatment. Haemostasis. 1982;12(12):74. Status: Excluded because no comparison group.
Hansbrough JF, Boyce ST, Cooper ML, et al. Burn wound closure with cultured autologous keratinocytes and fibroblasts attached to a collagen-glycosaminoglycan substrate. JAMA. Oct. 1989;262(15):2125-30. Status: Excluded because no comparison group. [pmid: 2677425].
Harriger MD, Warden GD, Greenhalgh DG, et al. Pigmentation and microanatomy of skin regenerated from composite grafts of cultured cells and biopolymers applied to full-thickness burn wounds. Transplantation. Mar 15. 1995;59(5):702-7. Status: Excluded because no use of heparin in burns. [pmid: 7886796].
Harrington DT, Mozingo DW, Cancio L, et al. Thermally injured patients are at significant risk for thromboembolic complications. Journal of Trauma-Injury Infection and Critical Care. 2001;50(3):495-9. Status: Excluded because no use of heparin in burns.
Hatzifotis M, Williams A, Muller M, et al. Hydrofluoric acid burns. Burns. 2004;30(2):156-9. Status: Excluded because no use of heparin in burns. [pmid: 15019125].
Hauben DJ, Mahler D, Neumann L. A burn formula in clinical practice. Ann R Coll Surg Engl. Jul. 1981;63(4):293-4. Status: Excluded because no use of heparin in burns. [pmid: 7247292]. [pmcid: 2493791].
Hawkins DB, Demeter MJ, Barnett TE. Caustic ingestion: Controversies in management. A review of 214 cases. Laryngoscope. 1980;90(1):98-109. Status: Excluded because no use of heparin in burns. [pmid: 7356772].
Hirsh J. Prevention of deep venous thrombosis. Br J Hosp Med. 1981;26(2):143-7. Status: Excluded because no comparison group. [pmid: 7296130].
Hubsher J, Olshan AR, Schwartz AB, et al. Continuous arteriovenous hemofiltration for the treatment of anasarca and acute renal failure in severely burned patients. ASAIO Trans. Jul. 1986;32(1):401-4. Status: Excluded because no comparison group. [pmid: 3778742].
Hurnikova M, Dostalova D. Continuous elimination methods in burn patients from the point of view of a nurse. Acta Chir Plast. 2005;47(2):55-7. Status: Excluded because no comparison group. [pmid: 16033154].
Johansson SA. Platelets, coagulation factors and 5-hydroxytryptamine in sensitization, anaphylaxis and burn injuries. Effect of heparin and possible relation to intravascular coagulation. Acta Med Scand Suppl. 1967;471:1-30. Status: Excluded because no comparison group. [pmid: 5231222].
Kereiakes DJ. The fire that burns within: C-reactive protein. Circulation. 2003;107(3):373-4. Status: Excluded because no use of heparin in burns. [pmid: 12551855].
Kim K-J, Park Y-T, Yoo J-H, et al. Hydrofluoric acid burns. Exogenous Dermatology. 2004;3(1):12-8. Status: Excluded because no comparison group.
Kinsella J, Rae CP. Smoke inhalation and airway injury. Baillieres Clinical Anaesthesiology. 1997;11(3):385-406. Status: Excluded because no comparison group.
Konigova R. Commentary. Acta Chir Plast. 1997;39(1):36. Status: Excluded because no use of heparin in burns.
Latenser BA, Iteld L. Smoke inhalation injury. Sem Respir Crit Care Med. 2001;22(1):13-22. Status: Excluded because no use of heparin in burns.
Lawrence JC, Carney SA. Tangential excision of burns: studies on the metabolic activity of the recipient areas for skin grafts. Br J Plast Surg. Apr. 1973;26(2):93-100. Status: Excluded because no use of heparin in burns. [pmid: 4267558].
Liljedahl SO, Frisk A, Wickman K. Successful treatment of Candida septicaemia in severely burned patients with a new antimycotic, clotrimazole (Bay b 5097). Injury. Nov. 1972;4(2):157-63. Status: Excluded because no use of heparin. [pmid: 4578796].
Lloyd JR. Thermal trauma: therapeutic achievements and investigative horizons. Surg Clin North Am. Feb. 1977;57(1):121-38. Status: Excluded because no use of heparin in burns. [pmid: 193208].
Lunan HN. Topical treatment of the burn patient. Am J Hosp Pharm. Jun. 1975;32(6):599-605. Status: Excluded because no use of heparin in burns. [pmid: 1080358].
Masaki F, Isao T, Aya Y, et al. Extensive thrombosis of the inferior vena cava and portal vein following electrical injury. Burns. 2005;31(5):660-4. Status: Excluded because no comparison group. [pmid: 15993315].
Maxwell RA, Blanchard TR, Hickerson WB, et al. Management of an unusual thermal injury to the thigh. Journal of Trauma-Injury Infection & Critical Care. 1999;46(5):976-7. Status: Excluded because no comparison group.
Mayou BJ, Wee J, Girling M. Deep vein thrombosis in burns. Burns. 1981;7(6):438-40. Status: Excluded because no comparison group.
McAuliffe PF, Mozingo DW. Inhalation injury and ventilator management. Problems in General Surgery. 2003;20(1):97-105. Status: Excluded because no comparison group.
McCall JE, Cahill TJ. Respiratory care of the burn patient. Journal of Burn Care & Rehabilitation. 2005;26(3):200-6. Status: Excluded because no comparison group. [pmid: 15879741].
Mcmanus WF, Eurenius K, Pruitt BA Jr. Disseminated intravascular coagulation in burned patients. J Trauma. May. 1973;13(5):416-22. Status: Excluded because no comparison group. [pmid: 4701839].
Miller SF. Blood platelets in severely injured burn patients. Burns. 1999;25(2):187. Status: Excluded because no comparison group. [pmid: 10208400].
Monafo WW. Initial management of burns. N Engl J Med. 1996;335(21):1581-6. Status: Excluded because no use of heparin in burns. [pmid: 8900093].
Moore FD. Reflections on new treatments for burns—caveat legor. JAMA. Jul 16. 1973;225(3):294-5. Status: Excluded because no comparison group. [pmid: 4740378].
Moore FD Jr. Therapeutic regulation of the complement system in acute injury states. Adv Immunol. 1994;56:267-99. Status: Excluded because no use of heparin in burns. [pmid: 8073948].
Munster AM. The early management of thermal burns. Surgery. Jan. 1980;87(1):29-40. Status: Excluded because no use of heparin in burns. [pmid: 6765998].
Norman KE. Alternative treatments for disseminated intravascular coagulation. Drug News Perspect. 2004;17(4):243-50. Status: Excluded because no use of heparin in burns. [pmid: 15334173].
Ors S. Hand burn in severe Raynaud's phenomenon: Case report. Burns. 2004;30(3):272-5. Status: Excluded because no comparison group. [pmid: 15082358].
Parks DA, Skinner KA, Skinner HB, et al. Multiple organ dysfunction syndrome: Role of xanthine oxidase and nitric oxide. Pathophysiology. 1998;5(1):49-66. Status: Excluded because no use of heparin in burns.
Pastorova VE, Liapina LA, Tabakina TE. The indices of the function of the anticoagulation system and of the nonenzymatic fibrinolytic activity of the antithrombin III-heparin-thrombin complex in the blood of children with burn and traumatic shock. Fiziol Cheloveka. Mar. 1990;16(2):71-6. Status: Excluded because no use of heparin in burns.
Purdue GF, Hunt JL. Pulmonary emboli in burned patients. J Trauma. Feb. 1988;28(2):218-20. Status: Excluded because no comparison group. [pmid: 3346921].
Ramasamy K, Gumaste VV. Corrosive ingestion in adults. J Clin Gastroenterol. 2003;37(2):119-24. Status: Excluded because no use of heparin in burns. [pmid: 12869880].
Renard G, Hirsch M, Pouliquen Y. Sem and Tem Study of Heparin Injection in Anterior-Chamber After Experimental Alkali Burn of Cornea. Exp Eye Res. 1977;25(5):533-4. Status: Excluded because animal study.
Rzany B, Mockenhaupt M, Hollander N, et al. Stevens-Johnson syndrome (SJS) and toxic epidermal necrolysis (TEN): Evaluation for drug risk based on sale numbers in defined daily doses (DDD). Example of the H2-antagonists. Pharmacoepidemiol Drug Saf. 1995;4(4):207-12. Status: Excluded because no use of heparin in burns.
Sadik F. Burn injuries and their therapy. Pharmindex. 1988;30(3):9-15. Status: Excluded because no use of heparin in burns.
Saffle JR. What's new in general surgery: Burns and metabolism. J Am Coll Surg. 2003;196(2):267-89. Status: Excluded because no comparison group. [pmid: 12595056].
Saliba MJ Jr. Heparin efficacy in burns. II. Human thermal burn treatment with large doses of topical and parenteral heparin. Aerosp Med. Nov. 1970;41(11):1302-6. Status: Excluded because there is no comparison group. [pmid: 4395237].
Saliba MJ Jr, Dempsey WC, Kruggel JL. Large burns in humans. Treatment with heparin. JAMA. Jul 16. 1973;225(3):261. Status: Excluded because there is no comparison group. [pmid: 4740376].
Saliba MJ Jr. The effects and uses of heparin in the care of burns that improves treatment and enhances the quality of life. Acta Chir Plast. 1997;39(1):13-6. Status: Excluded because there is no comparison group. [pmid: 9212486].
Sevitt S, Innes D. Prothrombin-time and thrombotest in injured patients on prophylactic anticoagulant therapy. Lancet. Jan 18. 1964;283(7325):121-80. Status: Excluded because no use of heparin in burns.
Sheridan R. Specific therapies for inhalation injury. Crit Care Med. 2002;30(3):718-9. Status: Excluded because no use of heparin in burns. [pmid: 11990950].
Shetlar MR, Van Lier P, Hern DL, et al. Uronic acid-containing polypeptides from the urine of burned patients. Proc Soc Exp Biol Med. Dec. 1969;132(3):999-1002. Status: Excluded because no use of heparin in burns. [pmid: 4243364].
Shetlar MR, Shetlar CL, Chien SF, et al. The hypertrophic scar. Hexosamine containing components of burn scars. Proc Soc Exp Biol Med. Feb. 1972;139(2):544-7. Status: Excluded because no use of heparin in burns. [pmid: 4258165].
Shook CD, MacMillan BG, Altemeier WA. Pulmonary complications of the burn patient. Arch Surg. Aug. 1968;97(2):215-24. Status: Excluded because no comparison group. [pmid: 4872481].
Simon TL, Curreri PW, Harker LA. Kinetic characterization of hemostasis in thermal injury. J Lab Clin Med. Apr. 1977;89(4):702-11. Status: Excluded because no use of heparin in burns. [pmid: 845474].
Summerly R, Jefferson BM. Sulphated acid mucopolysaccharides in actinic elastosis. Br J Dermatol. Jan. 1969;81(1):51-9. Status: Excluded because no use of heparin in burns. [pmid: 4236714].
Thomas S, Humphries J, Fear-Price M. The role of moist wound healing in the management of meningococcal skin lesions: A case study. World Wide Wounds 1999 (June) Status: Excluded because no use of heparin in burns
Traber DL, Traber LD. Airway blood flow changes and airway obstruction following lung injury. Arch Physiol Biochem. 2003;111(4):297-300. Status: Excluded because animal study. [pmid: 15764058].
Tremblay R, Ethier J, Querin S, et al. Venovenous continuous renal replacement therapy for burned patients with acute renal failure. Burns. 2000;26(7):638-43. Status: Excluded because no use of heparin in burns. [pmid: 10925188].
Triedman JK. So far, so good . J Cardiovasc Electrophysiol. 2004;15(3):284-5. Status: Excluded because no comparison group. [pmid: 15030416].
Troshev K, Dimitrov R. Application of heparin in the local treatment of burns. Acta Chir Plast. 2001;43(4):143-4. Status: Excluded because no comparison group. [pmid: 11789055].
Truong AT, Kowal-Vern A, Latenser BA. Aerosolized heparin does not improve pulmonary function in ventilated burn patients with < 50%TBSA. Crit Care Med. 2001;29(12):A49. Status: Excluded because no comparison group.
Vaglini M, Ammatuna M, Nava M. Regional perfusion at high temperature in treatment of stage IIIA–IIIAB melanoma patients. Tumori. 1983;69(6):585-8. Status: Excluded because no use of heparin in burns. [pmid: 6665881].
Volcheck GW. Clinical evaluation and management of drug hypersensitivity. Immunol Allergy Clin North Am. 2004;24(3):357-71. Status: Excluded because no use of heparin in burns. [pmid: 15242716].
Wolf SE, Debroy M, Herndon DN. The cornerstones and directions of pediatric burn care. Pediatr Surg Int. 1997;12(56):312-20. [pmid: 9244089].
Woodley DT. Covering wounds with cultured keratinocytes. JAMA. Oct. 1989;262(15):2140-1. Status: Excluded because no use of heparin in burns. [pmid: 2795787].
Yannas IV, Burke JF, Warpehoski M, et al. Prompt, long-term functional replacement of skin. Trans Am Soc Artif Intern Organs. 1981;27:19-23. Status: Excluded because no use of heparin in burns. [pmid: 7036496].
Yannas IV. What criteria should be used for designing artificial skin replacements and how well do the current grafting materials meet these criteria?. J Trauma. Sep. 1984;24(9 Suppl):S29-S39. Status: Excluded because no use of heparin in burns. [pmid: 6384532].
Yogaratnam D, Smith BS, Angood PB, et al. Antifactor Xa levels in four patients with burn injuries who received enoxaparin to prevent venous thromboembolism. Pharmacotherapy. 2004;24(12):1793-9. Status: Excluded because no comparison group. [pmid: 15585445].
Zamecnikova I, Tymonova J, Stetinsky J, et al. Critical and severe burn injury in children. Acta Chir Plast. 2005;47(1):16-8. Status: Excluded because no comparison group. [pmid: 15954457].