# Appendix B-Search Strings

## Ovid MEDLINE(R) December 2005

1 exp BURNS/ (34176)
2 (burn or burns or scald$).ti,ab. (27779)
3 (burn or burns or scald$).kw,kf. (39)
4 thermal injur$.mp. (3113)
5 or/1–4 (41466)
6 Glycosaminoglycans/ (18154)
7 exp Heparin/ (43913)
8 heparin, therapeutic/ (0)
9 anticoagulant$.mp. (45650)
10 fibrinolytic agent$.mp. (15759)
11 glucosaminoglycan$.mp. (227)
12 heparin.mp. (62357)
13 (heparinic acid or alpha-heparin or alpha heparin or liquaemin or sodium heparin).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (304)
14 or/6–13 (120774)
15 or/7–8,12–13 (63236)
16 5 and 15 (178)
17 5 and 14 (293)
18 animals/ not (humans/ and animals/) (3013652)
19 17 not 18 (204)
20 16 not 18 (120)
21 limit 20 to (clinical trial or clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or comment or congresses or consensus development conference or consensus development conference, nih or controlled clinical trial or “corrected and republished article” or dictionary or directory or duplicate publication or editorial or evaluation studies or festschrift or government publications or guideline or historical article or interview or journal article or lectures or legal cases or legislation or letter or meta analysis or multicenter study or news or newspaper article or overall or patient education handout or periodical index or practice guideline or randomized controlled trial) (120)
22 limit 21 to (clinical trial or clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or evaluation studies or randomized controlled trial) (5)
23 limit 20 to (addresses or bibliography or biography or case reports or comment or congresses or dictionary or directory or editorial or interview or lectures or letter) (20)
24 16 not 23 (158)
25 from 24 keep 1–158 (158)

## EMBASE December 2005

1 Glycosaminoglycans/ (8239)
2 exp Heparin/ (56642)
3 heparin, therapeutic/ (0)
4 anticoagulant$.mp. (44490)
5 fibrinolytic agent$.mp. (10502)
6 glucosaminoglycan$.mp. (131)
7 heparin.mp. (74395)
8 (heparinic acid or alpha-heparin or alpha heparin or liquaemin or sodium heparin).mp. [mp=title, abstract, subject headings, heading word, drug trade name, original title, device manufacturer, drug manufacturer name] (281)
9 or/1–8 (115664)
10 or/2–3,7–8 (74395)
11 (Alpha Heparin or Ammonium Heparinate or Benzalkonium or Heparin or Clarin or Contusol or Disebrin or Eleparon or Elheparin or Elheparon or Endogenous Heparin or Epiheparin or Gag 98 or Hepalean or Heparinate Sodium or Heparine or Heparine Novo or Heparinic Acid or Heparin Lock Flush or Heparin Monosulfate or Heparin Ointment or Heparin Potassium or Heparin Sodium or Heparin Sulfate or Heparin Sulfuric Acid or Heparitin Monosulfate or Hepcon or Hep Lock or Hepsal or Lipo Hepin or Lipohepin or Liquaemin or Liquaemin or Sodium Liquemin or Menaven or Monoparin or Mucoitin Polysulfate or Mucoitin Polysulfate Ester or Mucoitin Sodium Polysulfate or Multiparin or Noparin or Panheparin or Panhepin or Panheprin or Praecivenin or Pularin or Sodium Heparin or Thrombareduct or Thromboliquin or Thromboliquine or Thrombophlogat or Thrombophob or Thrombophob Gel or Thrombosamine or Thrombosamine Heparin or Thrombosamine Heparine or Thrombo Vetren or Unfractionated Heparin or Vetren or Vister).mp. [mp=title, abstract, subject headings, heading word, drug trade name, original title, device manufacturer, drug manufacturer name] (77001)
12 2 or 3 or 7 or 8 or 11 (77001)
13 exp burn/ or exp chemical injury/ (21157)
14 (burn or burns or scald$ or thermal injur$).mp. (27192)
15 13 or 14 (29169)
16 12 and 15 (245)
17 animal/ or (animal/ and human/) (15813)
18 animals/ not (humans/ and animals/) (12812)
19 16 not 18 (245)
20 limit 19 to (editorial or erratum or letter or note or “review”) (59)
21 19 not 20 (186)
22 from 21 keep 1–186 (186)

## CINAHL December 2005

1 Glycosaminoglycans/ (41)
2 exp Heparin/ (1872)
3 heparin, therapeutic/ (0)
4 anticoagulant$.mp. (1997)
5 fibrinolytic agent$.mp. (823)
6 glucosaminoglycan$.mp. (2)
7 heparin.mp. (2304)
8 (heparinic acid or alpha-heparin or alpha heparin or liquaemin or sodium heparin).mp. [mp=title, subject heading word, abstract, instrumentation] (16)
9 or/1–8 (4465)
10 or/2–3,7–8 (2306)
11 (Alpha Heparin or Ammonium Heparinate or Benzalkonium or Heparin or Clarin or Contusol or Disebrin or Eleparon or Elheparin or Elheparon or Endogenous Heparin or Epiheparin or Gag 98 or Hepalean or Heparinate Sodium or Heparine or Heparine Novo or Heparinic Acid or Heparin Lock Flush or Heparin Monosulfate or Heparin Ointment or Heparin Potassium or Heparin Sodium or Heparin Sulfate or Heparin Sulfuric Acid or Heparitin Monosulfate or Hepcon or Hep Lock or Hepsal or Lipo Hepin or Lipohepin or Liquaemin or Liquaemin or Sodium Liquemin or Menaven or Monoparin or Mucoitin Polysulfate or Mucoitin Polysulfate Ester or Mucoitin Sodium Polysulfate or Multiparin or Noparin or Panheparin or Panhepin or Panheprin or Praecivenin or Pularin or Sodium Heparin or Thrombareduct or Thromboliquin or Thromboliquine or Thrombophlogat or Thrombophob or Thrombophob Gel or Thrombosamine or Thrombosamine Heparin or Thrombosamine Heparine or Thrombo Vetren or Unfractionated Heparin or Vetren or Vister).mp. [mp=title, subject heading word, abstract, instrumentation] (2329)
12 2 or 3 or 7 or 8 or 11 (2331)
13 exp burn/ or exp chemical injury/ (5156)
14 (burn or burns or scald$ or thermal injur$).mp. (5878)
15 13 or 14 (6313)
16 12 and 15 (12)
17 animal/ or (animal/ and human/) (630)
18 animals/ not (humans/ and animals/) (630)
19 16 not 18 (12)
20 limit 19 to (editorial or erratum or letter or note or “review”) [Limit not valid in: CINAHL; records were retained] (3)
21 19 not 20 (9)
22 from 21 keep 1–9 (9)

## EBM Reviews - Cochrane Central Register of Controlled Trials December 2005

1 Glycosaminoglycans/ (171)
2 exp Heparin/ (2686)
3 heparin, therapeutic/ (0)
4 anticoagulant$.mp. (2762)
5 fibrinolytic agent$.mp. (1185)
6 glucosaminoglycan$.mp. (8)
7 heparin.mp. (5293)
8 (heparinic acid or alpha-heparin or alpha heparin or liquaemin or sodium heparin).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (71)
9 or/1–8 (7651)
10 or/2–3,7–8 (5388)
11 (Alpha Heparin or Ammonium Heparinate or Benzalkonium or Heparin or Clarin or Contusol or Disebrin or Eleparon or Elheparin or Elheparon or Endogenous Heparin or Epiheparin or Gag 98 or Hepalean or Heparinate Sodium or Heparine or Heparine Novo or Heparinic Acid or Heparin Lock Flush or Heparin Monosulfate or Heparin Ointment or Heparin Potassium or Heparin Sodium or Heparin Sulfate or Heparin Sulfuric Acid or Heparitin Monosulfate or Hepcon or Hep Lock or Hepsal or Lipo Hepin or Lipohepin or Liquaemin or Liquaemin or Sodium Liquemin or Menaven or Monoparin or Mucoitin Polysulfate or Mucoitin Polysulfate Ester or Mucoitin Sodium Polysulfate or Multiparin or Noparin or Panheparin or Panhepin or Panheprin or Praecivenin or Pularin or Sodium Heparin or Thrombareduct or Thromboliquin or Thromboliquine or Thrombophlogat or Thrombophob or Thrombophob Gel or Thrombosamine or Thrombosamine Heparin or Thrombosamine Heparine or Thrombo Vetren or Unfractionated Heparin or Vetren or Vister).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (5440)
12 2 or 3 or 7 or 8 or 11 (5535)
13 exp burns/ (664)
14 (burn or burns or scald$ or thermal injur$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (1175)
15 13 or 14 (1257)
16 12 and 15 (5)
17 from 16 keep 1–5 (5)
18 from 17 keep 1–5 (5)

## WOS (Web of Science) December 2005

TS=((heparin* OR Benzalkonium or Clarin or Contusol or Disebrin or Eleparon or Elheparin or Elheparon or Epiheparin or Gag 98 or Hepalean or Heparitin Monosulfate or Hepcon or Hep Lock or Hepsal or Lipo Hepin or Lipohepin or Liquaemin or Liquaemin or Sodium Liquemin or Menaven or Monoparin or Mucoitin Polysulfate or Mucoitin Polysulfate Ester or Mucoitin Sodium Polysulfate or Multiparin or Noparin or Panheparin or Panhepin or Panheprin or Praecivenin or Pularin or Thrombareduct or Thromboliquin or Thromboliquine or Thrombophlogat or Thrombophob or Thrombophob Gel or Thrombosamine or Thrombo Vetren or Vetren or Vister) AND (burn or burns or scald* or thermal injur*))

## BIOSIS December 2005

TS=((heparin* OR Benzalkonium or Clarin or Contusol or Disebrin or Eleparon or Elheparin or Elheparon or Epiheparin or Gag 98 or Hepalean or Heparitin Monosulfate or Hepcon or Hep Lock or Hepsal or Lipo Hepin or Lipohepin or Liquaemin or Liquaemin or Sodium Liquemin or Menaven or Monoparin or Mucoitin Polysulfate or Mucoitin Polysulfate Ester or Mucoitin Sodium Polysulfate or Multiparin or Noparin or Panheparin or Panhepin or Panheprin or Praecivenin or Pularin or Thrombareduct or Thromboliquin or Thromboliquine or Thrombophlogat or Thrombophob or Thrombophob Gel or Thrombosamine or Thrombo Vetren or Vetren or Vister) AND (burn or burns or scald* or thermal injur*))