# Appendix A -Technical Expert Panel

- Bishara Atiyeh, MD, FACS, PhD
- Secretary General, WHO: Mediterranean Council for Burns & Fire Disasters
- Clinical Professor, Division of Plastic and Reconstructive Surgery
- American University of Beirut Medical Center
- Beirut, Lebanon

- David Herndon, MD
- President, International Society for Burn Injuries
- Chief of Staff, Galveston Shriners Hospital
- Galveston, Texas

- Leo Klein, MD, PhD
- Brigadier General, Surgeon General of the Czech Armed Forces (retired)
- Head, Dept. of Burns Medicine, Prague Burn Center
- Associate Professor, 3rd Medical Faculty, Charles University
- Prague, Czech Republic

- Ján Koller, MD, CSc, PhD
- President, European Association of Tissue Banks
- Head, Teaching Department for Burns and Reconstructive Surgery
- Central Tissue Bank
- University Hospital Bratislava Ruzinov
- Bratislava, Slovak Republic

- Gurvaneet Randhawa, MD, MPH
- Task Order Officer, Agency for Healthcare Research and Quality
- Rockville, Maryland

- Michael J. Saliba Jr., MD
- Nominator of the heparin and burns topic to AHRQ
- Chairman, The Saliba Burns Institute
- La Jolla, California

- Glenn Warden, MD, MBA
- President and CEO, Warden BioScience Associates
- Salt Lake City, Utah

- Steven E. Wolf, MD
- Professor, Department of Surgery
- University of Texas Health Science Center at San Antonio
- Director, US Army Institute of Surgical Research Burn Center
- Brooke Army Medical Center
- Fort Sam Houston, Texas