# Appendixes

Appendix A -Technical Expert Panel

Appendix B-Search Strings

Appendix C - List of Excluded Studies

Appendix D - Forms

Appendix E - Quality Assessment - Effective Public Health Practice Project Quality Assessment Tool 2003