# References and Included Studies

1 Bakker E, Wyndaele JJ. Changes in the toilet training of children during the last 60 years: the cause of an increase in lower urinary tract dysfunction?. BJU Int. 2000;86:248-52. [pmid: 10930924].
2 Rogers J. Promoting continence: the child with special needs. Nurs Stand. 1998;12(34):47-55. [pmid: 9687716].
3 Brazelton TB, Christophersen ER, Frauman AC, et al. Instruction, timeliness, and medical influences affecting toilet training. Pediatrics. 1999;103:1353-58. [pmid: 10353953].
4 Bettison S. Toilet training the retarded: analysis of the stages of development and procedures for designing programs. Aust J Ment Retard. 1978;5:95-100.
5 deVries MW, deVries MR. Cultural relativity of toilet training readiness: a perspective from East Africa. Pediatrics. 1977;60(2):170-7. [pmid: 887331].
6 US Dept of Labor, Children's Bureau. Infant Care (report). Publication 8, 1932.
7 Lieberman L. The changing ideology of socialization: toilet training, mass media, and society. Int J Contemp Sociol. 1972;9(4):188-99.
8 Brazelton TB. A child-oriented approach to toilet training. Pediatrics. 1962;29:121-8. [pmid: 13872676].
9 Foxx RM, Azrin NH. Dry pants: a rapid method of toilet training children. Behav Res Ther. 1973;11(4):435-42. [pmid: 4777640].
10 Vincent CE. Trends in infant care ideas. Child Dev. 1951;22(3):199-209. [pmid: 14870226].
11 Giles DK, Wolf MM. Toilet training institutionalized, severe retardates: an application of operant behavior modification techniques. Am J Ment Defic. 1966;70(5):766-80. [pmid: 5908530].
12 Staddon JE, Cerutti DT. Operant conditioning. Annu Rev Psychol. 2003;54:115-44. [pmid: 12415075]. [pmcid: 1473025].
13 Sun M, Rugolotto S. Assisted infant toilet training in a Western family setting. J Dev Behav Pediatr. 2004;25(2):99-101. [pmid: 15083131].
14 Shaikh N. Time to get on the potty: are constipation and stool toileting refusal causing delayed toilet training?. J Pediatr. 2004;145(1):12-3. [pmid: 15238899].
15 Smeets PM, Lancioni GE, Ball TS, et al. Shaping self-initiated toileting in infants. J Appl Behav Anal. 1985;18(4):303-8. [pmid: 4086412]. [pmcid: 1308025].
16 Stadtler AC, Gorski PA, Brazelton TB. Toilet training methods, clinical interventions, and recommendations. Pediatrics. 1999;103(6):1359-61. [pmid: 10353954].
17 Community Paediatrics Committee CPS. Toilet learning: anticipatory guidance with a child-oriented approach. J Paediatr Child Health. 2000;5(6):333-5.
18 Schum TR, McAuliffe TL, Simms MD, et al. Factors associated with toilet training in the 1990s. Ambul Pediatr. 2001;1(2):79-86. [pmid: 11888377].
19 Blum NJ, Taubman B, Nemeth N. Relationship between age at initiation of toilet training and duration of training: a prospective study. Pediatrics. 2003;111(4 Pt 1):810-4. [pmid: 12671117].
20 Schum TR, Kolb TM, McAuliffe TL, et al. Sequential acquisition of toilet-training skills: a descriptive study of sex and age differences in normal children. Pediatrics. 2002;109(3):48-54.
21 Blum NJ, Taubman B, Nemeth N. Why is toilet training occurring at older ages? A study of factors associated with later training. J Pediatr. 2004;145(1):107-11. [pmid: 15238916].
22 Pickering LK, Bartlett AV, Woodward WE. Acute infectious diarrhea among children in day care: epidemiology and control. Rev Infect Dis. 1986;8(4):539-47. [pmid: 3529310].
23 Borowitz SM, Cox DJ, Tam A, et al. Precipitants of constipation during early childhood. J Am Board Fam Pract. 2003;16(3):213-8. [pmid: 12755248].
24 Loening-Baucke V. Encopresis and soiling. Pediatr Clin North Am. 1996;43(1):279-98. [pmid: 8596685].
25 Partin JC, Hamill SK, Fischel JE, et al. Painful defecation and fecal soiling in children. Pediatrics. 1992;89:1007-9. [pmid: 1594338].
26 Baker SS, Liptak GS, Colletti RB, et al. Constipation in infants and children: evaluation and treatment. A medical position statement of the North American Society for Pediatric Gastroenterology and Nutrition. J Pediatr Gastroenterol Nutr. 1999;29(5):612-26. [pmid: 10554136].
27 Rasquin-Weber A, Hyman PE, Cucchiara S, et al. Childhood functional gastrointestinal disorders. Gut. 1999;45(Suppl 2):1160-8.
28 Fleisher DR. Understanding toilet training difficulties. Pediatrics. 2004;113(6):1809-10. [pmid: 15173510].
29 van Ginkel R, Buller HA, Heymans HS, et al. Functional childhood gastrointestinal disorders. III. Constipation and solitary encopresis; diagnosis work-up and therapy. Ned Tijdschr Geneeskd. 2003;147(26):1267-71. [pmid: 12861667].
30 Abramovitch IB, Abramovitch HH. Enuresis in cross-cultural perspective: A comparison of training for elimination control in three Israeli ethnic groups. J Soc Psychol. 1989;129(1):47-56. [pmid: 2733401].
31 Pachter LM, Dworkin PH. Maternal expectations about normal child development in 4 cultural groups. Arch Pediatr Adolesc Med. 1997;151(11):1144-50. [pmid: 9369877].
32 Wheeler M. 1998. Toilet training for individuals with autism and related disorders: a comprehensive guide for parents and teachers. Arlington, Texas:Future Horizons.
33 Ando H. Training autistic children to urinate in the toilet through operant conditioning techniques. J Autism Child Schizophr. 1977;7(2):151-63. [pmid: 68952].
34 Stadtler AC, Burke P. A group treatment approach to failure to toilet train: the case of Max. Clin Excell Nurse Pract. 1998;2(2):83-7. [pmid: 10451268].
35 Luxem M, Christophersen E. Behavioral toilet training in early childhood: research, practice, and implications. J Dev Behav Pediatr. 1994;15(5):370-8. [pmid: 7868706].
36 American Physicatric Association. Diagnostic and statistical manual for mental disorders IV- text revised. Washington, DC: American Psychiatric Association;2000.
37 Hjalmas K, Arnold T, Bower W, et al. Nocturnal enuresis: an international evidence based management strategy. J Urol. 2004;171:2545-61. [pmid: 15118418].
38 Glazener CM, Evans JH. Simple behavioural and physical interventions for nocturnal enuresis in children. Cochrane Database Syst Rev 2004;(2):CD003637.
39 Glazener CM, Evans JH, Peto RE. Tricyclic and related drugs for nocturnal enuresis in children. Cochrane Database Syst Rev 2003;(3):CD002117.
40 Fishman L, Rappaport L, Cousineau D, et al. Early constipation and toilet training in children with encopresis. J Pediatr Gastroenterol Nutr. 2003;34(4):385-8. [pmid: 11930094].
41 Taubman B. Toilet training and toileting refusal for stool only: a prospective study. Pediatrics. 1997;99(1):54-8. [pmid: 8989338].
42 Taubman B, Buzby M. Overflow encopresis and stool toileting refusal during toilet training: a prospective study on the effect of therapeutic efficacy. J Pediatr. 1997;131(5):768-71. [pmid: 9403665].
43 Blum NJ, Taubman B, Osborne ML. Behavioral characteristics of children with stool toileting refusal. Pediatrics. 1997;99:50-3. [pmid: 8989337].
44 Taubman B, Blum NJ, Nemeth N. Stool toileting refusal: a prospective intervention targeting parental behavior. Arch Pediatr Adolesc Med. 2003;157(12):1193-6. [pmid: 14662573].
45 Schonwald A, Sherritt L, Stadtler A, et al. Factors associated with difficult toilet training. Pediatrics. 2004;113:1753-7. [pmid: 15173502].
46 Taubman B, Blum NJ, Nemeth N. Children who hide while defecating before they have completed toilet training. Arch Pediatr Adolesc Med. 2003;157:1190-2. [pmid: 14662572].
47 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52(6):377-84. [pmid: 9764259]. [pmcid: 1756728].
48 Jadad AR, Moore RA, Caroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
49 Schulz KR, Chalmers I, Hayes RJ, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-12. [pmid: 7823387].
50 Kaffman M. Toilet-training by multiple caretakers: enuresis among kibbutz children. Isr Ann Psychiatr Relat Discip. 1972;10(4):340-65.
51 SullivanBolyai S, Swanson M, Shurtleff DB. Toilet training the child with neurogenic impairment of bowel and bladder function. Issues Compr Pediatr Nurs. 1984;7(1):33-43. [pmid: 6370933].
52 van Kuyk EM, Brugman-Boezeman AT, Wissink-Essink M, et al. Defecation problems in children with Hirschsprung's disease: a prospective controlled study of a multidisciplinary behavioural treatment. Acta Paediatr. 2001;90(10):1153-9. [pmid: 11697427].
53 Hyams G, McCoull K, Smith PS, et al. Behavioural continence training in mental handicap: a 10-year follow-up study. J Intellect Disabil Res. 1992;36(Pt 6):551-8. [pmid: 1477492].
54 Candelora K. An evaluation of two approaches to toilet training normal children. Diss Abstr Int 1977;38(5-B).
55 Hundziak M, Maurer RA, Watson LS. Operant conditioning in toilet training severely mentally retarded boys. Am J Ment Defic. 1965;70(1):120-4. [pmid: 5830561].
56 Sadler OW, Merkert F. Evaluating the Foxx and Azrin toilet training procedure for retarded children in a day training center. Behav Ther. 1977;8(3):499-500.
57 Edgar CL, Kohler HF, Hardman S. A new method for toilet training developmentally disabled children. Percept Mot Skills. 1975;41(1):63-9. [pmid: 1101191].
58 Matson JL, Ollendick TH. Issues in toilet training normal children. Behav Ther. 1977;8(4):549-53.
59 Bakker E, Van Gool JD, Van Sprundel M, et al. Results of a questionnaire evaluating the effects of different methods of toilet training on achieving bladder control. BJU Int. 2002;90(4):456-61. [pmid: 12175408].
60 Smith PS. A comparison of different methods of toilet training the mentally handicapped. Behav Res Ther. 1979;17(1):33-43. [pmid: 109075].
61 Kimbrell DL, Luckey RE, Barbuto PF, et al. Operation dry pants: an intensive habit training program for severely and profoundly retarded. Ment Retard. 1967;5(2):32-6. [pmid: 6044014].
62 Tierney AJ. Toilet training. Nurs Times. 1973;69(51):1740-5. [pmid: 4778171].
63 Connolly JA. Behaviour modification: toilet-training procedures in a special care unit. Child Care Health Dev. 1976;2(5):267-72. [pmid: 991397].
64 Lancioni GE, Ceccarani PS. Teaching independent toileting within the normal daily program: two studies with profoundly retarded children. Behavior Research of Severe Developmental Disabilities. 1981;2(1):79-96.
65 Van Wagenen RK, Meyerson L, Kerr NJ, et al. Field trials of a new procedure for toilet training. J Exp Child Psychol. 1969;8(1):147-59. [pmid: 5804588].
66 Spencer RL, Temerlin MK, Trousdale WW. Some correlates of bowel control in the profoundly retarded. Am J Ment Defic. 1968;72(6):879-82. [pmid: 5654111].
67 Colwell CN, Richards E, McCarver RB, et al. Evaluation of self-help habit training of the profoundly retarded. Ment Retard. 1973;11(3):14-8. [pmid: 4786301].
68 Didden R, Sikkema SPE, Bosman ITM, et al. Use of a modified Azrin-Foxx toilet training procedure with individuals with Angelman-Syndrome. JARID. 2001;14(1):64-70.
69 Lancioni GE. Teaching independent toileting to profoundly retarded deaf-blind children. Behav Ther. 1980;11(2):234-44.
70 Smith PS, Smith LJ. Chronological age and social age as factors in intensive daytime toilet training of institutionalized mentally retarded individuals. J Behav Ther Exp Psychiatry. 1977;8(3):269-73.
71 Holverstott-Cockrell MK. Using measures of intervention integrity, intervention acceptability, and intervention effectiveness to evaluate a toilet training program in a preschool classroom for children with special needs. Coldwater (Mish): Western Michigan University;2002.
72 Mahoney K, Van Wagenen RK, Meyerson L. Toilet training of normal and retarded children. J Appl Behav Anal. 1971;4(3):173-81. [pmid: 16795293]. [pmcid: 1310689].
73 van Kuyk EM, Brugman-Boezeman AT, Wissink-Essink M, et al. Biopsychosocial treatment of defecation problems in children with anal atresia: a retrospective study. Pediatr Surg Int. 2000;16:317-21. [pmid: 10955553].
74 van Kuyk EM, Brugman-Boezeman AT, Wissink-Essink M, et al. Defecation problems in children with Hirschsprung's disease: a biopsychosocial approach. Pediatr Surg Int. 2000;16:312-6. [pmid: 10955552].
75 King JC, Currie DM, Wright E. Bowel training in spina bifida: importance of education, patient compliance, age, and anal reflexes. Arch Phys Med Rehabil. 1994;75(3):243-7. [pmid: 8129572].
76 Forsythe WI, Kinley JG. Bowel control of children with spina bifida. Dev Med Child Neurol. 1970;12(1):27-31. [pmid: 4907699].
77 Christophersen ER. The case for evidence-based toilet training. Arch Pediatr Adolesc Med. 2003;157(12):1153-4. [pmid: 14662563].
78 Bauer I. 2004. Diaper free! The gentle wisdom of natural infant hygiene. Salt Spring Island, Canada: Natural Wisdom Press.
79 Butler JF. The toilet training success of parents after reading toilet training in less than a day. Behav Ther. 1976;7(2):185-91.
80 Begg C, Cho M, Eastwood S, et al. Improving the quality of reporting of randomized controlled trials. The CONSORT statement. JAMA. 1996;276(8):637-9. [pmid: 8773637].