# Executive Summary

## Introduction

Toilet training is the mastery of skills necessary for urinating and defecating in a socially acceptable time and manner. In many cultures, parents regard the achievement of independent toileting as a significant accomplishment and a step toward self-sufficiency. Bladder and bowel function is regulated by complex muscles and may be modified by physiological, psychological, social, and cultural factors. Currently, an all-encompassing definition of “toilet trained” is lacking, and there are no strict criteria stating how long a child must be bladder or bowel continent, or what components of the toileting process a child must accomplish independently, in order to be considered “toilet trained.”

Over the last 100 years, recommended toilet training methods have oscillated between rigid programs and child-oriented ones. In 1962, Brazelton developed the “child readiness” approach, which focused on gradual training. This approach described parameters of child and parent toilet training readiness. The Azrin and Foxx method emerged in 1971 as a parent-oriented method that emphasized structured behavioral endpoint training aimed at eliciting a specific chain of independent events by teaching the component skills of toilet training. These two methods differ with respect to goal development, endpoints, and emphasis on the child's self-esteem. Other methods include variations of operant conditioning, assisted infant toilet training, and the Spock method. The toilet training methods are described in Appendix H *.

* Appendixes and Evidence Tables are provided electronically at http://www.ahrq.gov/clinic/tp/toilettrtp.htm.

Some factors believed to impact toilet training include sex, age at initiation, race, physical or mental handicaps, and constipation. While the majority of children are toilet trained without incident, approximately 2 to 3 percent experience an adverse outcome. Common adverse events are enuresis, encopresis, stool toileting refusal, stool withholding, and hiding while defecating. Toilet training children with special needs presents a unique set of challenges as impaired communication skills, reduced ability to process sensory information, and mobility and neurophysiological deficits add challenges to their toilet training.

Current published toilet training guidelines in North America recommend (1) a child-oriented approach, (2) not starting before 18 months because the child is not physically ready, and, (3) starting when the child displays interest.

## Objectives and Key Questions

The American Academy of Pediatrics put forth the following four questions:

1 What is the evidence for effectiveness of various toilet training methods to achieve bowel and bladder control?
2 What factors modify the effectiveness of toilet training, such as age, sex, race, ethnicity, culture, age at initiation, constipation, or stool toileting refusal?
3 What is the evidence for various toilet training methods as a risk factor for adverse outcomes, such as dysfunctional voiding, enuresis, encopresis, later problems, and psychological consequences?
4 What is the effectiveness of toilet training methods for achieving bowel and bladder control among patients with special needs?

## Methods

### Literature Search

Search terms were adapted for the following electronic databases: MEDLINE^®^, Ovid MEDLINE^®^ In-Process & Other Non-Indexed Citations, Ovid OLDMEDLINE^®^, Cochrane Central Register of Controlled Trials, EMBASE, CINAHL^®^, PsycINFO^®^, ERIC^®^, EBM Reviews, HealthSTAR, AMED, Web of Science^®^, Biological Abstracts, Sociological Abstracts, OCLC ProceedingsFirst, OCLC PapersFirst, Dissertation Abstracts, Index to Theses, NLM Gateway, and the National Research Register's Projects Database. Trials registers were searched and position statements were sought. In addition, annual conference proceedings were hand searched and the reference lists were reviewed. Only studies published in English were included.

### Study Selection

Each title and when available, abstract was independently screened by two reviewers and assessed for inclusion using a standardized form. References identified as “potentially relevant” and “unclear” were then screened by a pediatrician and a pediatric urologist. The full texts of potentially relevant articles were retrieved.

Using a priori inclusion criteria, two reviewers independently assessed the full text articles. Studies that examined the treatment of enuresis or encopresis were excluded; however, those that measured the development of enuresis or encopresis as the result of a specific toilet training method were included. Disagreement among reviewers was resolved by discussion and consulting a third party as needed.

### Quality Assessment

Two reviewers independently assessed the methodological quality. The quality of observational cohort studies was assessed using Downs and Black's partially validated “Checklist of the assessment of methodological quality of both randomized and non-randomized studies of health care interventions.” The Jadad Scale and allocation concealment were used to assess the methodological quality of randomized and non-randomized controlled clinical trials.

### Data Extraction

Data were extracted by one reviewer and checked for accuracy and completeness by a second. Data describing study design, toilet training objective (bladder vs. bowel; daytime vs. nighttime; self-directed vs. assisted), patient demographics, source of the study population, toilet training interventions and associated details, and outcomes were extracted. All outcomes reporting change in bladder and bowel function, number of successes and accidents, success and failure rates, time to toilet train, and the occurrence of adverse events were extracted. Whenever possible, information was extracted pertaining to effect modifiers.

### Data Analysis

Due to extreme clinical heterogeneity in study designs, interventions, populations, and outcomes, no statistical meta-analysis was performed. Studies were organized by population (healthy, mentally challenged, or physically challenged) and the toilet training programs were categorized as Azrin and Foxx, child-oriented, operant conditioning, or other. In a few instances Fisher's exact test was used to compute a p-value to compare dichotomous data between two groups.

## Results

### Direct Comparisons

There were three randomized trials involving healthy children; none compared the child-oriented approach to the Azrin and Foxx method. In healthy children the Azrin and Foxx method performed better than the Spock method (trained without force) for both day and night toilet training. Negative term avoidance using the child-oriented method significantly reduced the time of stool toileting refusal and time to toilet training compared to the child-oriented method alone.

In mentally challenged children, individual training was more effective than group methods for toilet training, although neither appeared to have long term effectiveness. Relaxation showed some effectiveness in reducing accidents over standard methods. An operant conditioning method was also found to be superior to both conventional and control groups in achieving urination and defecation in the toilet. The Azrin and Foxx method showed significant reductions in dampened pants compared to no training. Behavior modification methods improved toilet training habits over no training.

A multi-disciplinary behavior treatment was found effective in improving toileting habits of children with Hirschsprung's disease and anal atresia.

### Single Cohort

Healthy children. In Taubman's 1997 study, 482 children from middle- and upper-class families were toilet trained using a child-oriented approach. Twenty-two percent experienced at least one month of stool toileting refusal (STR) and 13 percent developed stool withholding during training. Twenty-nine children required an intervention. In a second study, Brazelton described toilet training results of 1170 children from upper-middle class families over ten years. All used a child-oriented approach beginning at approximately 18 months of age. Daytime continence for all was achieved by a mean age of 28.5 months and nighttime continence by 33.3 months. By five years of age, 16 children suffered from at least one of the following problems: enuresis (12), soiling in stressful situations (4), and chronic constipation (8). Kaffman examined children living in kibbutzim in Israel who were trained using an individualized child-oriented program. The prevalence of enuresis at 3.5 years was 13.9 percent (192/1376).

Foxx and Azrin identified 34 children from the community who passed a readiness test. Post training, bladder and bowel accidents were reduced by 97 percent and success was maintained at four-month follow-up. A second study examined 49 children who were trained using Azrin and Foxx's Toilet Training in Less than a Day (TTLD) program. Ten children failed to achieve continence within the intensive training session because of the child's severe emotional reaction or the parents quitting the program. In both studies children were trained in approximately 4.5 hours.

Mentally handicapped children. Didden used the Azrin and Fox method in an attempt to achieve prompted bowel or bladder control in six children with Angelman Syndrome. The average frequency of correct daily toileting increased from 0.8 to 3.5 at post-treatment and to 3.1 at 2.5 years follow-up. Lancioni trained nine profoundly deaf and blind children who had never shown any signs of self-initiated toileting. The training program included positive reinforcement and punishment. At day 44, eight of the nine children exhibited self-initiated toileting. Smith retrospectively examined 13 mentally retarded children trained using the Azrin and Foxx method and a urinary training device. Frequency of wetting declined from 50 percent to 10 percent by week 5 and this result was sustained at follow-up. In the final study of nine mentally handicapped children, the Azrin and Foxx method was augmented with daily reading of a toilet training book. The number of successes increased. There was poor compliance to the book and it was deemed unnecessary.

Five studies examined variants of operant conditioning programs. Van Wagenen used a forward-moving series of actions and urine alarms to successfully train nine mentally handicapped children. Ando used operant conditioning to toilet train five institutionalized autistic boys. The program involved positive reinforcement and punishment. Four children improved self-initiating toileting, while the remaining child did not respond to any reinforcers. Giles attempted to toilet train five severely and profoundly mentally retarded children using positive reinforcement and, if it did not produce continence, punishment was used. All five were successfully toilet trained in 8 weeks. Spencer attempted to establish bowel control in 38 severely and profoundly retarded boys using a six-week program consisting of positive reinforcement for sitting on the toilet and defecating in the toilet. Spontaneous toileting increased by 9 percent and accidents decreased by 17 percent. Using operant conditioning, Colwell attempted to bring toileting behaviors under verbal control in 47 profoundly and severely mentally retarded children. Of this group, 33 children improved in skill, 3 worsened, and the remaining 8 experienced no change.

Physically handicapped children. Van Kuyk retrospectively assessed a multidisciplinary program for 43 children with anal atresia and for 16 with Hirschsprung's disease. The program aimed to teach adequate defecation behavior by reducing fear and anxiety, using the lower body to improve straining techniques, and adopting a regular schedule. There was a significant improvement in the Templeton continence score in children with anal atresia (from 2.2 ± 0.45 to 1.6 ± 0.59) and significantly fewer children suffered from constipation (18 vs 8). The 16 boys with Hirschsprung's disease also had a significant improvement in Templeton score (from 2.7 ± 0.48 to 1.1 ± 0.34 at post treatment) and there were fewer constipated boys.

Three studies developed toilet training programs for establishing bowel control in children with spina bifida. King aimed to establish neurogenic bowel habituation in 35 patients. In children ≤6 years old, continence improved from 0 (0/17) to 65 percent (11/17) and it improved further to 88 percent (8/9) among children who completed the program. Forsythe created a similar stepwise program for 47 children. A combination of regular toileting, initial enemas, and laxatives was the most effective. Sullivan-Bolyai evaluated a component-based toilet training program in 525 children with spina bifida. Of 184 children >4 years of age, 141 were socially acceptably trained using suppositories, expansion enemas or timed evacuations. Regardless of age, 44 children failed to achieve bowel control. Forty-six children <6 years of age achieved socially acceptable bladder control mainly with diaper or pants inserts, and clean intermittent catheterization. Of 158 children >6 years of age, 107 achieved socially acceptable bladder control, primarily by ileal diversion and clean intermittent catheterization. In both age groups, 62 children did not achieve socially acceptable bladder control.

Adverse outcomes. Only four studies specifically addressed adverse outcomes. In a case-control study among school aged children, Bakker found that those who were trained at a later age (>18 months) and by more aggressive training methods had more lower urinary tract symptoms. Kaffman reported the frequency of enuresis in 6 and 7 year-old children trained by multiple caregivers on a kibbutz to be higher than non-kibbutz raised children, but lower after 10 years of age. Taubman reported an incidence of roughly 22 percent for stool toileting refusal, 53 percent for stool withholding, and 69 percent for hiding to defecate that occurred during the training process; this was associated with the presence of younger siblings, parental difficulty in setting limits, and late (>42 months) training. In contrast, Brazelton 1962 reported a 1.4 percent incidence of residual problems >5 years of age following a child-oriented training approach. None of the Azrin and Foxx studies reported these outcomes.

## Discussion

### Effectiveness of Toilet Training

In general, both the child-oriented and Azrin and Foxx approaches seem able to teach toilet training to healthy children. The regimented Azrin and Foxx approach seems to result in rapid success rates at relatively young ages and results are maintained.

Based on single-arm studies, mentally handicapped children had some degree of success regardless of the toilet training method. A limited number of studies was identified with most published from 1966 to 1981. Since then, the definition of mental handicap has been revised; therefore, some of the children classified as mentally handicapped in the older studies may not meet the current definition.

One of the key questions asked to identify toilet training strategies and/or outcomes of children with behavior problems. Unfortunately no studies were identified. Children with complex medical conditions should not be expected to toilet train as healthy children, and no studies evaluating standard methods among physically handicapped children were located. The results of cohort studies confirmed that children with Hirschprung's disease or anal atresia could achieve continence with a multidisciplinary approach. Due to spinal cord neurologic impairment, children with spina bifida can suffer from constipation and/or fecal incontinence as well as urinary symptoms such as failure to empty or incontinence. The primary means to control elimination problems are timed evacuation via clean intermittent catheterization, stool softeners, suppositories, and enemas.

### Potential Limitations

The main limitation is the lack of research conducted and reported in the area of toilet training and the heterogeneity among the populations studied, the toilet training programs evaluated, and the definitions of success. As a consequence of this heterogeneity, the pooling of results was not possible. Additional limitations include analyses conducted in the primary studies, several of which did not perform a statistical analysis of their data. Finally, a descriptive analysis has several limitations and leaves the clinical reader with less information to guide future actions.

### Future Research Opportunities

Given the findings of this systematic review, the following research priorities are recommended:

- Standardize definitions of “toilet trained,” “success,” and “failure” and adapt them to cultural differences when appropriate.
- Conduct trials that directly compare two toilet training methods, such as Azrin and Foxx and the child-oriented approach, within the same population.
- Accurately describe the populations in terms of mental and/or physical challenges, using current diagnostic standards.
- Conduct toilet training programs with children suffering from behavioral disorders such as attention-deficit disorder and oppositional defiant disorder.
- Determine if toilet training is affected by age, sex, race, culture, etc.
- Document adverse outcomes.

### Conclusions

There is a lack of high-quality research to guide clinicians in advising parents and guardians on how to toilet train their children. Based on the evidence, the following conclusions can be made:

- The strategies appear similar among healthy children, thus caregivers and health care providers can try any of the methods.
- Some mentally handicapped children can attain at least partial success with toilet training.
- Given the range of functionality among mentally handicapped children and the potential for concurrent physical and behavior problems, toilet training programs may need to be flexible.
- Toilet training physically handicapped children is enhanced by a multidisciplinary team.
- Elimination problems should be treated early to encourage normal psychosocial development.