# Acknowledgments

We thank the members of the technical expert panel for providing scope and direction for the contents of the review and the peer reviewers for providing invaluable input on the draft report. The names of these individuals are listed in Appendix F (available on the AHRQ Web site at http://www.ahrq.gov/clinic/tp/toilettrtp.htm). We are grateful to the following people for their efforts:

- Liza Bialy for implementing the quality assessment and data extraction forms within the online SRS system and for assisting with quality assessment.
- Nicola Hooton for verifying the extracted data.
- Donna Dryden for editing and providing feedback on the draft of this report.
- Lisa Malinowski and Kenneth Moreau for collecting potentially relevant studies.