# Discussion

In many cultures, including North America, parents regard a child achieving independent toileting skills as a significant accomplishment. It is one of the first steps in becoming self-sufficient; caregivers no longer need to spend time or energy on diaper changes and there are financial savings in diaper costs. As such, successful toilet training is an adaptive skill that caregivers expect their healthy child will achieve. However, the toilet training process can cause some anxiety for caregivers, particularly among parents with children who have significant physical, mental, or behavior problems. Achieving independent toileting requires that a child have a combination of skills in language, motor, sensory, neurological, and social domains. For the child with a significant impairment in one or more of these, successful toileting can be problematic.

This review summarizes the scientific evidence relating to the effectiveness of defined methods used to toilet train children to achieve bowel and bladder control. In addition to overall effectiveness, the review looked at evidence to support or refute proposed factors that might modify the effectiveness of toilet training (e.g. age, sex, race/ethnicity, culture, age at initiation), and to assess if some toilet training methods pose a risk for developing adverse outcomes such as dysfunctional voiding, enuresis, or encopresis. This review sought to determine the optimal toilet training methods for healthy children and those with mental, physical or behavioral problems.

An extensive search for trials was conducted in databases from education, psychology, social sciences, and health sciences. We searched for meeting abstracts, theses, and dissertations; we searched for position papers from professional pediatric societies and conference proceedings. Only eight RCTs were identified; all compared different versions of the same method. The remaining 26 included studies were retrospective and prospective cohort studies; only 3 had a comparison group and all were children receiving usual care. For these reasons, we were not able to conduct a meta-analysis and the results are presented qualitatively. Notwithstanding, some valuable general information does arise from this review in the form of a descriptive analysis.

Three primary toilet training methods were identified and examined for training healthy and mentally handicapped children: Azrin and Foxx, operant conditioning, and a child-oriented approach. The interventions used to train some children, particularly those with physical handicaps, were specifically designed to work with their particular problems and abilities; we categorized these as “other” methods.

## Toilet Training Healthy Children

Toilet training for healthy children is not a subject that invokes passion among researchers; however, parents and pediatricians struggle with this seemingly minor problem on a daily basis. Pediatricians faced with the task of providing evidence-based advice have difficulty finding the literature to support the various approaches.^77^

Most parents want to know the quickest, easiest approach to toilet training that does not result in adverse outcomes. Parents are inundated with media and lay information on various methods from the child oriented approach to the extreme and time intensive method of elimination communication where an infant may be diaperless from birth.^78^ Despite this method's growing popularity in North America, we did not identify any studies that examined the elimination communication toilet training method. A method similar to this idea was used among the Digo people of East Africa; however, the article did not report any quantitative results and thus failed to meet our inclusion criteria. The author did state that toilet training success was achieved by infants 4 to 6 months old.^5^

In this review, we identified three randomized trials looking at toilet training methods in healthy children.^44^ ^54^ ^58^ Unfortunately, there were no head-to-head comparisons between the child-oriented approach^8^ and the Azrin and Foxx method^9^ and this prevented us from drawing definitive conclusions regarding one method's superiority over the other. The rather regimented Azrin and Foxx approach appeared to result in rapid success, Matson reported 50 percent success with 10 toddlers aged 20 to 26 months after 5 four-hour sessions. At the 10 week follow-up, one child had regressed to diapers due to parental problems.^58^ Candelora found Azrin and Foxx to be superior at reducing accidents, increasing successes, and reducing the number of wet mornings than the Spock method.^54^ In the one large study examining the child-oriented approach, the positive approach to bowel habits and avoidance of negative terminology in reference to defecation improved the time to fecal continence by 3 months; however, this may not be clinically significant.^44^ These children were completely toilet trained at a much later age (3.5 ± 0.5 years) in comparison to those by the Azrin and Foxx method.

While single-cohort studies are a lower level of evidence, they do provide insight into outcomes, particularly when there is limited higher-level evidence available. The two cohort studies examining the effectiveness of the Azrin and Foxx method concurred with the Matson trial.^9^ ^79^ Children seem to attain continence quickly, with a relatively high success rate and at a relatively early age. Following one day of training, Butler reported 74 percent success in 34 toddlers under 25 months and 93 percent success in 15 older toddlers; Foxx reported 100 percent success in 34 toddlers ranging from 20–36 months. Success at follow-up was 96 percent and 97 percent respectively. One of the larger studies was a prospective cohort of children who trained using the child-oriented approach.^41^ With this approach, 61 percent (292/482) were continent by the age of 3 years and 98 percent were continent by 4 years of age. The study does not state how long it took to achieve continence.

Unfortunately there is insufficient evidence to provide conclusive answers regarding the optimal toilet training method. Overall, we found that in the small studies evaluating the Azrin and Foxx method, success is relatively high and achieved soon after training. Follow-up at 1 to 4 months indicated success was maintained. Successes were also seen in the child-oriented approach, but they generally did not occur as quickly as those displayed by the Azrin and Foxx method. Brazelton's retrospective study reported that 94 percent of parents (1105/1170) started toilet training between 12 to 24 months and that 26 percent (304/1170) had completed day time training by 24 months.^8^ In general, both toilet training programs seem to have the ability to teach toilet training in healthy children. It appears from the literature that parents who want quick results should consider the Azrin and Foxx method of toilet training but must be prepared for a regimented approach and should use positive reinforcement. For parents who are not prepared to put as much focus into attaining continence, the child-oriented approach can be successful but may take somewhat longer. Until we have additional studies that compare the toilet training methods, it appears safe to tailor the approaches in healthy children to individual families. This recommendation is in keeping with Brazelton's review article.^3^

## Toilet Training Mentally Handicapped Children

Many caregivers of mentally handicapped children want to know if the child will ever attain independent, successful toileting, and if so, what toilet training methods exist to facilitate this process. Our search strategy identified a limited number of comparative and single-arm studies. Many of them were from the 1960s and 1970s and the definition of mental retardation has undergone several revisions, mainly that the lower IQ limit decreased from 85 to 70. As such, some of the children who were classified as mentally retarded in these older studies may not meet the current definition.

One of the key questions was to identify toilet training strategies and/or outcomes of children with behavior problems. Unfortunately, no studies involving this population were identified. Some children with mental retardation can have behavior co-morbidities; however, in studies of mixed populations, results were not specified by the diagnoses. A small (n=5) prospective cohort of children with autism and mental retardation had some success with an operant conditioning method and toilet training was more successful in children with receptive language skills.^33^ Another small (n=9) study in autistic mentally retarded children found that improved access to a potty could assist in toilet training.^64^ Children who were mentally retarded secondary to Angelman syndrome had partial success in toileting using a modified Azrin and Foxx method.^68^ Although this study did not specify the behavior problem(s), Angelman syndrome is often associated with hyperactivity and characteristic bouts of laughter. Given that many children who are otherwise healthy but have significant behavior problems, including but not exclusive to attention-deficit disorder and oppositional defiant disorder, future studies should be designed to examine toileting strategies and outcomes in these children.

Based on single-arm studies, mentally handicapped children had some degree of success regardless of the toilet-training method used. From the comparative studies, the Azrin and Foxx method, operant conditioning, and relaxation techniques were all superior to not using a toilet training method. Unfortunately, none of the studies did a head-to-head comparison between the different toilet training methods. Furthermore, the child-oriented method was not used in any of the studies on mentally handicapped children.

Even though studies are few and have small sample size, the evidence suggests that some mentally retarded children can attain at least partial success with toilet training. At present all of the strategies seem equivocal, thus caregivers and health care providers can try any of the methods. Success may be optimized among those with receptive language skills and easy access to a toilet.

Given there is a broad spectrum of function in mentally retarded children, often confounded by physical and behavior problems, caregivers and health care providers may need to be flexible when developing toilet training strategies.

## Toilet Training Physically Handicapped Children

Children with physical handicaps face difficulties with bowel and bladder control related to the physiology and psychology of their conditions. In many conditions, such as Hirschsprung's disease and other congenital anal anomalies (e.g. anal atresia and spina bifida), children may not have the abilities to develop control with standard toilet training methods. We included this patient population into this systematic review in an effort to develop insight into toilet training this particular group of children.

We did not find any studies that evaluated the child-oriented approach or the Azrin and Foxx method in children with physical disabilities. In the one prospective controlled trial 27 children with Hirschsprung's disease were successful with a multidisciplinary (Evidence Table D-6) approach to toilet training.^52^ While this was only one small study with only 9 months of follow-up, it is clear that for children with complicated medical conditions, this approach is favored. Not only are results generally better, but also families tend to be more satisfied with their care.

The multidisciplinary approach to bowel control was also assessed in two retrospective cohort studies of children with anal atresia and Hirschsprung's.^73^ ^74^ The results confirmed those of the trial and the belief among most specialists was that children with complex conditions required the expertise of many specialists in a interdisciplinary fashion. Children with spina bifida present with different elimination problems due to varying degrees of neurologic impairment at different spinal cord levels. With regard to the bowel, they can suffer from constipation and/or fecal incontinence. Urinary symptoms can include failure to empty as well as incontinence. Standard methods for toilet training rarely work in this patient population. The primary means to control these problems are timed evacuation as described in the three cohort studies.^51^ ^75^ ^76^ With timed elimination via clean intermittent catheterization, stool softeners, suppositories and enemas, children have the ability to become continent. The long-term success varied and few children were able to remain continent without some sort of medical intervention. Families of children with complex medical conditions should not expect their children to toilet train as per healthy children; however, there are many options to gain continence. Parents should be made aware of the difficulties and the potential solutions in order to avoid unreasonable expectations. Identifying support groups for families is often helpful in order to expose them to the unique solutions used by other children with complex medical conditions.

## Modifying Factors that May Affect Toilet Training

While there were no studies that looked specifically at modifying factors, some common themes were found among the studies. Candelora found that certain parental variables improved outcomes, such as having older and more tolerant mothers, and higher socioeconomic status.^54^ Butler and Taubman's studies revealed quicker training in girls than boys.^41^ ^79^ On the other hand, Brazelton did not report a difference in attaining daytime continence between sexes but did observe a quicker attainment of nighttime continence in girls.^8^ ^44^ Taubman et al. also revealed an association between the presence of younger siblings and a higher incidence of stool toileting refusal.^44^ While race and culture were not evaluated in these studies, they may play a role in expectations, choices of interventions, and accepted norms.

## Adverse Outcomes Associated with Toilet Training

Only four studies specifically addressed the topic of adverse outcomes: two addressed bladder problems retrospectively,^50^ ^59^ one examined bowel problems prospectively,^41^ and one reported unspecified residual problems also prospectively.^8^ Regarding long term bladder control, one cohort^59^ determined that school age children with lower urinary tract symptoms (21 percent of the sample) were trained at a later age (>18 months) and that their parents had used more aggressive methods to provoke voiding (e.g. ran water, asked to push); however, no specific training methods were compared and data were collected via a questionnaire when the children were approximately ten years of age. The second study reported the frequency of enuresis in those that had been trained by multiple caregivers on a kibbutz; training began between 15 and 24 months.^50^ At six to seven years of age, they had a higher incidence of enuresis than non-kibbutz raised children, but a lower incidence after age ten. On the topic of prolonged bowel incontinence the one prospective RCT reported an incidence of approximately 22 percent for stool toileting refusal.^41^ These problems were associated with the presence of younger siblings, parental difficulty in setting limits, and training at a later age; however, “later” was defined as children >42 months as compared to 18 months, which was used by Bakker^59^. These children were trained in a child-oriented fashion. In contrast, Brazelton reported a 1.4 percent incidence of residual problems at >5 years of age following a child-oriented training approach.^8^ None of the operant conditioning or Azrin and Foxx studies reported these outcomes. The only other adverse effects mentioned in these studies were temper tantrums and child and parental refusals and frustration with the training method itself.

## Limitations

There are a variety of limitations associated with this review, including bias, variation in study definitions, weak study design, variability in the toilet training programs, and lack of statistical analysis. Also, the majority of the studies were conducted between the 1960s to the 1980s.

As with all systematic reviews, there is a possibility of publication and selection bias. To reduce publication bias, an experienced medical librarian conducted a comprehensive search of the published literature for potentially relevant studies using a systematic strategy. This was augmented with hand searching of reference lists and conference proceedings and tracking forward sentinel articles. Overall, toilet training was a well-indexed subject and we are confident that the search located all the major literature on this topic. Despite these efforts, we recognize that unpublished negative studies may have been missed. Although the search was conducted without language restrictions, in the end the review was restricted to English articles due to difficulties in obtaining complete, accurate translations in more than ten non-English languages. It is likely that approximately three additional foreign studies might have been included. Selection bias was controlled by having two reviewers apply a priori inclusion criteria independently then resolve all discrepancies with a third party who had clinical expertise. We feel confident that the studies excluded were done so for consistent and appropriate reasons.

Prior to determining effectiveness, it is necessary to have a clear, specific, and measurable definition of the end result. In the case of toilet training, there is no all-encompassing definition and each of the included studies varied in their definition of success. The populations studied in this review displayed great heterogeneity; healthy children and those with special needs involving either mental or physical handicaps are included. As a result, the definition of success had to be modified. For some it meant total and lasting self-directed independent toileting, including recognizing elimination urges, going to a toilet, handling clothing, assuming proper positioning, attending to sanitation, and returning to activities without notifying anyone; other definitions were less inclusive regarding which aspects of the process must be complete and for how long before success was accorded. In institutionalized populations, improvement in frequency of toileting successes and reduced accidents resulting in less laundry and less staff time spent toileting and cleaning was reward enough for implementing a program although some participants did achieve independent toilet skills. For those with neurophysiological handicaps, attaining social acceptability, independently or not, and sometimes not until late teen years was the goal. Some of the populations had been subjected to previous unsuccessful attempts to toilet train; others were attempting training for the first time. These variations in populations, definitions of success and failure, and reported outcomes proved too disparate to permit pooling of results.

A second limitation of this review is the weakness of the study design that the majority of the studies used. There were only eight RCTs. Among the other studies comparing two or more toilet training programs, the majority of the interventions were non-randomized and the rationale for the intervention decision was largely unknown. The quality of included studies varied and was generally low. All RCTs received a low methodological score (1 or 2 of a possible 5 points); the only reported details were that group assignment was random (with the exception of one study) and withdrawals and dropouts were accounted for. How the randomization code was derived, concealed, and applied is unknown and the nature of intervention does not lend itself to double blinding. The cohort studies scored a mean of 16.9 ± 3.1 of a possible 29 (range 11–22). However, it should be noted that 70 percent of the studies were published before the CONSORT guidelines were introduced to improve reporting requirements particularly for RCTs; therefore, it is unclear if the poor reported methodological quality is a reflection of reporting omissions or true methodological quality.^80^ Some of the prospective cohort studies that were dependent on observer evaluation made an effort to have two observers and calculated agreement to improve accuracy.

A third limitation is imposed by the variability in the programs themselves. The most studied intervention was the Azrin and Foxx method and this was assessed in nine studies; however, there was significant variation in which aspects were incorporated, who did the training, and the extent of training the trainers received prior to implementing the program. Four were conducted on healthy children (2 RCTs, 2 prospective cohorts). Three of these studies used the Toilet Training in Less Than a Day Program (TTLD); two involved parents (some pre-trained, some not, some supervised, some not) training the children at home; the other used qualified trainers who conducted the training in a separate facility. The toilet training success rate was lower when the child was trained by parents versus the qualified trainer: 50 and 78 percent compared to 100 percent. Parents reported a high incidence of negative emotional reactions to the procedure while the trainers reported that most children responded as if it were a very pleasant experience. Candelora reported the TTLD program was superior to Dr. Spock's recommendations.^54^ The Azrin and Foxx method was used in five studies involving mentally handicapped children (one RCT, three prospective and one retrospective cohort); two used potty and pant alerts (success rates 60 and 89 percent), three did not (success rates 60 percent, 100 percent and significant improvement in successes). All studies modified the method to suit the particular population or staff availability and costs. Because of the heterogeneity in design, populations, implementation, the definitions of success, and outcomes reported, data results could not be pooled. In general, though, it can be said that the Azrin and Foxx method produced many more successes than failures with both healthy and mentally handicapped children.

The toilet training programs and populations were diverse and were assessed using a variety of study designs. A child-oriented toilet training method was used in four studies (1 RCT, 3 single cohort: 1 prospective, 2 retrospective) all involving healthy developing children. Parents were the sole trainers in three of the studies and were part of a multiple caregiver approach on a kibbutz in the other. Only one reported a training success rate (98 percent by age 4 yr). The other studies were investigating on-going bowel and bladder incontinence but training success can be assumed to be 80 percent without problems (generally by 3.5 yrs of age).^8^

An operant conditioning method was investigated in twelve studies (2 RCTs, 9 cohort: 5 single, 5 with a control group). All were prospective, eleven involved mentally handicapped populations, (one study used three healthy children as comparison group) and one was conducted among children with a physical handicap. Two investigators looked at the use of auditory signals to train children. Three of the healthy children were successful and four of nine mentally handicapped children achieved criterion success levels. Two programs involving ten children administered negative consequences for incontinent episodes in addition to positive reinforcement for appropriate actions. Five subjects achieved consistent self-initiated control, four improved between 18 to 60 percent and one did not respond. The remaining eight studies reported only positive reinforcement procedures were employed. Though results are reported in various ways and cannot be combined, they all indicated that operant conditioning interventions yielded improvements over control groups—toileting scores increased, wetting/soiling accidents decreased, laundry requirements decreased, and Templeton/Wingspread/constipation scores improved.

A fourth limitation lies in the fact that several of the studies did not perform a statistical analysis of their own data and only reported results in a descriptive fashion. A descriptive analysis has several limitations and provides the clinical reader with less information to guide future actions. This review provides a table describing the population, each intervention and a range of outcomes depicting success/partial success/and failure rates along with the authors' conclusions. A handful of studies address negative consequences of a program, thus leaving this topic largely unexplored. It allows the reader to draw their own conclusions but fails to answer specific clinical questions. Without a pooled statistical analysis it is difficult to draw conclusions that can be generalized to similar populations in the clinical setting. While we have made limited progress in determining whether one toilet training program is more effective than another, we do know that all programs elicited a measure of success and that the majority of children achieved a higher level of, if not complete, continence.

## Future Research Opportunities

To date, toilet training research is hampered by heterogeneity and methodological flaws. The first step to improving the state of toilet training research is to standardize definitions related to toilet training, such as “toilet trained,” “successes,” and “failures.” Second, studies with larger sample sizes should be undertaken. Because almost all children are toilet trained, there is potential for large-scale research.

Given the findings of this systematic review, the following future research priorities are recommended:

- Definitions of toilet training should be standardized and where appropriate, cultural definitions should be developed. The same principles of standardization should be applied to outcome measures.
- While toilet training interventions do not lend themselves to double-blind trials, the methodological quality of future trials could be enhanced by having blinded outcome assessors and concealing allocation.
- The child-oriented approach requires further evaluation and the effectiveness of the elimination communication method needs to be determined.
- Few studies examined factors that may affect or modify toilet training. Additional research is required to examine the effects of modifiers such as maternal age, parenting experience, child temperament, and match or miss-match of parent-child relationship on toilet training success.
- Studies that directly compare two toilet training methods, such as Azrin and Foxx to child-oriented approach, within the same population should be undertaken to determine the most effective toilet training program.
- In an attempt to reduce bias, future studies should be randomized controlled trials or large prospective cohort studies.
- Among the studies examining toilet training among mentally handicapped children, very few described the exact mental handicap. The applicability of the study results would be enhanced if there were increased details concerning the nature of the handicaps.
- Few studies examined adverse outcomes associated with the particular toilet training method. There is a need for long-term follow-up that measures the occurrence of adverse events, such as enuresis, encopresis, stool withholding, stool toileting refusal, and other psychological consequences.
- It has been hypothesized that toilet training is more challenging among children with behavioral disorders, such as autism and attention deficit disorder; however, there is a paucity of evidence examining toilet training in this specific group of children. Toilet training programs should be assessed in children suffering from behavioral disorders.

## Conclusions

Toilet training is an important milestone in pediatric development. There are several different toilet training methods; however, the individual programs have not been well researched. Few trials have examined the various toilet training programs and the existing trials tend to compare variations of the same program and not one toilet training method to another. A more popular study design among the toilet training literature is the single cohort: generally, a small group of children were toilet trained using the same method and continence was subsequently assessed. The individual studies were heterogeneous, as the children, toilet training interventions, measured outcomes, and definitions of ‘toilet trained’ were variable.

After a comprehensive search of electronic databases, conference proceedings, and reference lists of included articles, we identified 8 controlled trials and 26 observational studies that examined toilet training methods in healthy and handicapped children. Based on the evidence, the following conclusions can be made:

- The studies are heterogeneous and the methodological quality of the included studies is poor. For this reason, the results and conclusions should be interpreted cautiously.
- Both the Azrin and Foxx and child-oriented methods successfully toilet trained healthy children. However, although the effectiveness of variants of the child-oriented approach and Azrin-Foxx has been studied, the child-oriented approach has not been directly compared to the Azrin-Foxx method.
- No study evaluated the early communication method.
- Toilet training methods in children with behavioral or developmental handicaps were not well studied.
- There is some evidence that, among healthy children, the Azrin and Foxx method may train children sooner than the child-oriented approach but there was limited research to determine if the achieved continence was maintained. In addition, the two methods have not been directly compared to determine the time to achieving continence.
- Azrin and Foxx and operant conditioning toilet training programs were used to partially or completely toilet train mentally handicapped children.
- For children suffering from Hirschsprung's disease and anal atresia, a multidisciplinary approach to toilet training proved to be successful for achieving bowel continence.
- Timed evacuation also was successful for obtaining bowel control among children with physical handicaps.
- Few analyses have been conducted to identify effect modifiers; they were only assessed in studies that attempted to toilet train healthy children.
- There was mixed evidence regarding sex of the child and toilet training; two of the three studies concluded that girls trained earlier than boys, while the third study found that girls achieved nighttime continence before boys.
- Adverse outcomes were seldom assessed and only in the child-oriented approach. Later age of training (>42 months), younger siblings, and parents not being able to set limits for their child tended to be associated with adverse events.
- Later age of toilet training and aggressive toilet training methods were associated with subsequent urinary tract symptoms.