# Results

## Literature Search

Database specific search strategies were applied to the electronic databases and output generated 1476 unique citations. Five potentially relevant studies were identified by hand searching the conference proceedings from the Canadian Paediatric Society and American Academy of Pediatrics. In total, 1481 unique studies were reviewed and five were later determined to be duplicates. Study identification and selection is outlined in Figure 2.

Figure 2. Selection of Included Studies

Seven hundred and seventy-two studies were identified as being potentially relevant. Studies were then excluded for the following reasons: inappropriate study design (n=303), inappropriate intervention (n=237), foreign language (n=43), incorrect study population (n=43), or inadequate data or outcomes not reported (n=4) (Appendix E *).

* Appendixes and Evidence Tables are provided electronically at http://www.ahrq.gov/clinic/tp/toilettrtp.htm.

There were several instances where the same cohort children, or a portion of the same cohort, was included in more than one publication. In such cases, the most recent and complete study was chosen as the primary study and additional information was extracted from the related publications. A description of these multiple publications appears in Appendix C.

## Description of Included Studies

Thirty-five studies were included in this systematic review. There were three instances of multiple publications that examined toilet training within the same group of children.

Observational Studies. The median year of publication was 1976.5. Half of the studies were conducted in the United States (13/26; 50 percent), followed by the Netherlands (4/26; 15 percent). One study was conducted in Japan^33^, the only study occurring outside of the United States or Europe. The median sample size was 34.5; five studies included one hundred or more children.^1^ ^8^ ^41^ ^50^ ^51^

The included observational studies are described in Appendix D, Evidence Tables D-1, D-2, and D-3 *. Six of the 26 (23 percent) included studies that examined healthy children. Fifty percent (13/26) of the studies assessed toilet training methods in children with mental handicaps and 5 of the 26 studies examined physically handicapped children. Thirteen of 20 studies stated the children's specific handicap. Three studies included autistic children and two studies examined children with spina bifida. Two studies included mixed populations: one was a combination of healthy and mentally handicapped children and the other was a combination of mentally and physically handicapped children. Children were most commonly recruited from special care facilities (13/26; 50 percent), followed by clinical practice (7/26; 27 percent), community (2/26; 8 percent), school (2/26; 8 percent), and community and clinical practice (1/26; 4 percent). One study did not report the source of the children.

The goals of the specific toilet training programs were summarized as self-directed daytime bladder control (5/26; 19 percent), daytime bowel and bladder control (4/26; 15 percent), daytime and nighttime bladder control (2/26; 8 percent), daytime and nighttime bowel control, prompted bladder and bowel control anytime (2/26; 18 percent), and self-directed daytime bladder and bowel control (2/26; 8 percent). The remaining studies examined a variation of daytime versus nighttime, self-directed or promoted, bladder or bowel control. Twenty of the included studies examined one toilet training program and the remaining six studies assessed two programs, for a total of 32 programs. The most common toilet training program was operant conditioning (8/32; 25 percent) and Azrin and Foxx (5/32; 16 percent). Child-oriented toilet training was assessed in three studies. The remaining studies examined ‘other’ toilet training programs, which often included components of reinforcement and increasing liquids.

The outcomes were heterogeneous. The primary outcome in 23 of the 26 (88 percent) studies measured success or failure of toilet training; however, ‘success’ had variable definitions, such as bladder and/or bowel continence, self-toileting, directed toileting, lack of accidents, etc. The outcomes assessed in the remaining three studies were lower urinary tract symptoms, enuresis, and stool toileting refusal.

Trials. In this review, there were 13 trials that examined eight unique cohorts of children (Appendix D Evidence Table D-4, D-5, and D-6). The median year of publication was 1977 and only three of the eight (38 percent) trials were conducted after 1991^44^ ^52^ ^53^. Six trials were conducted in the United States (75 percent) and one of each in the United Kingdom (13 percent)53 and Netherlands (13 percent)^52^. The median sample size was 22.5 children; two trials included more than 50 children (25 percent).^44^ ^54^ All eight trials employed a parallel arm study design. Three trials had three arms (38 percent)^53^ ^55^ ^56^; the five remaining trials were two-armed.

The included populations were heterogeneous. Three of the trials included healthy children (38 percent), four included children with a mental handicap (50 percent); and one trial included children with Hirschsprung's disease (13 percent). All of the mentally handicapped children were recruited from a special care facility. Taubman et al. enrolled children from their clinical practice, while the remaining studies recruited children from the community.

The included trials had a range of toilet training objectives: mastery of daytime and nighttime bladder control (2/8; 25 percent), daytime bladder control (2/8; 25 percent), and self-directed daytime bladder control (2/8; 25 percent), self-directed and prompted daytime bladder control (1/8;l 13 percent), and self-directed daytime bladder and bowel control (1/8; 13 percent). The toilet training methods were diverse. Azrin and Foxx was the most common method and it was examined in at least one arm of four of the trials. In two trials, variations of the Azrin and Foxx method were compared to one another. The remaining trials used other toilet training methods, such as Spock's baby book^54^, relaxation-tension exercise regimen^57^, operant conditioning^55^, praising defecation^44^, and a biopsychosocial approach aimed to reduce defecation associated anxiety and stool avoidance. Two trials contained a control group that was comprised of no toilet trainng method (2/8; 25 percent).^55^ ^56^

Seven of the included eight studies measured a variation of toileting accidents or successes, such as the frequency or number of accidents/successes or proper use of the toilet. One study measured the development of stool toileting refusal.^44^

## Methodological Quality of Included Studies

Observational Studies. The mean Downs and Black score of the 26 included observational studies was 17.2 (SD 2.8) of a maximum possible score of 29. The mean scores of the individual components of the quality tool are presented in Table 4 and additional details are reported in Appendix D Evidence Table D-7 *.

Table 4 Summary of components of Downs and Black Score

| Reporting | External Validity | Bias | Confounding | Power | Overall
Maximum Score | 11 | 3 | 7 | 6 | 2 | 29
Mean Score (SD)* | 8.1 (1.3) | 1.3 (1.1) | 4.2 (0.8) | 3.0 (1.0) | 0.5 (0.5) | 17.2 (2.8)

* SD indicates standard deviation

The majority of the studies collected data prospectively (14/26; 54 percent). Seven studies (27 percent) reported their funding source: government agency (1/26; 4 percent), private industry (1/26; 4 percent), foundation (1/26; 4 percent), combination of government and foundation (1/26; 4 percent), or other (3/26; 12 percent).

Trials. The methodological quality among the included studies was very similar. With the exception of one trial^52^, all of the trials scored two on the Jadad scale. The two points were earned for stating the trial was randomized and adequately describing the children who withdrew or dropped out from the trial. Van Kuyk (2001) was a clinical controlled trial, but not randomized and scored 1 on the Jadad scale.^52^ All trials failed to describe the method used to conceal allocation. Four of the trials were funded by government organizations (50 percent) and one received funding from an internal source (13 percent); the remaining three trials did not comment on funding source (38 percent). Appendix D Evidence Table D-8 provides additional information about the methodological quality of the included trials.

## Toilet Training Success

Toilet training successes are displayed pictorially in Figures 2 to 4. The arms of all the studies reporting success rates are presented by the type of toilet training method, study design, and healthy versus handicapped child. Because the studies are heterogeneous with respect to toilet training definitions, type of children (even within the broad categories of healthy, physically and mentally handicapped), and intervention (even within the categorizations) these comparisons are meant only for broad illustrative purposes and can not be used to compare the toilet training methods to one another. In addition, the findings of the individual studies are described in Appendix D Evidence Table D-9 and D-10 *.

Figure 4. Reported success of toilet training among mentally handicapped children

The size of the shape is proportional to sample size.

Square=RCT, circle=prospective cohort, triangle=retrospective cohort.

Figure 3 shows, perhaps not surprisingly, that healthy children tended to have the highest success rates, generally ranging from 80 to 100 percent. There was only one small study that had a lower success rate and the children were toilet trained by the Azrin and Foxx method. Studies conducted with healthy children tended to be a mix of RCTs, and both prospective and retrospective cohorts.

Figure 3. Reported success of toilet training among healthy children

The size of the shape is proportional to sample size.

Square=RCT, circle=prospective cohort, triangle=retrospective cohort.

The studies examining mentally handicapped children were all relatively small and generally prospective in nature. Success rates encompassed the full spectrum from 0 to 100 percent; the operant conditioning method results were particular dispersed (Figure 4).

The studies assessing physically handicapped children primarily used toilet training methods categorized as “other” with the exception of one small study that examined operant conditioning (Figure 5). Similar to studies of mentally handicapped children, success rates were variable, ranging from 15 to 100 percent, although the majority of studies and the larger ones had rates under 50 percent.

Figure 5. Reported success of toilet training among physically handicapped children

The size of the shape is proportional to sample size.

Square=RCT, circle=prospective cohort, triangle=retrospective cohort.

## Direct Comparisons

Healthy children. There were four studies that examined head-to-head comparisons between methods among normal children.

Matson randomized ten children (age 20 to 26 months) into one of the following groups: Azrin and Foxx method with an experienced trainer or mothers training their children using a book to guide the toilet training process.^58^ Four out of five children in the former group were successfully trained, while only one of five in the latter group was completely successful, one obtained partial success, the remaining three failed. The small sample size precludes statistical significance and would in even the most extreme case (80 percent success rate versus 20 percent success rate; p-value for Fisher's exact test (2 sided): 0.21).

The Azrin and Foxx method was also used in an RCT conducted by Candelora (1977) to compare it to the Spock method in 71 healthy children aged 18 to 35 months.^54^ Three primary outcomes were examined: number of accidents, number of successes, and number of wet mornings. Three time periods were examined: pre-treatment, post-treatment, and at follow-up. When looking at difference in pre-training and post-training results as well as in pre-training and follow-up results, the Azrin and Foxx method was found to be superior to the Spock method in all three outcomes. However, there was no significant difference between the groups with respect to post-training and follow up. Using the Azrin and Foxx method, the number of accidents per child per day was reduced by 2.48 from pre-training to post-training under the Azrin and Foxx method and reduced an additional 0.70 at follow-up, resulting in a total reduction of 3.17. For the Spock method, there was a reduction of 1.37 in post-training and an additional 0.52 at follow up (1.90 total reduction). The number of successes per child per day was increased by 2.50 in post-training and by an additional 0.87 at follow-up, for a total increase of 3.37 when using the Azrin and Foxx method. For children trained using the Spock method, there was an increase of 1.12 in post-training and an additional 0.79 in follow-up (1.90 total increase). Finally, the percentage of mornings wet was reduced in the Azrin and Foxx group by 21 percentage points in post-training and an additional 10 points in follow-up (total of 31 percentage points), compared to a reduction in the Spock method of 6 percentage points in post-training and an additional 9 points at follow-up, for a total reduction of 15 percentage points.

Taubman enrolled 406 children aged 17 to 19 months in a toilet training study using a child-oriented approach, and the parents determined when toilet training would commence. The children were randomized into two groups: one group was given instructions to avoid negative terms to describe defecation or to a group who received no such direction.^44^ The groups were equivalent in terms of number of children with stool toileting refusal (STR) (26 percent in the intervention group compared to 23 percent in the control group) but duration of STR was significantly longer in the control group (7.3 months compared to 5.1 months; p=0.03). No significant differences were found between the groups in terms of incidence of stool withholding (intervention 52 percent; control 55 percent) or incidence of hiding during defecation (intervention 68 percent; control 70 percent). The intervention group did find that toilet training was completed significantly sooner (intervention 40 months; control 43 months; p=0.04).

Bakker conducted a retrospective study that collected data on 4332 primary school age children and compared children who did and did not develop abnormal outcomes in bladder control.^59^ There were 3404 children in the control group and 928 in the symptom group. The authors found that significantly more children in the control group had prompting from their parents during toilet training than those in the symptom group (68 percent versus 62 percent; p < 0.001). Parents of the symptom group tended to reward and punish more so than the control group (53 percent versus 46 percent). Parents reacted differently when an attempt to void was unsuccessful. Parents in the control group were much more likely to encourage the child to try again later (83 percent compared to 67 percent; p < 0.001). Those in the symptom group were more likely to make the child wait until voiding (8 percent to 3 percent; p < 0.001), make the child push or strain (13 percent to 5 percent; p < 0.001), make special noises (43 percent to 37 percent; p =0.002), and open a tap (26 percent to 21 percent; p=0.003).

Mentally handicapped children. There were eight studies that contained direct comparisons of interventions in mentally handicapped children: four were RCTs, two were multiple cohort studies, while the remaining two were single cohort studies.

Smith conducted an RCT to look at three methods of training fifteen severely mentally retarded children with social ages ranging from 0.94 to 2.2 years on the VSMS scale.^60^ The first method was an intensive individual regular “potting” program, the second was group training with regular “potting” program and the third was an intensive individual timing training program. The primary difference between regular “potting” and timing training is in which the manner incontinent events are handled. In the timing training method, the child is promoted to toilet and positively reinforced for urinating after an incontinent event. An incontinent event among the regular “potting” group resulted in a reprimand and 10 minute timeout. The number of children who achieved independent toileting at the end of training was 5/5 in the first method, 1/5 in the second method, and 4/5 in the third method. Despite the small sample sizes, the exact three-way test for independence is approaching significance (p=0.051). In addition, the comparison of method 1 versus 2 does show a significantly greater odds of being trained in group 1 (Fisher exact p-value=0.048). Looking at percentage reduction in incontinence and the end of the 12-week study, methods 1 and 3 (about 97 percent and 80 percent respectively) did achieve greater reductions than method 2 (about 45 percent), although the difference was not significant (F p-value=0.10). The authors competed a 10-year follow-up study.^53^ Only one child (in method 1) was still independent after 10 years. The authors also examined incontinence reduction both after the initial study and at the 10-year follow-up, although no comparisons among groups were presented. The first method showed a 99 percent reduction in incontinence after initial training and this dropped to 88 percent after 10 years. For the second method, incontinence was initially 39 percent and improved to 52 percent after 10 years. For the third method, incontinence decreased from 80 percent to 74 percent after 10 years.

Edgar completed an RCT of 20 severely and profoundly retarded children (developmental ages between 15 and 23 months) to examine relaxation methods versus a control group.^57^ Among the children who received relaxation exercises, there was a significant reduction in accidents and toilet training was successful (8/10 versus 2/10; p=0.02). Self-initiated toileting was identical in the two groups: two children from each group eventually achieved it. Compared to the control group, the relaxation group also showed significant reduction in accidental urination and improvement in appropriate urination.

Hundziak randomized 29 severely mentally retarded boys with a social quotient between 8 and 33 months to one of three interventions: operant conditioning, conventional training, or a control group.^55^ Scores for defecation and urination in toilet were determined and non-parametric tests conducted. The operant conditioning group advanced significantly more in both defecation and urination than the conventional training group, and more in defecation (although not in urination) than the control group. There were no significant differences between the conventional and control groups. The authors concluded that the operant conditioning method is useful in training severely retarded children.

Sadler conducted an RCT among 14 severely retarded children aged 7 to 12 years.^56^ Children were randomized to Azrin and Foxx method, a no training group, or a scheduling toilet training method. The primary outcome was the number of accidental urine-dampened pants and was analyzed using a repeated measures ANOVA while controlling for time. Compared to both the no-training group and the scheduling method, the Azrin and Foxx method proved to significantly reduce dampened pants (3 months and 4 months, p < 0.01 in all comparisons). As the experiment continued to its second phase, the scheduling group and half the no-training group were moved to the Azrin and Foxx group, which had a significantly lower number of dampened pants than the remaining no-training group (p < 0.01).

Kimbrell examined 40 severely retarded female children (VSMS range 6 to 28 months).^61^ Based on age, race, length of institutionalization and VSMS, children were systematically allocated to an operant conditioning behavior modification intervention or a control group. Compared to children in the control group, the children receiving operant conditioning had significantly greater gains in the toilet training score component of the VSMS (gain of 4.10 versus 0.30, p < 0.001).

Tierney studied 36 mentally subnormal children with mental ages between 4 and 22 months.^62^ Age, mental age, level of functioning, degree of incontinence, and degree of mobility were used to systematically separate the children into an operant conditioning behavior modification group and a control group. Seven patients in the operant conditioning group achieved consistent continence while an additional seven showed a marked improvement. The remaining four patients failed to improve. None of the eighteen control patients improved. The differences in both achievement of consistent continence and improved continence were significant (Fisher's exact test: p < 0.0001 and p=0.008 respectively).

Connolly looked at nine children between the ages of 3 and 18 years that exhibited moderate to severe mental handicaps.^63^ Four children who were already toilet trained were included as controls. The toilet training program consisted of a three-stage operant conditioning process that involved both positive and negative reinforcement. The amount of soiling and wetting from baseline to program completion improved by 15.8 percent and 75.0 percent respectively. Improvements were still evident at the six-week follow-up; however, they had decreased to 14.0 percent and 25.0 percent respectively. Two of the nine children were considered fully trained.

Lancioni describes two separate experiments on toilet training autistic, retarded children.^64^ The first looked at 5 children (aged 10.6 to 14.6 years) that were divided into two similar interventions. For the 3 children assigned to intervention A, 25 potties were placed throughout the room and there were no potties placed in the room for the 2 children in intervention B. The other aspects of the toilet training program were identical. All three subjects in A showed independent toileting, while neither of the two subjects in B did. For the second phase of the study the two B children were transferred to intervention A and achieved independent toileting. The second study was almost identical in design to the first with the exception that no negative reinforcement was employed. Four children (ages 11.0 to 13.8 years) were put into the two interventions A and B (two in each intervention). Once again the subjects in A exhibited independent toileting, while those in B did not until moved into intervention A for the second phase. The authors conclude that intervention A, with or without negative reinforcement, is effective in promoting independent toileting for autistic, retarded children.

Physically handicapped children. There was only one study that contained direct comparisons of interventions involving physically handicapped children. Van Kuyk (2001) randomized 27 children (aged 2 to 12 years) with Hirschsprung's disease to either a multidisciplinary behavior treatment or a waiting list control.^52^ An ANOVA was performed on the change scores for six different outcomes and the intervention group was found to be significantly superior to the control group in all outcomes. There were three scores used to measure toileting: the Templeton score (intervention: 1.1 reduction; control: 0.0 reduction), the Wingspread score (intervention: 1.3 reduction; control: 0.1 reduction) and the Wingspread constipation score (intervention 0.7 reduction; control: 0.1 reduction). The remaining three outcomes were percent of feces in toilet (intervention: 53.7 percent increase; control: 2.3 percent decrease; p<0.001), number of days without soiling (intervention: 8.4 day increase; control: 0.7 day increase; p<0.001), and scale determining parental judgment incontinence (intervention: 5.2 reduction; control: 0.9 reduction; p<0.05).

## Single Cohorts

Healthy children. Five studies examined toilet training in healthy children: three studies assessed a child-oriented approach and the remaining two evaluated Azrin and Foxx methods.

Three studies examined the child-oriented approach to toilet training. Stool toileting refusal of at least one month duration occurred in 22 percent of the children (106/482) and 29 children required an intervention, such as returning the child to diapers or using suppositories. Stool toileting refusal was associated with presence of a younger sibling and the parents' inability to set limits for the child. The study was conducted in a private pediatric practice of middle and upper class families. In a second study, Brazelton describes 1170 children who were toilet trained during ten years of his pediatric practice.^8^ All children were trained using a child-oriented approach and training occurred in a pressure-free environment and only begun once the child has expressed interest (at approximately 18 months of age). The clinical population consisted of primarily upper-middle class families. For the majority of children, bowel and bladder training occurred simultaneously (930/1170; 79.5 percent). Daytime continence was achieved at a mean age of 28.5 months and nighttime continence by 33.3 months. While males and females completed daytime training at the same age, girls achieved nighttime continence approximately 2.46 months sooner than boys. Sixteen children were not trained by five years of age and suffered from at least one of the following: 12 had enuresis, 4 soiled in stressful situations, and 8 suffered from chronic constipation. Finally, Kaffman examined children living in one of twelve kibbutzes in Israel.^50^ Toilet training is conducted by at least six people and is led by the the head metapelet (caregiver). The toilet training program is child-oriented and is tailored to the child's temperament, emotions, and neurophysiological development. Enuresis was defined as a lack of complete bladder control by the age of three and half years and the prevalence was 13.9 percent (192/1376).

Two studies assessed the Azrin and Foxx method in healthy children. Foxx et al. identified 34 children who previously attempted toilet training. The children were assessed with a screening test to ensure their ability to follow the toilet training program.^9^ Two trainers applied the Azrin and Foxx method and the children were toilet trained with a mean time of 3.9 hours. Older children (aged 26 to 36 months) completed unprompted toileting within 2.3 hours, whereas the younger children required approximately 5 hours. After the Azrin and Foxx method, bladder and bowel accidents were reduced by 97 percent and this success was maintained at four months follow-up. With the exception of one parent, the parents were pleased with their child's progress; however, the parent's displeasure was not related to the toilet training method. A second study examined 49 children toilet trained according to Azrin and Foxx's Toilet Training in Less than a Day program. Parents went to three weekly classes where they were taught the principle of the Azrin and Foxx method. Ten children failed to achieve continence within the intensive training session; nine of the children were less than 25 months of age. Reasons for failure include the child's severe emotional reaction (n=6) and parents quitting the program (n=4). The average toilet training time was 4.5 hours. At 8-week follow-up, bladder and bowel control continued to improve, but many children were lost to follow-up.

Mentally handicapped children. A total of ten studies examined toilet training methods among mentally handicapped children. Four studies assessed variations of the Azrin and Foxx method and six utilized operant conditioning programs.

Five studies examined variants of operant conditioning programs. Van Wagenen used forward-moving series toilet training to toilet train nine mentally handicapped children.^65^ The children wore an alarm that sounded at the time of urination. The trainer then said “no,” led the child to the toilet, and placed the child on the toilet where the child continued to urinate. Once this sequence was established, the alarm was replaced with cotton underwear and the children were taught to dress and undress. All of the children were successfully trained with this method and toileting skills were maintained in different toileting facilities. In the second study, Ando utilized operant conditioning techniques to toilet train five institutionalized autistic boys.^33^ Positive reinforcement for correct toileting included candy, praise, and affection, while physical and verbal punishment was used to negatively reinforce improper toileting behavior. The children were toileted every two hours or when they appeared to have to urinate. Three of the children improved self-initiating toileting (approximate improvement ranged from 30–60 percent). One child had minimal improvement; self-initiating toileting increased from 0 to 20 percent after twelve months of training. The fifth child failed to increase self-initiating toileting and the child did not respond to any of the positive or negative reinforcers. In the third study Giles et al. attempted to toilet train five severely and profoundly mentally retarded children who rarely displayed self-initiated toileting.^11^ Bladder training was only initiated after some bowel continence was achieved. Correct toileting behavior was positively reinforced. If positive reinforcement did not produce behavior modification, aversive consequences in the form of physical restraints were used to correct inappropriate toileting behavior. The length of the training program was eight weeks. All five children were successfully toilet trained. In the fourth study, Spencer attempted to establish bowel control in nine severely and 29 profoundly retarded boys.^66^ The operant conditioning program consisted of positive reinforcement for defecating in the toilet and sitting on the toilet (providing the boys were incontinent at least half of the time). The program was 6 weeks in length. Achieving bowel control was not significantly correlated to mental age, chronological age, leg coordination, sociability, negativism, emotionality, bowel movement frequency, brain damage or, time in institution. Spontaneous toileting increased by 9 percent and accidents decreased by 17 percent. Improvement was more profound in children with a higher degree of incontinence. Using an operant conditioning program, Colwell attempted to improve toileting, dressing, and eating behaviors among 47 profoundly and severely mentally retarded children.^67^ The objective was to bring these behaviors under verbal control. Initially, tangible items were used to positively reinforce proper behavior and were then replaced with social praise. A 23-item toileting scale was used to measure changes in behavior. Follow-up ranged from 3 to 12 months. Thirty-three of the 47 children increased their toileting skills, 3 children decreased toileting skills and the remaining 8 children experienced no change. The mean toileting score improved from 6.0 out of 18.0 at baseline (goes to bathroom area when asked, requires assistance with clothing, and has accidents) to 10.1 after the intervention (toilets on command, manages own clothing, and has few or no accidents).

Four studies evaluated variations of the Azrin and Foxx program. Didden attempted to achieve prompted bowel and bladder control with six children diagnosed with Angelman syndrome.^68^ The daily 6-hour training sessions included walking to the bathroom, drinking every 30 minutes, scheduled toileting in 30-minute intervals, remaining on toilet until elimination or 20 minutes expires, positive reinforcement for successes, and self-dressing. If the child had an accident, the child was reprimanded, changed clothing, cleaned the soiled area, was denied toys, and had a one-hour timeout. Children were followed up at 2.5 years. At baseline, the average frequency of correct daily toileting was 0.8 (SD 0.95). This increased to 3.5 (SD 1.23) at post-treatment and similar results were observed at follow-up (3.1; SD 0.57). The mean time spent toilet training was 108.2 hrs (30.6). In the second study, Lancioni used the Azrin and Foxx method to toilet train nine profoundly deaf and blind children who had never shown any signs of self-initiated toileting.^69^ The training program consisted of increased liquid and decreased food, positive reinforcement for proper toileting behavior and remaining dry, punishment for accidents, increasing distance from the toilet, and removing environmental stimulus. Training was conducted in three phases and followed by a maintenance phase. At day 44 of follow-up, eight of the nine children exhibited self-initiated toilet training. In the third study, Smith retrospectively examined 13 mentally retarded children who were toilet trained by the Azrin and Foxx method.^70^ The children wore a urinary training device, fluid intake was increased, and operant conditioning techniques were used to elicit the desired toileting behavior. At baseline, the children had a 50 percent frequency of wetting accidents, which was reduced to approximately 10 percent by week 5 to 6. All three of the higher social-aged children and three of the five lower social-aged children maintained a near-zero accident rate at follow-up (6 to 18 months). The remaining children experienced a slight increase in accidents. In the final study, a toilet training method similar to that of Azrin and Foxx was used to toilet train nine mentally handicapped children.^71^ The Azrin and Foxx method was augmented with the Big Kids book, which was read to the children at least once a day. There was no punishment or reinforcement of accidents. Follow-up measurements were taken at 2, 4, and 6 weeks. The authors found an increased number of success and a decreased frequency in the number of accidents. When compliance to each component of the toilet training program was measured, there was poor compliance to the Big Kids book and was deemed an unnecessary component to toilet training. In the final study, the population consisting of three healthy children and five mentally handicapped children.^72^ The children were subjected to a two-step operant conditioning program aimed at establishing all components of toileting behavior. During the first step, the children responded to physical, verbal, and auditory stimuli. Prompts were then elicited by the auditory stimulus alone. Seven of the eight children were successfully toilet trained with this method.

Physically handicapped children. Five studies examined toilet training among children with various physical handicaps. All toilet training methods were classified as “other” and, with the exception of two papers,^73^ ^74^ the toilet training programs were different.

Van Kuyk conducted two studies that retrospectively assessed a multidisciplinary toilet training program among children diagnosed with anal atresia^73^ and Hirschsprung's disease.^74^ The toilet training program aimed to teach adequate defecation behavior by reducing fear and anxiety concerning defecation and stool withholding, learning how to use the lower body to defecate, improving straining techniques, and defecating on a regular schedule. The program was conducted by a variety of health care professionals, including a child psychologist, pediatric physiotherapist, and pediatric surgeon. Among the 43 children with anal atresia, there was a significant improvement in the three-point continence score after treatment compared to baseline (Templeton score at baseline: 2.2 ± 0.45; post treatment: 1.6 ± 0.59). The Templeton score measures awareness of impending defecation, occurance of accidental defication, need for additional underwear or diaper liners, presence of diaper rash, social problems, and restriction of phycial activity. There were also significantly fewer children suffering from constipation (18 versus 8). Among the 16 boys diagnosed with Hirschsprung's disease, there was significant improvement in Templeton score after completing the toilet training treatment program. After treatment, the Templeton score decreased to 1.1 (SD 0.34) from 2.7 (SD 0.48). The number of constipated children was reduced from 12 to 4. The treatment was effective, regardless of the age of the child or the specific physical handicap.

Three studies developed toilet training programs for establishing bowel control in children with spina bifida.^51^ ^75^ ^76^ In the study by King, the toilet training program aimed to establish neurogenic bowel habituation.^75^ It included training provided by a psychiatrist and establishing a set time for bowel elimination. Specifically, the bowel was cleaned and stool softeners, glycerin suppositories, bisacodyl suppositories, digital stimulation, and oral medication were incorporated to result in a timed defecation. The age range of the study population was 18 months to 29 years and results were stratified by age (≤6 years versus > 6 years of age). Among children less than or equal to 6 years of age, continence improved from 0 percent (0/17) to 65 percent (11/17) and further improved to 88 percent (8/9) among children who completed to the toilet training program. In the second study, Forsythe created a similar program for 47 children.^76^ The children worked through the following steps sequentially until an intervention was successful: regular toileting after supper, daily enemas, enemas plus suppository or microenema before evening meals, and enemas and daily use of laxatives. At each stage, the prior intervention(s) were also used. Regular toileting resulted in bowel control in 8 of the 47 children (17 percent). Seven of the 39 children (18 percent) achieved bowel control with a combination of regular toileting and enemas; 2 other children experienced initial success but relapsed after 6 to 8 months. Of the 25 children treated with daily suppositories or micro-enemas, enemas, and regular toileting, only 5 children attained bowel control (20 percent). Glycerin suppositories were ineffective; three treatment successes occurred in the bisacodyl group and two in the microenema group. Twenty-seven children received a combination treatment of laxatives, enemas, and regular toileting. Among the 16 children using bisacodyl tablets, 12 were free from stooling accidents and were followed up from 9 to 24 months. All 15 children who received a laxitive syrup experienced bowel control and were followed up for at least 6 months. In the third study, a bowel and bladder toileting program was evaluated in 525 children with spina bifida and aged 1 to 18 years.^51^ The bowel training program consisted of five components: (1) untimed collection of a diaper or insert and cleaning by a primary care giver, (2) infrequent enemas, (3) small, rapid, low-level enemas, (4) suppositories, and (5) timed evacuation with or without digital stimulation. The control program was comprised of (1) diaper or pant insert, (2) penile collectors, and (3) urinary diversions with either timed bladder emptying with or with out medication or clean intermittent catheterization with or without medication. Dependent socially acceptable bowel control among children less than 3 years of age was best achieved with diaper care (15/41) and suppositories (14/41). Thirty-nine of the 41 children were trained. Among children over the age of 4 years, dependent socially acceptable bowel control was best achieved by suppository use (24/184) and expansion enema (12/184). The timed method was most successful for achieving independent socially acceptable bowel control (55/184), followed by suppository use (24/184). Regardless of age, 44 children failed to achieve socially acceptable bowel control. Among children less than 6 years of age, socially acceptable dependent training was most frequency achieved by a diaper/pants insert (32/57). Only one child achieved independent socially acceptable bladder control and this was achieved by clean intermittent catheterization. Socially acceptable independent and dependent bladder control was achieved by ileal diversion (23/158 and 27/158, respectively). In total, 62 children did not achieve socially acceptable bladder control.